# Methods

## Literature Search Strategy

We searched MEDLINE (1966-December 2000), HealthSTAR (1975-December 2000), PsychINFO (1984-December 2000), and Cochrane Library databases using the search strategy in Appendix 1. We combined the Medical Subject Headings hormone replacement therapy and estrogens with the headings dementia, mental processes, cognition disorders, and memory disorders. Additional articles were obtained from reference lists of relevant reviews and from expert reviewers.

## Inclusion/Exclusion Criteria

A single reader reviewed all English abstracts identified by the search and determined if a study would be included in this review by applying inclusion and exclusion criteria (Appendix 2). Studies were considered for inclusion if they provided primary data of the effects of HRT on tests of cognition or memory or on any type of dementia diagnosis. We excluded papers from further review if subjects were not postmenopausal women, subjects had pre-existing dementia, the study did not address links in the analytic framework, or the study was a review, a letter, or an editorial. Only articles published after peer review were included (no abstracts).

In order to identify the most important studies for inclusion in the evidence tables, a "best evidence" approach was used.^ 15 ^ To address the association between HRT and cognitive testing, we included only randomized, double-blind, placebo-controlled trials and cohort studies. Randomized controlled trials tended to include younger, perimenopausal women who used estrogen for short periods (months), while cohort studies included older populations followed for longer periods. Nonrandomized trials, case-control studies, and cross-sectional studies were excluded from the evidence tables on the grounds that they were too subject to bias. Other studies have found that users are healthier, have healthier lifestyles, and are more highly educated than nonusers.^16-20^

To address the association between HRT and dementia, only prospective cohort and case-control studies were included in the evidence table; there were no randomized controlled trials for this question. Cross-sectional studies were felt to be subject to multiple biases because women with dementia would be less likely to be given HRT. For a case-control study to be included, the study methodology had to provide details about how dementia was determined in the cases and excluded in the controls. If two studies were done on the same population, the more recently updated data were included.

## Size of Literature Reviewed

We reviewed all 509 abstracts identified by the search (Appendix 3). We excluded 396 papers from further review because they focused on animals, studied only men, were in a foreign language (unless a key article), or did not address links in the analytic framework; 57 papers were reviews, letters, or editorials. From the original search, 56 articles with primary data on the relationship between HRT and cognition in postmenopausal women without dementia were then identified. An additional 16 articles with primary data were identified from reference lists of relevant reviews.

## Data Extraction and Synthesis

### HRT and Cognitive Function

We reviewed 9 randomized controlled trials and 8 cohort studies of the effects of HRT on cognition as measured by formal cognitive testing. Abstracted data from the trials included the type of study and setting; a description of active treatment and placebo groups, including age and menopausal type; type of HRT and duration of use; whether subjects had menopausal symptoms; and the effects of HRT on symptoms in the treatment groups (to look for unblinding of the study). We recorded study design information such as exclusion/inclusion criteria, method of allocation, and compliance and follow-up rates. In both the randomized controlled trials and cohort studies, we recorded the cognitive tests that were used and the results in users and nonusers. Not all studies used the same types of analyses. We recorded analyses based on either 1) comparisons of the change scores (post-pre) of users with those of nonusers, or 2) if the pretest scores were equal or appropriate adjustments were made, comparisons of the post scores of users with those of nonusers. If between-group comparisons were not available, within-group comparisons were documented. The most adjusted values were recorded. Any trends in duration, currency, or dosage were also noted.

Although the original goal was to quantitatively combine the results of the cognitive tests, the studies were too dissimilar. Instead, the cognitive tests were qualitatively combined according to what they measured (memory, attention, reasoning, mental status, motor speed, verbal function) using a reference guide^ 21 ^ and expert opinion. When possible, we calculated the increment of effect and normalized the scores using a total of 100 points. In some cases, scores were estimated from figures.^22-24^

Two reviewers independently rated the quality of the randomized controlled trials using Jadad scores and had 100% agreement (Appendix 4a).^ 25 ^ For the other studies, we applied quality criteria developed by the methods workgroup of the U.S. Preventive Services Task Force and had 80% agreement (Appendix 4b).^ 26 ^ A final score was reached through consensus if reviewers disagreed. Quality scores are detailed in the evidence tables (Appendix 6).

### HRT and Dementia

We reviewed 10 case-control and 2 cohort studies of the relationship between HRT and risk of dementia of any type. Abstracted data included the type of study and setting; a description of the cases and controls or the users and nonusers, including age, menopausal status (surgical or natural), and education; the type and amount of HRT (formulation, duration, and recency); and any confounders that were controlled. We recorded how the history of HRT exposure was obtained because of the potential for recall bias and proxy bias. Demented women would be less likely than controls to remember previous exposures. Although proxy respondents were used in several of the studies, they may not have accurately remembered exposure history or may not have been aware of hormone use because many women consider this a personal decision. The cohort studies, because they document HRT use prior to the development of Alzheimer disease, are less prone to these biases. However, since Alzheimer disease is an insidious disease with a long latency period,^ 8 ^ a long followup time is needed to avoid finding a falsely low HRT usage rate in women with early cognitive decline.

We also abstracted how the investigators documented dementia in their cases and excluded it in their controls, and whether they used the criteria created by the work group of the National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer Disease and Related Disorders Association (NINCDS-ADRDA). This is the most widely applied criterion for defining Alzheimer disease clinically and requires a medical history; neurologic, psychiatric, and clinical exam; neuropsychological testing; and laboratory studies. Subjects are categorized as having possible, probable, or definite Alzheimer disease. Definite Alzheimer disease can be diagnosed only by the presence of neurofibrillary tangles and senile plaques at autopsy. A subject with a typical, insidious onset of dementia with progression will be given a diagnosis of probable Alzheimer disease once other systemic or brain diseases such as Parkinson disease and multi-infarct dementia are excluded. A possible Alzheimer disease diagnosis is made if the course of dementia is somewhat uncharacteristic or if the subject has other diseases that may be playing a minor role.^ 27 ^ The inter-rater agreement for these criteria ranges from poor to good (Kappa statistic 0.36 to 0.65).^28, 29^ Using pathological diagnosis of Alzheimer disease as the gold standard, a multi-site reliability and validity study found that the NINCDS-ADRDA criteria had a sensitivity of 0.81 and a specificity of 0.73.^ 29 ^ Seventy percent of the errors in this study were false-negatives.

The recorded outcome measures were adjusted odds ratios or relative risks with 95 percent confidence intervals. When confidence intervals were not given, they were calculated using the available data from the original paper. In addition, any duration or recency of use data were recorded. Studies were evaluated for quality using U.S. Preventive Services Task Force criteria as described previously.

We performed a meta-analysis of the 2 cohort^30, 31^ and 10 case-control studies^32-41^ meeting inclusion criteria. The two cohort studies reported adjusted relative risks. Three of the case-control studies provided raw data to calculate the unadjusted odds ratio but did not provide odds ratios from multivariate models.^32-34^ The rest of the case-control studies reported adjusted odds ratios from logistic regression models. Because dementia is a relatively rare event, the odds ratio is a good estimate for the relative risk. For uniformity, we indicated the results from all studies as relative risks (RR).

The logarithm of the relative risk (logRR) was assumed to have a normal distribution. Standard errors for logRR were calculated from reported confidence intervals or p-values. If neither were reported, standard errors were calculated from the raw data. The logRR and the corresponding standard errors were the data points for the meta-analysis.

We tested both fixed-effects and random-effects models. A fixed-effects model is fit on the data and assumes only one source of variability (the variability within studies). It also assumes that the patient populations across studies are sufficiently similar and that the results are suitable to pool together. A random-effects model assumes a second source of variability among studies. Variation among studies implies that each study potentially estimates different effects sizes. Random-effects models are more conservative in the sense that they allow for more variability in treatment effects.^ 42 ^

The Bayesian data analytic framework was used for the meta-analysis. Inference on the parameters was done via posterior probability distributions. The data were analyzed using WinBUGS software,^ 43 ^ which uses a method of Markov Chain Monte Carlo called Gibbs Sampling to simulate posterior probability distributions.

Noninformative prior probability distributions were used. Inference was made on 5,000 simulated draws (1,000 draws from 5 chains) from the posterior distribution after adequate convergence. Sensitivity analysis was performed using different prior distributions, combining only studies with similar methods (using just the cohort studies, the case-control studies, the studies that looked at Alzheimer disease only, and the studies that used NINCDS-ADRDA criteria), excluding poor quality studies and studies with potential proxy bias, and excluding a study with uncertain confidence intervals.

We also evaluated all studies for selection bias using funnel plots^ 44 ^ and investigated the sensitivity of the analysis to possible missing studies due to publication bias by trim and fill^45, 46^. Some asymmetry was detected in the funnel plots, suggesting that study selection bias was possible although interpretation of the plots is subjective.