# Appendix 8. Acknowledgements

This systematic evidence review was prepared for the Agency for Healthcare Research and Quality (contract #290-97-0018, task order no. 2) to be used by the U.S. Preventive Services Task Force. Task Force members Janet Allen, PhD, RN, and Steven Teutsch, MD, MPH, served as liaisons. Jeri Janowsky, PhD, Mark Helfand, MD, MS, and Eric Orwoll, MD provided scientific expertise. Oregon Health & Science University, Evidence-based Practice Center staff who contributed to this project included Peggy Nygren MA, research associate, Susan Wingenfeld, administrative assistant, and Patty Davies, MA, librarian.