# Appendix 7. Acronym/Abbreviation List

Appendix 7. Acronym/Abbreviation List

BID | Twice daily
BMI | Body mass index
BSO | Bilateral salpingo-oophorectomy
BVRT | Benton visual retention test
CASI | Cognitive abilities screening instrument
CCSE | Cognitive capacity screening examination
CE | Conjugated estrogen
CEE | Conjugated equine estrogen
CI | Confidence intervals
CVA | Cerebrovascular accident
FMRI | Functional magnetic resonance imaging
FSH | Follicle stimulating hormone
IM | Intramuscular
IVD | Ischemic vascular disease
MMSE | Mini mental status exam
MPA | Medroxy progesterone acetate
MRI | Magnetic resonance imaging
NINCDS-ADRDA | National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer Disease and Related Disorders Association Criteria for Alzheimer Disease
OR | Odds ratio
pmol/u | Picomole per unit
RR | Relative risk
SOP | Self ordered pointing
USTM | User skills and task match
TAH | Total abdominal hysterectomy
WAIS | Wechsler adult intelligence scale
WMS | Wechsler memory scale
3MS | Modified mini-mental state examination