# Appendix 6. Cognitive Measures Used in Studies

Cognitive Measure | Test | Sub-category | Differences in performance between users and nonusers
Cognitive Measure | Test | Sub-category | Reference Number
Cognitive Measure | Test | Sub-category | 48 | 47 | 49 | 50 | 22 | 23 | 51 | 52 | 59 | 63 | 60 | 24 | 61 | 65 | 64 | 66 | 62
Attention | Attention | Complex attention | | | | | | p<0.01
Attention | Digit Symbol | Complex attention | | NS | | NS | | | | NS | | NS
Attention | Spot Pattern Test | Complex attention | | | | | | | p=0.08
Attention | Trail Making Test-Part B | Complex attention | | | | | | | | | | NS | | | NS
Attention | Arithmetic-Groninger Intelligence test | Mental tracking | | | | | | | | NS
Attention | Auditory Serial Addition Test | Mental tracking | | NS
Attention | Digit Span | Mental tracking | | NS | NS | NS | p<0.01 | | | NS | NS
Attention | Months Backwards | Mental tracking | | | | | | | | | | | | | NS
Attention | Serial Sevens | Mental tracking | | | | | | | | | | | | | NS
Attention | Stroop Color Word Test | Mental tracking | | NS | | | | p<0.01
Attention | World Backwards | Mental tracking | | | | | | | | | | | | | NS
Attention | Letter Cancellation | Vigilance | | NS
Attention | Multi-step Reaction Time | Vigilance | | NS
Attention | Sorting (KVT) | Vigilance | | | | | | p<0.01
Attention | Vigilance Test | Vigilance | | | | | | | p=0.07
Attention | Visual Search | Vigilance | | | | | | p<0.01
Attention | Working Memory | Working memory | | | | | | | | | | | | | | | NS
Attention | Nonverbal Working Mem. Test | Working memory | NS
Attention | Subtraction Test | Working memory | | NS
Attention | Verbal Working Memory Test | Working memory | NS
Attention | Working Memory Task | Working memory | | NS | | | | | | | | | | | | | NS
Attention | Verification Test | Working memory | | NS
Concept Formation & Reasoning | Similarities (WAIS-R) | Concept formation | | | | | | | | | | | NS
Concept Formation & Reasoning | Abstract Reasoning | Reasoning | | | | p<0.01
Learning Ability | Manual Labyrinth of Rey | Learning ability | | | | | | | | NS
Memory | Guild memory Test | Memory battery | | | | | | | p<0.02
Mental Status | CCSE | Mental status | | | | | | | | | | | | | | NS
Mental Status | MMSE | Mental status | | | | | | | | | | NS | | | NS
Mental Status | Modified 3MS | Mental status | | | | | | | | | | | | | | | | p<0.05
Mental Status | CASI | Mental status | | | | | | | | | | | | | | | | | p=0.023
Motor Speed | Simple Reaction Time | Motor speed | | NS | | | | p<0.01
Motor Speed | Clerical Speed and Accuracy | Speed of perception | | | | | p<0.01
Verbal Functions/Language Skills | Boston Naming Test | Verbal expression | | | | | | | | | | | NS
Verbal Functions/Language Skills | Category Naming/Retrieval | Verbal fluency | | | | | | | | | NS | | | | NS
Verbal Memory | 5 Minute Recall | Delayed verbal recall | | | | | | | | | | | | | NS
Verbal Memory | Associate Learning-Delayed | Delayed verbal recall | | p<0.05 | | | | | | | NS
Verbal Memory | Paragraph Recall-Delayed | Delayed verbal recall | | | NS | | | | | | NS
Verbal Memory | Selective Reminding-Delayed | Delayed verbal recall | | | | | | | | | p<0.01 | | p<0.001 | | NS
Verbal Memory | Associate Learning-Intermediate | Delayed verbal recall | | p<0.05 | | | | | | | | NS
Verbal Memory | Paragraph Recall - Intermediate | Delayed verbal recall | | p<0.05 p<0.01 | | | | | | | NS
Verbal Memory | Selective Reminding-Intermediate | Delayed verbal recall | | | | | | | | | NS | | p<0.01 | | NS
Verbal Memory | Visual Paired Associates- Delayed | Delayed verbal recall | | | | | | | | | NS
Verbal Memory | Visual Paired Associates-Intermediate | Immediate verbal recall | | | | | | | | | NS
Verbal Memory | Benton Visual Retention | Visual memory | | NS | | | | | | NS | | | | p=0.05
Verbal Memory | Figural Memory | Visual memory | | | | | | | | | NS
Verbal Memory | Visual Memory Span | Visual memory | | | | | | | | | NS
Verbal Memory | Visual Reproduction (WMS) | Visual memory | | | NS | | | | | | NS | | | | NS