# Appendix 5. Evidence Tables

Evidence Table 1. HRT and Cognition-Randomized Controlled Trials

Author, year | Type of study | How recruited | Setting | Number of subjects | Number originally randomized | Mean age (years) (Range) | Confirm menopause with FSH/estradiol? | Percentage with surgical menopause | Symptomatic? | HRT form | Duration of use | Follow-up rate | Percentage compliant to HRT | Possible confounders? | Method of measuring outcome | Outcome | Results | Analysis | Further explanation of main differences | Additional Information on Study Methodology | Jadad Score
Janowsky 2000^ 64 ^ | Trial | Paid volunteers | Portland, OR | 6 & 7 | Not stated | 69 | Yes | Not stated | Not stated | .625 mg conjugated estrogen | I month | 100% | Not stated | None | Interview | SOP working memory table | Not significant | | | | 2
Shaywitz, 1999^ 48 ^ | Crossover | Paid volunteers from community | New Haven, CT | 46 | 47 | 50.8 (33-61) | Yes | Not stated | Not stated | Oral-CEE 1.25 mg/day | 21 day course with 14 day break | 100% | 94% | Not measured | 1. Interview 2. Functional MRI | Verbal working memory tasks Nonverbal working memory tasks Brain activation | Not significant Not significant Significant | Intention to treat | Increased activation of certain brain areas during verbal storage | 6 not menopausal by FSH/estradiol, did not use standard tests for measuring cognition; May not have been able to discriminate with tests because all scored high-"ceiling effect" | 5
Polo-Kantola, 1998^ 47 ^ | Crossover | Volunteers-newspaper ads | Finland | 62 | 70 | 56.3 (47-65) | Yes | 24% BSO | Not stated | Transdermal- If age <56-Estrogel 0.6 mg/g (2.5 g/d), If age >55-Evorel patch 50 ug/24 hr | 3 month course with 1 month wash-out | 100% | 92% | No difference in depression scores with estrogen therapy | Interview | Simple reaction time Multistep reaction time Subtraction test Statement verification test Auditory serial addition Digit span Digit symbol Benton visual retention Letter cancellation Stroop color word test | Not significant for each test | Only those that complete study | | Mean serum estradiol levels lower with patch (190 vs 431 pmol/u) | 4
Phillips, 1992^ 49 ^ | Trial | Recruitment after TAH/BSO | Canada | 10 & 9 | 31 | overall 48.2 +/- 4.7 | TAH/BSO | 100% TAH/BSO | Yes-Placebo groups with more hot flashes; No difference in mood,depression, anxiety, hostility | 10 mg of estradiol valerate IM each month | 2 months | 100% | 61% | No difference on anxiety, depression, hostility scores | Interview | Digit span (WMS) Paragraph recall-immediate Paragraph recall-delayed Associate learning (WMS)-Immediate associate learning (WMS)-Delayed Visual reproduction (WMS) | Not significant p<0.05 Not significant p<0.05 p<0.05 Not significant | Only those that complete study | Immediate paragraph recall--users had improvement in score;no change in placebo Associate learning--users stayed the same; placebo had decline | Compared pre and post scores. Did not compare scores of the estrogen and placebo groups | 4
Ditkoff, 1991^ 50 ^ | Trial | Not stated | East Los Angeles-Hispanic | 24 & 12 | Not stated | Overall 53 (45-60) | Yes | 100% TAH | No- <4 hot flash episodes for 2 weeks | Oral CEE .625(12) or oral CEE 1.25(12) daily for 25 days/month | 3 months | ?100% | ?100% | Users had improved depression (not controlled) | Interview | Digit span (WAIS) Digit symbol (WAIS) | Not significant Not significant | Not clear | | Hispanic (American born); Compared pre and post scores. Did not compare scores of the estrogen and placebo groups | 4
Sherwin, 1988^ 22 ^ | Crossover | Recruitment after TAH/BSO (cases) or TAH (controls) | Canada | 10&10& 10&10 | 59 | 45.4 | Yes | Cases-100% TAH/BSO | Not specifically stated but most were likely symptomatic after TAH/BSO | 1. Estradiol valerate 10.0 mg IM 2. Testosterone 150 mg IM 3. Estradiol dienanthate 7.5 mg + Estradiol benzoate 1.0 mg + Testosterone 150 mg IM | 2- 3 month treatment periods with 2 month wash out | 100% | 85% | No difference in: baseline scores, education, occupation, personality inventory | Interview | Digit span Clerical speed & accuracy Paragraph recall test Abstract reasoning | p<0.01 p<0.01 p<0.01 p<0.01 | Only those that complete study and compliant | Scores of all treatment groups higher than placebo; Scores of treatment groups dropped during the placebo month (p<0.01) | Only 10 women in estradiol treatment alone; Likely many women with symptoms | 3
Fedor-Freybergh 1977^ 23 ^ | Trial | Recruitment at outpatient clinic | Gynecology clinic in Stockholm | 11 & 10 | 25 | 56.5 (47-70) | Yes | Not stated | Yes. Did not ask about hot flashes but majority had sleep problems, depression, fatigue. | 2 mg estradiol-17B-valerianate (Progynon) daily | 3 months | 100% | 84% (exclude noncompliant) | Estrogen users slightly older and had decreased depression, anxiety, and fatigue and improved sleep | Interview | Subjective cognition Reaction time Visual search Color word test -Stroop Sorting task (KTV) Attention test (USTM) | "More improvement" in estrogen group p<0.001 (for HRT vs placebo);p<.01 (for change HRT) p<0.01 (simple); p<0.001 (with memory load) p<0.01 (simple);p<0.001 (with interference) p<0.01 (time); p<0.001 (errors) p<0.05 (time); p<0.001 (errors) | | Estrogen users improved but placebo with no change | Compared difference in estrogen and placebo groups; Also looked at change in pre and post test score for estrogen and placebo groups--p value for estrogen group and difference between estrogen and placebo same unless specified | 3
Hackman, 1976^ 51 ^ | Trial | Not stated | England | 9 & 9 | Not stated | 29-68 | No | 44% TAH/BSO < 6 months ago | Yes | 1.5 mg piperazine oestrone sulphate twice daily | 6 months | 100% | Not stated | None | Interview | Guild Memory Test | p<0.02 | Not reported | Estrogen users improved but placebo with no change | Did not compare estrogen and placebo groups; No correlation between subjective improvement in memory and GMT Score; 10/18 identified because of menopausal signs/symptoms; Sherwin reanalyzed and did not find significant result; 3 estrogen users had large improvement and 1 had large deterioration; More variation in estrogen group than in nontreated group | 2
Vanhulle, 1976^ 52 ^ | Trial | Volunteers | Nuns in Belgium | 11 & 15 | 12 & 17 | 56.6 (cases) & 58.7 (controls) | No | Not stated | Yes. Estrogen group had fewer menopausal symptoms. Had less hot flashes, chest pressure, and fatigue. | 4 mg estriol daily | 3 months | 100% | 90% | Age | Interview | Subjective cognition, BVRT, Series of numbers (WAIS)(Digit span), Substitution (WAIS) (Digit symbol), Arithmetic (GIT), Manual Labyrinth of Rey, Reaction time, Vigilance, Tempo of work (spot pattern test), Attention (spot pattern test) | "no significant differences" for each test | Only those that complete | Compared difference in means of both groups (pretest-posttest). Estrogen users had greater improvement in scores in vigilance and attention. | Compared difference in means of both groups (pretest-posttest). When compared post-tests, only attention was different (p<0.03 for unadjusted analysis). Change in overall health score--no change in yes but did have change in no's | 3

Evidence Table 2: HRT Cognition--Cohort Studies

Author year | Setting/Project | HRT user (n) | Non-user (n) | Eligibility | Mean Age (years) (User/Nonuser) | Percentage with surgical menopause (User/Nonuser) | Education (years) (User/Nonuser) | Other differences | How determine use/nonuse | Definition user | Definition nonuser | HRT form | Duration of HRT use | Length of follow-up | Follow-up rate | Con-founders controlled | Con-founders not controlled | How outcome determined | Results (For current or ever users - not past users) | Trends | Differences | Comments | Quality Score
Rice, 2000^ 62 ^ | Kame project | Current-196 Past-186 | 455 | Japanese-American living in King County, Washington Aged >65 years with 2 years of followup | 69.61 71.47 72.1 | 45.41 55.41 74.5 | 13.1/12.8/12.1 | | Interview | Current or past use | Never use | Use of any form of unopposed estrogen or combined with progestin | 4 - 15 years | 2 years | 89.9% | Age, education, in care, marital status, birthplace, language, formal education, WSAID, health check-ups, thyroid disease, cancer history, blood pressure, BMI, smoking, physical activity, alcohol, fiber, hysterectomy status, de-pression, age of menarche/menopause | | Cognitive Abilities Screening Instrument (CASI) Abstract reasoning subsection Category fluency subsection Attention subsection Recent verbal memory subsection Mental tracking subsection | p<0.05 p<0.001 p<0.05 Not significant Not significant Not significant | | Significant improvement only seen in users of current unopposed estrogen. Current users of estrogen-progestin actually had decline in scores | | Fair
Carlson 1999^ 59 ^ | McGill University | 14 | 41 | No major acute or chronic medical or psychiatric illness; no psychotropic medications or glucocorticoids | 71.2 | 72.4 | 14.4/11.9 (p<0.05) | Users had higher socio-economic status | Questionnaire | Current use | Not current use | 50% unopposed oral 0.625 mg CEE; 30% CEE with 2.5 mg MPA; 20% CEE 0.30 mg | 19.5 years | 18 months | 67% | Socioeconomic status and years of education | Mood, medical problems | Immediate paragraph recall Delayed paragraph recall Immediate paired associates Delayed paired associates Immediate Selective Reminding Delayed Selective Reminding Immediate visual paired associates Delayed visual paired associates Visual reproduction Figural memory Digit span Visual memory span Category retrieval | Not significant Not significant Not significant Not significant Not significant p<0.01 Not significant Not significant Not significant Not significant Not significant Not significant Not significant | None studied | Users had improvement in scores on delayed selective reminding but non-users had decreased scores | Analysis based on only 10 users and 27 nonusers | Fair
Matthews 1999^ 63 ^ | Study of Osteoporotic Fractures (SOF) | Current-1325 Past-2612 | 5714 | >64 yrs, Not Black, Able to walk without help, No history of bilateral hip replacement | Users younger | Users more likely to report surgical menopause | Users more educated | Users more likely to use sedatives/anxiolytics, less likely to smoke | Interview | Ever use of oral estrogen at initial assessment | Never use of oral estrogen at initial assessment | Oral only | Current-14.3 yr Past-5.2 yr | 4-6 years | 77% | Age, education, activity limitations, initial performance | Mood, medical problems | Modified MMSE Trails B Digit Symbol | Not significant Not significant Not significant | Past users had more benefit than current users | Only past users exhibited smaller decline in MMSE (p=0.03) and Trails B (p=0.02); Current users did not differ from nonusers | When only looked at those who were consistent current, past, or never users, results not changed | Fair
Jacobs, 1998^ 60 ^ | Community based study of aging/dementia in NY | 81 | 646 | Free of dementia, stroke, CVA; complete data | 73.8/74.3 | Not stated | 11.0/9.1 (p<0.05) | Users were more likely to be white; medical conditions not different; same level of depression | Questionnaire | Ever use of HRT | Never use of HRT | Any but most used unopposed oral CEE | 4.55 yr | 2.5 years | 72% | Education, age, ethnicity | Mood, medical problems | Immediate Selective Reminding Delayed Selective Reminding Similaries Subtest Boston Naming Test | p<=0.01 p<=0.001 Not significant Not significant | None studied | Selective Reminding Test-Users with improved scores while nonusers scores declined; No difference in scores over time on other tests | Level of depression did not differ by HRT use history | Fair
Yaffe, 2000^ 66 ^ | Cardiovascular Health Study | Current 297 Past 336 | 2083 | Age >65, community dwelling, able to give informed consent | 70.6/71. 9/72.5 | Not stated | 14.5/13.6/13.4 | Users with younger age, current users drank more alcohol per week | Interview | Current or past use | Never use | Unopposed estrogen only | Not stated | 7 years | 84% | Age, education, race, stroke history | Mood, medical problems | Modified mini mental status exam | p=0.0023 | Only current users had less decline | Current users had a 1.5 point decline in 3 months while never users had a 2.7 point decline | When model was adjusted for confounders, there was no longer a significant difference | Fair
Resnick, 1997^ 24 ^ | Baltimore Longitudinal Study of Aging | 18 | 18 | >39 yr; No dementia; Normal BVRT1 at start; Short interval between HRT use and BVRT; No past use of HRT; No use of vaginal cream only | 59.9/60.2 | 33.3/16.7 | 15.6/15.8 | | Interview | Never user at first test and current user at time of follow-up test | Never user at both tests | Oral or transdermal | | Not stated | Not stated | Age, baseline BVRT score, interval between assessments | Education, mood, symptoms, medical problems | BVRT | p=0.05 | None studied | Users with stable number of errors over time compared to increased number of errors in nonusers | | Poor; Did not state follow-up rate
Barrett-Connor, 1993^ 61 ^ | Rancho Bernardo Cohort | 394 | 406 | >64 years, live in Rancho Bernardo, CA | 76.9 | Not stated | 2/3 completed college or more-not state if users differ | Users were less depressed | Interview; pill & prescription review | Ever use of oral estrogen at initial assessment | Never use of oral estrogen at initial assessment | Any but most used unopposed oral CEE (80% used premarin) | Current-19.1 yr Past-7.7 yr | 15 years | 80% | Education, age, ethnicity | Mood, medical problems | Immediate Selective Reminding MMSE Trails B Category naming/Fluency Visual reproduction tests Months backwards 5 minute recall Serial sevens World backwards | Not significant Not significant Not significant Not significant Not significant Not significant Not significant Not significant Not significant | Long term users (>20 years) scored 1 point higher on Category Fluency than never users (p<0.01) | No difference in age related decrease in cognitive function in current or past users | | Fair
Funk, 1991^ 65 ^ | Veterans Administration longitudinal study of aging | 30 | 77 | Age 40-69, Caucasion | 67 | Not stated | Not stated | Users were more likely to smoke and drink more than 2 alcholic drinks per day | Medical record review | Current use | Not current use | "Almost entirely unopposed" estrogen | Not stated | Maximum of 6 years | Not stated | Length of time since menopause | Education, mood, medical problems | Cognitive Capacity Screening Examination (CCSE) | Not significant | | May have been no difference because of ceiling effects on the CCSE--both groups almost to maximum scores; Cerebral blood flow was in normal range for both groups across the length of the study and no difference in perfusion was seen between groups | Study included women with a history of transient ischemic attacks (TIA) or reversible ischemic neurologic deficits (RIND) but only the results from the women without this history are included in this table; there were benefits on cognition and cerebral blood flow in estrogen users who have history of RIND or TIA | Poor; No education information or adjustment

Evidence Table 3: HRT and Dementia -- Case-Control Studies

Author, year | Setting | Number of Cases/Controls | Type of dementia | Criteria for dementia | How cases were found | Definition of Controls-How exclude dementia | How controls were found | Mean Age (years) (Case/Control) | %surgical menopause (Case/Control) | Average Education (years) (Case/Control) | Other differences | Response rate | How HRT use determined | Definition of HRT use | Definition of Nonuser | HRT form/dose | Duration of HRT use | Confounders controlled | Confounders not controlled | Number cases & controls that used HRT | Adjusted OR (95% CI) | Significance | Trends | Comments | Quality score
Waring, 1999^ 40 ^ | Rochester, Minnesota-Population based | 222/222 | Alzheimer disease | Diagnostic criteria "equivalent" to NINCDS-ADRDA | Rochester Epi Project Records Linkage System & retrospective review of medical records by one neurologist | Extensive medical evaluation in index yr of case but no sign of dementia per neurologist medical record review | Linkage system-residents during index year and matched by age (+/- 3 yr) and length of time in linkage system | Not stated-Case matched to control +/- 3 yr | 10 / 9 | 12 / 12 | Cases with less breast cancer; No difference in age at menarche, age at menopause | Not applicable | Record abstraction-blinded to case/control status or hypothesis | Any form (oral, IM, topical, suppository) of estrogen used for > 6 months after menopause but before onset of Alzheimer disease | Never use | 90% used oral +/- topical; most CEE | Not stated | Age, education, length of time in linkage system | Mood, symptoms, medical problems, ethnicity | 9 & 20 ?? for matched data - which is how got OR for >6 mo. vs. never | 0.42 (0.18-0.96) | p=0.04 | No significant decreased risk with use less 6 months; trend fro decreasing risk with increasing duration(p=0.04); no cumulative dose effect | | Fair
Harwood, 1999^ 41 ^ | Alzheimer disease center-Miami 30% Hispanic | White -229/139 Hispanic-133/53 | Alzheimer disease | NINCDS-ADRDA | Were evaluated at Alzheimer disease center | Age >=65, Normal MMSE, Normal 4 trial recall of 3 words in MMSE | 85% recruited for free memory screening; 9% evaluated at Alzheimer disease center; | Cases-White 79.9/Hispanic 76.0 Controls-White 75.7/Hispanic 71.5 | Not stated | Cases-White 12.1/Hispanic 9.9 Controls-White 13.8/Hispanic 10.8 | Cases with higher alcohol use and more hypertension but not statistically significant | Not stated | Cases- proxy interview Controls-self interview | Ever use | Never use | Not stated | Median 2 years | Education, age | Mood, symptoms, medical problems | White-28 & 44 Hispanic-14 & 35 | White-0.6 (0.3-1.0) Hispanic-0.4 (0.2-1.0) | p=0.05 for both | None stated | Study was of both men and women--info in table on both | Poor
Paganini-Hill, 1996^ 39 ^ | Nested in Leisure World Cohort of 8877 women-Retirement Community California-High Socioeconomic status | 248/1198 | Alzheimer disease | Dementia diagnosis listed on death certificate; exclude multi-infarct dementia or dementia from another likely cause | Death certificate list Alzheimer disease, "senile dementia," "dementia," "senility" | No mention of dementia on death certificate | Death certificates-Matched on year of death and year of birth | 87.7/87.3 | Not stated | Not stated | Significant trend of decreasing risk with increasing weight | Not applicable | Questionnaire prior to death-85% complete >=5 years before death | Ever use | Never use | Any | Not stated | Age, weight, blood pressure medication, weight, menopause type, age, last menstrual period, age at menarche | Mood, education, symptoms, ethnicity | 96 & 568 | 0.65 (0.49-0.88) | p=0.005 | Oral only: 0.7(0.5-0.98); Significant dose trend; Significant duration trend (only users for >5 yrs. Had significant decreased risk of AD) | Did not exclude those with dementia at baseline; Earlier 1994 report had similar results)From previous reports of cohort - primarily Caucasian & highly educated | Poor
Mortel, 1995^ 38 ^ | Baylor College of Medicine and Houston VA | 93(Alzheimer disease)/65(IVD)/148 | 1. Alzheimer disease 2. IVD | 1. NINCDS-ADRDA 2. State of California Alzheimer Disease Diagnostic and Treatment Centers Criteria | Referral by local physicians and support groups Subjects in studies of aging & dementia | Neurological examination and neuropsychologic assessment revealed neurologically, cognitively normal | Friends and relatives | 73.7(Alzheimer disease)/74.4(IVD)/72.3 (Controls) | Not stated | Not stated | No difference in postmenopausal interval, age of onset of dementia, and duration of cognitive impairment for the two demented groups | Not stated | Medical records, questionnaires and interviews-surrogate used for patient with dementia | Current user | Not current user | Not stated | Not stated | For analysis of Alzheimer disease and IVD: none For analysis of all dementia: age | Mood, education, symptoms, ethnicity | 11 (Altzheimer disease) & 7 (IVD) & 29 (Controls) | Alzheimer disease: 0.55(0.26-1.16) IVD: .0.50(0.20-1.2) All: 0.53(0.26-0.94) | Not significant | None stated | | Poor
Henderson, 1994^ 34 ^ | Altzheimer disease research center California | 143/92 | Alzheimer disease | NINCDS-ADRDA (70 confirmed with autopsy) | Volunteers recruited from community outreach who meet criteria for Alzheimer disease by history, exam, lab | Neurological examination and detailed neuropsychologic assessment - nondementia neurologically unimpaired | Volunteers recruited from community outreach in whom Alzheimer disease excluded by exam, assessment | 76.0/76.3 | 39/44 | 12.2/13.9 | No difference in number of medications | Not stated | Cases- proxy interview Controls-self interview | Current user | Not current user | Any (>81% oral CEE) | Not stated | Education, age | Mood, symptoms, ethnicity | 10 & 17 | 0.33 (0.14-0.76) | p=0.01 | | OR is unadjusted, calculated using data in table. Authors state that univariate analysis same as multivariate analysis. | Poor
Brenner, 1994^ 37 ^ | HMO, Washington | 107/120 | Alzheimer disease | NINCDS-ADRDA | Alzheimer disease patient registry in HMO | MMSE score of at least 28 and no evidence of dementia on psychometric evaluation, chart review, judgement of study nurse | Stratified random sample of HMO matched within 2 yr | 78.7/76.6 | 47/16 | Percentage with > 12yrs: 34.6/60.8 | -- | Not stated 2 cases excluded for missing ?? data | 1. From 1977-Computerized pharmacy records 2. Prior 1977-Proxy interview | Ever use, Use in year prior to diagnosis | Never use | Any; 66% used oral CEE | Looked at number of prescriptions | Age, history of hysterectomy before & after age 55, (education & ethnicity not found to be confounders so not included in the model) | Mood, symptoms | 52 & 58 | 1.1 (0.6-1.8) | Not significant | Oral: 0.7 (0.4-1.5); Current 0.6 (0.3-1.2); No dose trend in number of prescriptions | | Good
Graves, 1990^ 35 ^ | Two Alzheimer disease referral centers in Washington State | 60/60 women (130/130 total) | Alzheimer disease | NINCDS-ADRDA | 90% from Alzheimer disease center and 10% from Veteran's Administration | No memory loss (not stated how determine this) | Friends and relatives-matched for sex and age within 10 years | 66.2/63.6 (men & women) | Not stated | Not stated | Cases more likely to have first-degree relative with history of dementia | Screened 800 medical records and 188 met criteria; 143 entered study, 130 provided control | Proxy telephone interview (88% were spouse of >10 years) | "Estrogen replacement" use prior to symptoms | No "estrogen replacement" | Not stated | Not stated | Age | Education, medical problems, symptoms, mood, ethnicity? | 11 & 10 | 1.15 (0.50-2.64) | Not significant | | Study of both men and women; Number of cases and controls may not be correct because they gave percentage and not clear if this is the percentage of the total or of just women (used women); Not blinded interviewers; HRT only one of many risk factors studied; Kappa for agreement in reported HRT use between controls in the validation subsample and their surrogates was 0.64. | Poor
Broe, 1990^ 36 ^ | Two dementia clinics in Sydney, Australia | 106/106 women (170/170 total) | Alzheimer disease | NINCDS-ADRDA | Referral by local physicians who had been requested to refer all new dementia cases | MMSE score of at least 26; Neurology of Aging examination | Clinic controls-matched for sex and age within 2 years | 78.6/78.7 (men & women) 78.6 men 78.7 women | Not stated | Not stated | Cases more likely to have first-degree relative with history of dementia | Screened 333 to obtain 174 Alzheimer disease cases & 170 participants cases; Screened 270 to obtain 170 controls | Proxy interview (>85% were spouse or 1st degree relative) | "Hormonal treatment" | No "hormonal treatment" | Not stated | Daily for at least 6 months | Age | Education, medical problems, symptoms, mood, ethnicity? | 14 & 18 | 0.78 (0.39-1.56) | p=0.48 | | Study of both men and women; Not stated if blinded interviewers; HRT only one of many risk factors studied; Kappa for agreement in reported HRT use between controls in the validation subsample and their surrogates was not specifically stated. | Poor
Amaducci, 1986^ 32 ^ | Neurology departments in Italy | 60 female cases/60 hospital and 50 female community controls (116/116/97 total) | Alzheimer disease | Blessed dementia scale; 2 signs or symptoms of cognitive decline; no depression; no evidence for dementias other than Alzheimer disease by history, exam, testing | Admission to neurology departments of seven centers | Blessed dementia scale excluded dementia | Hospital (116) and friend/neighbor (97) controls-matched for age (within 3 years), sex, and region of residence | 31 aged 51-60; 25 aged 61-70; 19 aged 71-80 for cases | 13.7 / 10.0 had oophorectomy | No significant association found between education/literacy and case/control status | Cases more likely to have first-or second-degree relative with history of dementia | Of 152 eligible admissions, obtained 116 cases; did not state how many screened to get controls | Proxy interview (>90% spouse or offspring); | "Use of estrogens in menopause" | No "use of estrogens in menopause" | Not stated | Not stated | Age, area of residence | Education, medical problems, symptoms, mood, ethnicity? | 6 & 4 | 1.67 (0.39-6.97) | p=0.73 | | Odds ratios and confidence intervals are for population controls-When hospital controls are used the OR is 0.71 with a p value of 0.77; Study of both men and women; Not state if blinded interviewers; Estrogen only one of many risk factors studied; Only 52% of proxy respondents could answer question about estrogen use during menopause; Agreement in reported HRT use between controls in the validation subsample and their surrogates was not specifically stated but was greater than 60%. | Poor
Heyman, 1984^ 33 ^ | Duke Medical Center, North Carolina | 28 female cases/56 female controls (40/80 total) | Alzheimer disease | "Rigorous criteria" | Participants of another comprehensive study of Alzheimer disease | MMSE>20 | Population controls--random digit dialing; matched for sex, race, and 5 year age interval | 60.8 (51-71) for cases | Not stated | 49% of cases and 22% of controls had education beyond high school | Cases had greater history of thyroid disease and history of severe heart disease | Not stated | Proxy interview | Current use of "estrogen replacement" | Not current user | Not stated | Not stated | Age, race, education residence | Medical problems, symptoms, mood | 4 & 4 | 2.17 (0.5-9.41) ^†^ | p>0.05 | | Study of both men and women; Number of cases and controls may not be correct because they gave % and not clear if this % of total or of just women (used women); Not blinded interviewers; HRT only one of many risk factors studied; Kappa for agreement in reported HRT use between controls and their surrogates was 0.63. | Poor

Odds ratios and confidence intervals are unadjusted and calculated from data in tables.

Matched odds ratios and confidence intervals calculated from data in paper using SAS.

^†^Odds ratios and confidence intervals are unadjusted and calculated from data in tables. Adjusted OR given in study is 2.38. Confidence intervals obtained by Yaffe et al were 0.7 to 7.8.

Evidence Table 4. HRT and Dementia -- Cohort Studies

Author year | Cohort | Recruitment Strategy | HRT (n) | Non-user (n) | Mean Age (years) | Percentage with surgical menopause (User/Nonuser) | Education (years) (User/Nonuser) | Other differences | Eligibility | Definition of user | How determine use | HRT form | Duration of use
Kawas, 1997^ 31 ^ | Baltimore Long-itudinal Study of Aging | Not stated | 230 | 242 | 61.5-range 28-94/No difference (data not given) | Not stated | No difference (data not given) 63% college graduates | No difference in age, menopause, type of menopause | Information on HRT, up to 16 yr follow-up | Ever use of oral or trans-dermal | Interview | Oral (212)/Patch (18) | Not stated
Tang, 1996^ 30 ^ | Manhattan Study of Aging | Recruitment from Medicare and senior housing | 156 | 968 | 73.0, 74.4 - users younger (p=0.01) | 50/26 (p=0.0001) | 10.2 / 9.0 (p=0.005) | Users: fewer Blacks, earlier menopause | No cognitive impairment at baseline/Information on HRT | Ever use after meno-pause | Interview | "Majority"-Conjugated Equine Estrogen | 2 mo-49 yrs (average 6.8 yr)