# Appendix 3. Inclusion/Exclusion Criteria

Title and Abstract Review--Exclusion Criteria

1. Non-human
2. Foreign language (unless key article)
3. Looked only at men
4. Did not address links in analytic framework
5. Reviews/letters/editorials that did not seem to offer new perspective or helpful reference list

Literature Review--Inclusion Criteria

1. Human
2. Postmenopausal women
3. Non-demented subjects
4. Any type of study (cohort, cross-sectional, case-control, randomized clinical trial) with primary data on the relationship between HRT and cognition (key question 6a) or HRT and dementia (any type of dementia) (key question 6b)
5. Review all meta-analyses

Evidence Tables -- Inclusion Criteria "Best Evidence Approach"

1. For the association between HRT and cognition, studies that meet the following criteria:
  a. Randomized double-blind placebo-controlled and cohort studies
  b. Objective measurement of cognition (not just subjective cognition)
2. For the association between HRT and dementia, studies that meet the following criteria:
  a. Cohort or case control study
  b. State dementia criteria (state how determined cases had dementia and controls did not)
3. If two reports of the same population, the more recent updated data will be included.
4. Peer reviewed published articles (no abstracts)