# Appendix 1. Search Strategy

Hormone replacement therapy and cognition

1 exp hormone replacement therapy estrogen replacement therapy

2 hormone replacement.tw. (text word taken from title and abstract of article)

3 estrogen replacement.tw.

4 exp estrogens/ad,tu (ad = administration & dosage; tu = therapeutic use)

equilenin | estrogens, catechol
equilin | estrogens, conjugated
estradiol | estrogens, non-steroidal
estriol | estrone

5 exp estrogens, synthetic/ad,tu

estrogens, non-steroidal epimestrol
chlorotrianisene | ethinyl estradiol
coumestrol | mestranol
dienestrol | quinestrol
diethylstilbestrol | hexestrol
zearalenone | zeranol

6 1 or 2 or 3 or 4 or 5

7 exp mental processes

cognition | learning
mental fatigue | mind-body relations (metaphysics)
perception | thinking
volition

8 cognition disorders

9 exp dementia

AIDS dementia complex dementia, vascular
Alzheimer disease | Creutzfeldt-Jakob syndrome

10 exp memory

deja vu | memory, short-term
retention (Psychology) | recall

11 memory disorders

12 7 or 8or 9or 10 or 11

13 6 and 12

14 limit 13 to human

15 limit 14 to english language

16 looked at english abstracts of foreign articles