# Appendixes

Appendix 1. Search Strategy

Appendix 2. HRT and Cognition--Search Results

Appendix 3. Inclusion/Exclusion Criteria

Appendix 4a. Criteria for Grading Quality of Randomized Controlled Trials: The Jadad Score

Appendix 4b. Criteria for Grading the Internal Validity of Individual Studies

Appendix 5. Evidence Tables

Appendix 6. Cognitive Measures Used in Studies

Appendix 7. Acronym/Abbreviation List

Appendix 8. Acknowledgements