# References

1 Developmental Disabilities Monitoring Network Surveillance Year Principal I. Prevalence of autism spectrum disorder among children aged 8 years - autism and developmental disabilities monitoring network, 11 sites, United States, 2010. MMWR Surveill Summ. Mar. 28. Suppl 2. 2014;63:1-21. [pmid: 24670961].
2 Carbone PS, Murphy NA, Norlin C, et al. Parent and pediatrician perspectives regarding the primary care of children with autism spectrum disorders. J Autism Dev Disord. Apr. 2013;43(4):964-72. [pmid: 22948548].
3 Zuckerman KE, Mattox K, Donelan K, et al. Pediatrician identification of Latino children at risk for autism spectrum disorder. Pediatrics. Sep. 2013;132(3):445-53. [pmid: 23958770].
4 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. IV ed. Washington DC. American Psychiatric Association. 2000.
5 Zwaigenbaum L, Bryson S, Lord C, et al. Clinical assessment and management of toddlers with suspected autism spectrum disorder: insights from studies of high-risk infants. Pediatrics. May. 2009;123(5):1383-91. [pmid: 19403506].
6 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. Nov. 2007;120(5):1162-82. [pmid: 17967921].
7 Myers SM. Management of autism spectrum disorders in primary care. Pediatr Ann. Jan. 2009;38(1):42-9. [pmid: 19213293].
8 American Psychiatric Association. DSM-5: The Future of Psychiatric Diagnosis. 2012. http://www.dsm5.org/Pages/Default.aspx.
9 Manning-Courtney P, Murray D, Currans K, et al. Autism spectrum disorders. Curr Probl Pediatr Adolesc Health Care. Jan. 2013;43(1):2-11. [pmid: 23332397].
10 Ozonoff S, Goodlin-Jones BL, Solomon M. Evidence-based assessment of autism spectrum disorders in children and adolescents. J Clin Child Adolesc Psychol. Sep. 2005;34(3):523-40. [pmid: 16083393].
11 Fecteau S, Mottron L, Berthiaume C, et al. Developmental changes of autistic symptoms. Autism. Sep. 2003;7(3):255-68. [pmid: 14516059].
12 Shattuck PT, Seltzer MM, Greenberg JS, et al. Change in autism symptoms and maladaptive behaviors in adolescents and adults with an autism spectrum disorder. J Autism Dev Disord. Oct. 2007;37(9):1735-47. [pmid: 17146700].
13 McGovern CW, Sigman M. Continuity and Change from Early Childhood to Adolescence in Autism. Journal of Child Psychology and Psychiatry. 2005;46(4):401-8. [pmid: 15819649].
14 Seltzer MM, Shattuck P, Abbeduto L, et al. Trajectory of development in adolescents and adults with autism. Ment Retard Dev Disabil Res Rev. 2004;10(4):234-47. [pmid: 15666341].
15 Mahjouri S, Lord CE. What the DSM-5 Portends for Research, Diagnosis, and Treatment of Autism Spectrum Disorders. Curr Psychiatry Rep. Dec. 2012;14(6):739-47. [pmid: 22991100].
16 Billstedt E, Gillberg C, Gillberg C. Autism after Adolescence: Population-Based 13- to 22-Year Followup Study of 120 Individuals with Autism Diagnosed in Childhood. Journal of Autism and Developmental Disorders. Jun. 2005;35(3):351-60. [pmid: 16119476].
17 Eaves LC, Ho HH. Young Adult Outcome of Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. Apr. 2008;38(4):739-47. [pmid: 17764027].
18 Howlin P, Goode S, Hutton J, et al. Adult outcome for children with autism. J Child Psychol Psychiatry. Feb. 2004;45(2):212-29. [pmid: 14982237].
19 Taylor JL, Seltzer MM. Employment and post-secondary educational activities for young adults with autism spectrum disorders during the transition to adulthood. J Autism Dev Disord. May. 2011;41(5):566-74. [pmid: 20640591].
20 Folstein SE, Rosen-Sheidley B. Genetics of autism: complex aetiology for a heterogeneous disorder. Nat Rev Genet. Dec. 2001;2(12):943-55. [pmid: 11733747].
21 Bailey A, Le Couteur A, Gottesman I, et al. Autism as a strongly genetic disorder: evidence from a British twin study. Psychol Med. Jan. 1995;25(1):63-77. [pmid: 7792363].
22 Marshall CR, Scherer SW. Detection and characterization of copy number variation in autism spectrum disorder. Methods Mol Biol. 2012;838:115-35. [pmid: 22228009].
23 Geschwind DH. Genetics of autism spectrum disorders. Trends Cogn Sci. Sep. 2011;15(9):409-16. [pmid: 21855394].
24 Hallmayer J, Cleveland S, Torres A, et al. Genetic heritability and shared environmental factors among twin pairs with autism. Arch Gen Psychiatry. Nov. 2011;68(11):1095-102. [pmid: 21727249].
25 Bristol MM, Cohen DJ, Costello EJ, et al. State of the science in autism: report to the National Institutes Health. J Autism Dev Disord. Apr. 1996;26(2):121-54. [pmid: 8744475].
26 Krakowiak P, Walker CK, Bremer AA, et al. Maternal metabolic conditions and risk for autism and other neurodevelopmental disorders. Pediatrics. May. 2012;129(5):e1121-8. [pmid: 22492772].
27 Dodds L, Fell DB, Shea S, et al. The role of prenatal, obstetric and neonatal factors in the development of autism. J Autism Dev Disord. Jul. 2011;41(7):891-902. [pmid: 20922473].
28 Sandin S, Hultman CM, Kolevzon A, et al. Advancing maternal age is associated with increasing risk for autism: a review and meta-analysis. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):477-86 e1. [pmid: 22525954].
29 Shelton JF, Tancredi DJ, Hertz-Picciotto I. Independent and dependent contributions of advanced maternal and paternal ages to autism risk. Autism Res. Feb. 2010;3(1):30-9. [pmid: 20143326].
30 Bhandari A, Sandlow JI, Brannigan RE. Risks to offspring associated with advanced paternal age. J Androl. Mar-Apr. 2011;32(2):121-2. [pmid: 20467047].
31 Gunnes N, Suren P, Bresnahan M, et al. Interpregnancy interval and risk of autistic disorder. Epidemiology. Nov. 2013;24(6):906-12. [pmid: 24045716].
32 Cheslack-Postava K, Liu K, Bearman PS. Closely spaced pregnancies are associated with increased odds of autism in California sibling births. Pediatrics. Feb. 2011;127(2):246-53. [pmid: 21220394].
33 Shelton JF, Hertz-Picciotto I, Pessah IN. Tipping the balance of autism risk: potential mechanisms linking pesticides and autism. Environ Health Perspect. Jul. 2012;120(7):944-51. [pmid: 22534084].
34 Schultz ST. Does thimerosal or other mercury exposure increase the risk for autism? A review of current literature. Acta Neurobiol Exp (Wars). 2010;70(2):187-95. [pmid: 20628442].
35 Ozonoff S, Young GS, Carter A, et al. Recurrence risk for autism spectrum disorders: a Baby Siblings Research Consortium study. Pediatrics. Sep. 2011;128(3):e488-95. [pmid: 21844053].
36 Gronborg TK, Schendel DE, Parner ET. Recurrence of autism spectrum disorders in full- and half-siblings and trends over time: a population-based cohort study. JAMA Pediatr. Oct. 2013;167(10):947-53. [pmid: 23959427].
37 Mandell DS, Listerud J, Levy SE, et al. Race differences in the age at diagnosis among medicaid-eligible children with autism. J Am Acad Child Adolesc Psychiatry. Dec. 2002;41(12):1447-53. [pmid: 12447031].
38 Warren ZE, Stone W. Best practices: Early diagnosis and psychological assessment. Autism Spectrum Disorders. New York. Oxford University Press. 2011:1271-82.
39 Pierce K, Carter C, Weinfeld M, et al. Detecting, studying, and treating autism early: the one-year well-baby check-up approach. J Pediatr. Sep. 2011;159(3):458-65 e1-6. [pmid: 21524759].
40 Stahmer AC, Mandell DS. State infant/toddler program policies for eligibility and services provision for young children with autism. Adm Policy Ment Health. Jan. 2007;34(1):29-37. [pmid: 16758329].
41 National Autism Center. National Standards Report. Randolph, MA. National Autism Center. 2009. Available from: http://www.nationalautismcenter.org/pdf/NAC%20Standards%20Report.pdf.
42 Committee on Educational Interventions for Children with Autism. Educating Children with Autism. Washington DC. National Academies Press. 2001. Available from: http://www.nap.edu/openbook.php?record_id=10017&page=R2.
43 Filipek PA, Accardo PJ, Ashwal S, et al. Practice parameter: screening and diagnosis of autism: report of the Quality Standards Subcommittee of the American Academy of Neurology and the Child Neurology Society. Neurology. Aug. 22. 2000;55(4):468-79. [pmid: 10953176].
44 Volkmar F, Cook E Jr., Pomeroy J, et al. Summary of the Practice Parameters for the Assessment and Treatment of Children, Adolescents, and Adults with Autism and other Pervasive Developmental Disorders. American Academy of Child and Adolescent Psychiatry. J Am Acad Child Adolesc Psychiatry. Dec. 1999;38(12):1611-6. [pmid: 10596264].
45 Johnson CP, Myers SM. Identification and evaluation of children with autism spectrum disorders. Pediatrics. Nov. 2007;120(5):1183-215. [pmid: 17967920].
46 Technical report: the pediatrician's role in the diagnosis and management of autistic spectrum disorder in children. Pediatrics. May. 2001;107(5):E85. [pmid: 11331735].
47 UK National Screening Committee. The UK NSC recommendation on Autism screening in children. 2012. Available from: http://www.screening.nhs.uk/autism.
48 Scottish Intercollegiate Guidelines Network. Assessment, diagnosis and clinical interventions for children and young people with autism spectrum disorders. 2007. Available from: http://www.sign.ac.uk/pdf/sign98.pdf.
49 Swanson AR, Warren ZE, Stone WL, et al. The diagnosis of autism in community pediatric settings: Does advanced training facilitate practice change?. Autism. 2013. Jul. 11. [pmid: 23847130].
50 Reed P, Osborne LA. Diagnostic practice and its impacts on parental health and child behaviour problems in autism spectrum disorders. Arch Dis Child. Oct. 2012;97(10):927-31. [pmid: 22806234].
51 Hyman SL, Johnson JK. Autism and Pediatric Practice: Toward a Medical Home. Journal of Autism and Developmental Disorders. 2012;42(6):1156-64. [pmid: 22411200].
52 Dosreis S, Weiner CL, Johnson L, et al. Autism spectrum disorder screening and management practices among general pediatric providers. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S88-94. [pmid: 16685190].
53 Kennedy T, Regehr G, Rosenfield J, et al. Exploring the gap between knowledge and behavior: a qualitative study of clinician action following an educational intervention. Acad Med. May. 2004;79(5):386-93. [pmid: 15107277].
54 Zwaigenbaum L, Bryson S, Garon N. Early identification of autism spectrum disorders. Behav Brain Res. Aug. 15. 2013;251:133-46. [pmid: 23588272].
55 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. [pmid: 21834171].
56 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
57 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force (USPSTF) Procedure Manual. 2008. Available from: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
58 Ben-Sasson A, Habib S, Tirosh E. Feasibility and Validity of Early Screening for Identifying Infants With Poor Social-Communication Development in a Well-Baby Clinic System. J Pediatr Nurs. 2013. Nov. 25. [pmid: 24333238].
59 Kamio Y, Inada N, Koyama T, et al. Effectiveness of Using the Modified Checklist for Autism in Toddlers in Two-Stage Screening of Autism Spectrum Disorder at the 18-Month Health Check-Up in Japan. J Autism Dev Disord. 2013. Jun. 6. [pmid: 23740200].
60 Posserud M-B, Breivik K, Gillberg C, et al. ASSERT—The Autism Symptom SElf-ReporT for adolescents and adults: Bifactor analysis and validation in a large adolescent population. Research in Developmental Disabilities. 2013;34(12):4495-503. [pmid: 24176259].
61 Robins DL, Casagrande K, Barton M, et al. Validation of the Modified Checklist for Autism in Toddlers, Revised With Followup (M-CHAT-R/F). Pediatrics. 2013. Dec. 23. [pmid: 24366990].
62 Nygren G, Sandberg E, Gillstedt F, et al. A new screening programme for autism in a general population of Swedish toddlers. Res Dev Disabil. Jul-Aug. 2012;33(4):1200-10. [pmid: 22502846].
63 Miller JS, Gabrielsen T, Villalobos M, et al. The each child study: systematic screening for autism spectrum disorders in a pediatric setting. Pediatrics. May. 2011;127(5):866-71. [pmid: 21482605].
64 VanDenHeuvel A, Fitzgerald M, Greiner B, et al. Screening for autistic spectrum disorder at the 18-month developmental assessment: a population-based study. Ir Med J. Sep. 2007;100(8):565-7. [pmid: 17955715].
65 Dietz C, Swinkels SH, van Daalen E, et al. Parental compliance after screening social development in toddlers. Arch Pediatr Adolesc Med. Apr. 2007;161(4):363-8. [pmid: 17404133].
66 Dietz C, Swinkels S, van Daalen E, et al. Screening for autistic spectrum disorder in children aged 14-15 months. II: population screening with the Early Screening of Autistic Traits Questionnaire (ESAT). Design and general findings. J Autism Dev Disord. Aug. 2006;36(6):713-22. [pmid: 16633887].
67 Kleinman JM, Robins DL, Ventola PE, et al. The modified checklist for autism in toddlers: a followup study investigating the early detection of autism spectrum disorders. J Autism Dev Disord. May. 2008;38(5):827-39. [pmid: 17882539].
68 Bi C, Wu J, Jiang T, et al. Mutations of ANK3 identified by exome sequencing are associated with autism susceptibility. Hum Mutat. Dec. 2012;33(12):1635-8. [pmid: 22865819].
69 Robins DL. Screening for autism spectrum disorders in primary care settings. Autism. Sep. 2008;12(5):537-56. [pmid: 18805946].
70 Pandey J, Verbalis A, Robins DL, et al. Screening for autism in older and younger toddlers with the Modified Checklist for Autism in Toddlers. Autism. Sep. 2008;12(5):513-35. [pmid: 18805945].
71 Robins DL, Fein D, Barton ML, et al. The Modified Checklist for Autism in Toddlers: an initial study investigating the early detection of autism and pervasive developmental disorders. J Autism Dev Disord. Apr. 2001;31(2):131-44. [pmid: 11450812].
72 Honda H, Shimizu Y, Nitto Y, et al. Extraction and Refinement Strategy for detection of autism in 18-month-olds: a guarantee of higher sensitivity and specificity in the process of mass screening. J Child Psychol Psychiatry. Aug. 2009;50(8):972-81. [pmid: 19298465].
73 Barbaro J, Ridgway L, Dissanayake C. Developmental surveillance of infants and toddlers by maternal and child health nurses in an Australian community-based setting: promoting the early identification of autism spectrum disorders. J Pediatr Nurs. Aug. 2011;26(4):334-47. [pmid: 21726784].
74 Barbaro J, Dissanayake C. Prospective identification of autism spectrum disorders in infancy and toddlerhood using developmental surveillance: the social attention and communication study. J Dev Behav Pediatr. Jun. 2010;31(5):376-85. [pmid: 20495475].
75 Baird G, Charman T, Baron-Cohen S, et al. A screening instrument for autism at 18 months of age: a 6-year followup study. J Am Acad Child Adolesc Psychiatry. Jun. 2000;39(6):694-702. [pmid: 10846303].
76 Wetherby AM, Brosnan-Maddox S, Peace V, et al. Validation of the infant-toddler checklist as a broadband screener for autism spectrum disorders from 9 to 24 months of age. Autism. 2008;12(5):487-511. [pmid: 18805944].
77 Inada N, Koyama T, Inokuchi E, et al. Reliability and validity of the Japanese version of the Modified Checklist for autism in toddlers (M-CHAT). Research in Autism Spectrum Disorders. 2011;5(1):330-6.
78 Canal-Bedia R, Garcia-Primo P, Martin-Cilleros MV, et al. Modified checklist for autism in toddlers: cross-cultural adaptation and validation in Spain. J Autism Dev Disord. Oct. 2011;41(10):1342-51. [pmid: 21161677].
79 Turner-Brown LM, Baranek GT, Reznick JS, et al. The First Year Inventory: A longitudinal followup of 12-month-old to 3-year-old children. Autism. 2013;17(5):527-40. [pmid: 22781058].
80 Oosterling I, Rommelse N, de Jonge M, et al. How useful is the Social Communication Questionnaire in toddlers at risk of autism spectrum disorder?. J Child Psychol Psychiatry. Nov. 2010;51(11):1260-8. [pmid: 20626528].
81 Oosterling IJ, Swinkels SH, van der Gaag RJ, et al. Comparative analysis of three screening instruments for autism spectrum disorder in toddlers at high risk. J Autism Dev Disord. Jun. 2009;39(6):897-909. [pmid: 19205862].
82 Oosterling IJ, Wensing M, Swinkels SH, et al. Advancing early detection of autism spectrum disorder by applying an integrated two-stage screening approach. J Child Psychol Psychiatry. Mar. 2010;51(3):250-8. [pmid: 19843319].
83 Koyama T, Inokuchi E, Inada N, et al. Utility of the Japanese version of the Checklist for Autism in Toddlers for predicting pervasive developmental disorders at age 2. Psychiatry Clin Neurosci. Jun. 2010;64(3):330-2. [pmid: 20602732].
84 LoVullo SV, Matson JL. Development of a critical item algorithm for the Baby and Infant Screen for Children with aUtIsm Traits. Research in Autism Spectrum Disorders. 2012;6(1):378-84.
85 Kozlowski AM, Matson JL, Worley JA, et al. Defining characteristics for young children meeting cutoff on the Modified Checklist for Autism in Toddlers. Research in Autism Spectrum Disorders. 2012;6(1):472-9.
86 Matson JL, Wilkins J, Sharp B, et al. Sensitivity and specificity of the Baby and Infant Screen for Children with Autism Traits (BISCUIT): Validity and cutoff scores for autism and PDD-NOS in toddlers. Research in Autism Spectrum Disorders. 2009;3(4):924-30.
87 Matson JL, Fodstad JC, Dempsey T. What symptoms predict the diagnosis of autism or PDD-NOS in infants and toddlers with developmental delays using the Baby and Infant Screen for aUtIsm Traits. Dev Neurorehabil. 2009;12(6):381-8. [pmid: 20205546].
88 Gray KM, Tonge BJ, Sweeney DJ, et al. Screening for autism in young children with developmental delay: an evaluation of the developmental behaviour checklist: early screen. J Autism Dev Disord. Jul. 2008;38(6):1003-10. [pmid: 17972169].
89 Corsello C, Hus V, Pickles A, et al. Between a ROC and a hard place: decision making and making decisions about using the SCQ. J Child Psychol Psychiatry. Sep. 2007;48(9):932-40. [pmid: 17714378].
90 Nadig AS, Ozonoff S, Young GS, et al. A prospective study of response to name in infants at risk for autism. Arch Pediatr Adolesc Med. Apr. 2007;161(4):378-83. [pmid: 17404135].
91 Allen CW, Silove N, Williams K, et al. Validity of the social communication questionnaire in assessing risk of autism in preschool children with developmental problems. J Autism Dev Disord. Aug. 2007;37(7):1272-8. [pmid: 17080270].
92 Eaves LC, Wingert H, Ho HH. Screening for autism: agreement with diagnosis. Autism. May. 2006;10(3):229-42. [pmid: 16682396].
93 Eaves LC, Ho HH. The very early identification of autism: outcome to age 4 1/2-5. J Autism Dev Disord. Aug. 2004;34(4):367-78. [pmid: 15449513].
94 Feldman MA, Ward RA, Savona D, et al. Development and initial validation of a parent report measure of the behavioral development of infants at risk for autism spectrum disorders. J Autism Dev Disord. Jan. 2012;42(1):13-22. [pmid: 21387111].
95 Snow AV, Lecavalier L. Sensitivity and specificity of the Modified Checklist for Autism in Toddlers and the Social Communication Questionnaire in preschoolers suspected of having pervasive developmental disorders. Autism. Nov. 2008;12(6):627-44. [pmid: 19005032].
96 Myers CL, Gross AD, McReynolds BM. Broadband Behavior Rating Scales as Screeners for Autism?. J Autism Dev Disord. 2013. Nov. 28. [pmid: 24287879].
97 Oner P, Oner O, Munir K. Three-item Direct Observation Screen (TIDOS) for autism spectrum disorder. Autism. 2013. Oct. 14. [pmid: 24126869].
98 Koh HC, Lim SH, Chan GJ, et al. The Clinical Utility of the Modified Checklist for Autism in Toddlers with High Risk 18-48 Month Old Children in Singapore. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812662].
99 Williams K, Perkins D, Wheeler D, et al. Can questions about social interaction correctly identify preschool aged children with autism?. J Paediatr Child Health. Feb. 2013;49(2):E167-74. [pmid: 23350819].
100 Narzisi A, Calderoni S, Maestro S, et al. Child Behavior Check List 1(1/2)-5 as a tool to identify toddlers with autism spectrum disorders: a case-control study. Res Dev Disabil. Apr. 2013;34(4):1179-89. [pmid: 23376628].
101 Chlebowski C, Robins DL, Barton ML, et al. Large-scale use of the modified checklist for autism in low-risk toddlers. Pediatrics. Apr. 2013;131(4):e1121-7. [pmid: 23530174].
102 Kamio Y, Inada N, Koyama T. A nationwide survey on quality of life and associated factors of adults with high-functioning autism spectrum disorders. Autism. 2013;17(1):15-26. [pmid: 22399449].
103 Dawson G, Rogers S, Munson J, et al. Randomized, controlled trial of an intervention for toddlers with autism: the Early Start Denver Model. Pediatrics. Jan. 2010;125(1):e17-23. [pmid: 19948568].
104 Dawson G, Jones EJ, Merkle K, et al. Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. Nov. 2012;51(11):1150-9. [pmid: 23101741].
105 Itzchak EB, Zachor DA. Who Benefits from Early Intervention in Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 2011;5(1):345-50.
106 Zachor DA, Itzchak EB. Treatment Approach, Autism Severity and Intervention Outcomes in Young Children. Research in Autism Spectrum Disorders. 2010;4(3):425-32.
107 Eldevik S, Hastings RP, Jahr E, et al. Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. Feb. 2012;42(2):210-20. [pmid: 21472360].
108 Eikeseth S, Klintwall L, Jahr E, et al. Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention in Mainstream Preschool and Kindergarten Settings. Research in Autism Spectrum Disorders. 2012;6(2):829-35.
109 Flanagan HE, Perry A, Freeman NL. Effectiveness of large-scale community-based intensive Behavioral Intervention: A waitlist comparison study exploring outcomes and predictors. Research in Autism Spectrum Disorders. 2012;6(2):673-82.
110 Zachor DA, Ben-Itzchak E, Rabinovich A-L, et al. Change in autism core symptoms with intervention. Research in Autism Spectrum Disorders. 2007;1(4):304-17.
111 Howard JS, Sparkman CR, Cohen HG, et al. A comparison of intensive behavior analytic and eclectic treatments for young children with autism. Res Dev Disabil. Jul-Aug. 2005;26(4):359-83. [pmid: 15766629].
112 Strain PS, Bovey EH. Randomized, Controlled Trial of the Leap Model of Early Intervention for Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(3):133-54.
113 Boyd BA, Hume K, McBee MT, et al. Comparative Efficacy of LEAP, TEACCH and Non-Model-Specific Special Education Programs for Preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812661].
114 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov-Dec. 2010;31(6):1678-84. [pmid: 20627451].
115 Hayward D, Eikeseth S, Gale C, et al. Assessing progress during treatment for young children with autism receiving intensive behavioural interventions. Autism. Nov. 2009;13(6):613-33. [pmid: 19933766].
116 Eikeseth S, Hayward D, Gale C, et al. Intensity of Supervision and Outcome for Preschool Aged Children Receiving Early and Intensive Behavioral Interventions: A Preliminary Study. Research in Autism Spectrum Disorders. Jan. 2009;3(1):67-73.
117 Eikeseth S, Smith T, Jahr E, et al. Intensive behavioral treatment at school for 4- to 7-year-old children with autism. A 1-year comparison controlled study. Behav Modif. Jan. 2002;26(1):49-68. [pmid: 11799654].
118 Eikeseth S, Smith T, Jahr E, et al. Outcome for children with autism who began intensive behavioral treatment between ages 4 and 7: a comparison controlled study. Behav Modif. May. 2007;31(3):264-78. [pmid: 17438342].
119 Cohen H, Amerine-Dickens M, Smith T. Early intensive behavioral treatment: replication of the UCLA model in a community setting. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S145-55. [pmid: 16685181].
120 Smith T, Groen AD, Wynn JW. Randomized trial of intensive early intervention for children with pervasive developmental disorder. Am J Ment Retard. Jul. 2000;105(4):269-85. [pmid: 10934569].
121 Peters-Scheffer N, Didden R, Mulders M, et al. Effectiveness of low intensity behavioral treatment for children with autism spectrum disorder and intellectual disability. Research in Autism Spectrum Disorders. 2013;7(9):1012-25.
122 Sallows GO, Graupner TD. Intensive behavioral treatment for children with autism: four-year outcome and predictors. Am J Ment Retard. Nov. 2005;110(6):417-38. [pmid: 16212446].
123 Reed P, Osborne LA, Corness M. Brief report: relative effectiveness of different home-based behavioral approaches to early teaching intervention. J Autism Dev Disord. Oct. 2007;37(9):1815-21. [pmid: 17180714].
124 Landa RJ, Holman KC, O'Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. [pmid: 21126245].
125 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. Nov. Suppl 2. 2012;130:S186-90. [pmid: 23118250].
126 Strauss K, Vicari S, Valeri G, et al. Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. Mar-Apr. 2012;33(2):688-703. [pmid: 22188793].
127 Fava L, Strauss K, Valeri G, et al. The Effectiveness of a Cross-Setting Complementary Staff- and Parent-Mediated Early Intensive Behavioral Intervention for Young Children with ASD. Research in Autism Spectrum Disorders. 2011;5(4):1479-92. EJ927555.
128 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. Mar. 2013;17(2):220-41. [pmid: 21949005].
129 Rogers SJ, Estes A, Lord C, et al. Effects of a brief Early Start Denver Model (ESDM)–based parent intervention on toddlers at risk for autism spectrum disorders: A randomized controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(10):1052-65. [pmid: 23021480].
130 Estes A, Vismara L, Mercado C, et al. The Impact of Parent-Delivered Intervention on Parents of Very Young Children with Autism. J Autism Dev Disord. 2013. Jul. 10. [pmid: 23838727].
131 Roberts J, Williams K, Carter M, et al. A Randomised Controlled Trial of Two Early Intervention Programs for Young Children with Autism: Centre-Based with Parent Program and Home-Based. Research in Autism Spectrum Disorders. 2011;5(4):1553-66.
132 Reed P, Osborne L. Impact of Severity of Autism and Intervention Time-Input on Child Outcomes: Comparison across Several Early Interventions. British Journal of Special Education. 2012;39(3):130-6.
133 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. [pmid: 20440639].
134 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of Hanen's ‘More Than Words’ in toddlers with early autism symptoms. Journal of Child Psychology and Psychiatry. 2011;52(7):741-52. [pmid: 21418212].
135 Green J, Charman T, McConachie H, et al. Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. 2010. May. 20. [pmid: 20494434].
136 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. Dec. 2002;11(6):266-72. [pmid: 12541005].
137 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. [pmid: 15482502].
138 Aldred C, Green J, Emsley R, et al. Mediation of treatment effect in a communication intervention for pre-school children with autism. Journal of Autism and Developmental Disorders. 2012;42(3):447-54. [pmid: 21512834].
139 Keen D, Couzens D, Muspratt S, et al. The effects of a parent-focused intervention for children with a recent diagnosis of autism spectrum disorder on parenting stress and competence. Research in Autism Spectrum Disorders. 2010;4(2):229-41.
140 Schreibman L, Stahmer AC. A Randomized Trial Comparison of the Effects of Verbal and Pictorial Naturalistic Communication Strategies on Spoken Language for Young Children with Autism. J Autism Dev Disord. 2013. Nov. 23. [pmid: 24272416].
141 Perry A, Blacklock K, Dunn Geier J. The relative importance of age and IQ as predictors of outcomes in Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2013;7(9):1142-50.
142 Kasari C, Lawton K, Shih W, et al. Caregiver-mediated intervention for low-resourced preschoolers with autism: an RCT. Pediatrics. Jul. 2014;134(1):e72-9. [pmid: 24958585].
143 Wong CS. A play and joint attention intervention for teachers of young children with Autism: A randomized controlled pilot study. Autism. May. 2013. 2013;17(3):340-57. [pmid: 23610236].
144 Warreyn P, Roeyers H. See what I see, do as I do: Promoting joint attention and imitation in preschoolers with autism spectrum disorder. Autism. 2013. Oct. 8. [pmid: 24104513].
145 Venker CE, McDuffie A, Weismer SE, et al. Increasing Verbal Responsiveness in Parents of Children with Autism: A Pilot Study. Autism: The International Journal of Research and Practice. 2012;16(6):568-85. [pmid: 21846665].
146 Kaale A, Smith L, Sponheim E. A randomized controlled trial of preschool-based joint attention intervention for children with autism. J Child Psychol Psychiatry. Jan. 2012;53(1):97-105. [pmid: 21883204].
147 Siller M, Hutman T, Sigman M. A Parent-Mediated Intervention to Increase Responsive Parental Behaviors and Child Communication in Children with ASD: A Randomized Clinical Trial. Journal of Autism and Developmental Disorders. 2013;43(3):540-55. [pmid: 22825926].
148 Lawton K, Kasari C. Teacher-implemented joint attention intervention: pilot randomized controlled study for preschoolers with autism. J Consult Clin Psychol. Aug. 2012;80(4):687-93. [pmid: 22582764].
149 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. Jun. 2006;47(6):611-20. [pmid: 16712638].
150 Kasari C, Gulsrud A, Freeman S, et al. Longitudinal followup of children with autism receiving targeted interventions on joint attention and play. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):487-95. [pmid: 22525955].
151 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. Feb. 2008;76(1):125-37. [pmid: 18229990].
152 Lawton K, Kasari C. Brief Report: Longitudinal Improvements in the Quality of Joint Attention in Preschool Children with Autism. Journal of Autism and Developmental Disorders. 2012;42(2):307-12. [pmid: 22187107].
153 Schertz HH, Odom SL, Baggett KM, et al. Effects of Joint Attention Mediated Learning for Toddlers with Autism Spectrum Disorders: An Initial Randomized Controlled Study. Early Childhood Research Quarterly. 2013. 2013;28(2):249-58.
154 Kasari C, Gulsrud AC, Wong C, et al. Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1045-56. [pmid: 20145986].
155 Goods KS, Ishijima E, Chang Y-C, et al. Preschool Based JASPER Intervention in Minimally Verbal Children with Autism: Pilot RCT. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1050-6. [pmid: 22965298].
156 Ingersoll B. Brief report: Pilot randomized controlled trial of reciprocal imitation training for teaching elicited and spontaneous imitation to children with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1154-60. [pmid: 20155309].
157 Ingersoll B. Brief report: effect of a focused imitation intervention on social functioning in children with autism. J Autism Dev Disord. Aug. 2012;42(8):1768-73. [pmid: 22146934].
158 Pinto-Martin JA, Levy SE, Feldman JF, et al. Prevalence of autism spectrum disorder in adolescents born weighing <2000 grams. Pediatrics. Nov. 2011;128(5):883-91. [pmid: 22007018].
159 Stephens BE, Bann CM, Watson VE, et al. Screening for autism spectrum disorders in extremely preterm infants. J Dev Behav Pediatr. Sep. 2012;33(7):535-41. [pmid: 22926660].
160 Limperopoulos C, Bassan H, Sullivan NR, et al. Positive screening for autism in ex-preterm infants: prevalence and risk factors. Pediatrics. Apr. 2008;121(4):758-65. [pmid: 18381541].
161 Kuban KC, O'Shea TM, Allred EN, et al. Positive screening on the Modified Checklist for Autism in Toddlers (M-CHAT) in extremely low gestational age newborns. J Pediatr. Apr. 2009;154(4):535-40 e1. [pmid: 19185317].
162 Guevara JP, Gerdes M, Localio R, et al. Effectiveness of developmental screening in an urban setting. Pediatrics. Jan. 2013;131(1):30-7. [pmid: 23248223].
163 Anderson DK, Liang JW, Lord C. Predicting young adult outcome among more and less cognitively able individuals with autism spectrum disorders. J Child Psychol Psychiatry. 2013. Dec. 9. [pmid: 24313878].
164 Dawson G. Early behavioral intervention, brain plasticity, and the prevention of autism spectrum disorder. Dev Psychopathol. Summer. 2008;20(3):775-803. [pmid: 18606031].
165 Poon KK, Watson LR, Baranek GT, et al. To what extent do joint attention, imitation, and object play behaviors in infancy predict later communication and intellectual functioning in ASD?. J Autism Dev Disord. Jun. 2012;42(6):1064-74. [pmid: 21858585].
166 Koegel LK, Koegel RL, Carter CM. Pivotal responses and the natural language teaching paradigm. Semin Speech Lang. 1998;19(4):355-71. quiz 72; 424. [pmid: 9857392].
167 Reichow B, Barton EE, Boyd BA, et al. Early intensive behavioral intervention (EIBI) for young children with autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2012;10. CD009260. [pmid: 23076956].
168 Peters-Scheffer N, Didden R, Korzilius H, et al. A Meta-Analytic Study on the Effectiveness of Comprehensive ABA-Based Early Intervention Programs for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(1):60-9.
169 Virues-Ortega J. Applied behavior analytic intervention for autism in early childhood: meta-analysis, meta-regression and dose-response meta-analysis of multiple outcomes. Clin Psychol Rev. Jun. 2010;30(4):387-99. [pmid: 20223569].
170 Reichow B. Overview of Meta-Analyses on Early Intensive Behavioral Intervention for Young Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(4):512-20. [pmid: 21404083].
171 Kuppens S, Onghena P. Sequential Meta-Analysis to Determine the Sufficiency of Cumulative Knowledge: The Case of Early Intensive Behavioral Intervention for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2012;6(1):168-76.
172 South Carolina Department of Disabilities and Special Needs. South Carolina Department of Disabilities and Special Needs. Available at: http://ddsn.sc.gov/Pages/default.aspx.
173 Zwaigenbaum L. Assessment and diagnosis of autism spectrum disorders. BMJ. 2011;343:d6628. [pmid: 22021469].
174 Warren Z, Stone W, Humberd Q. A training model for the diagnosis of autism in community pediatric practice. J Dev Behav Pediatr. Oct. 2009;30(5):442-6. [pmid: 19823138].
175 Autism Speaks A. Autism Speaks: State initiatives. Available at: http://www.autismspeaks.org/advocacy/states.
176 Luyster R, Gotham K, Guthrie W, et al. The Autism Diagnostic Observation Schedule-toddler module: a new module of a standardized diagnostic measure for autism spectrum disorders. J Autism Dev Disord. Sep. 2009;39(9):1305-20. [pmid: 19415479].
177 Guthrie W, Swineford LB, Nottke C, et al. Early diagnosis of autism spectrum disorder: stability and change in clinical diagnosis and symptom presentation. J Child Psychol Psychiatry. May. 2013;54(5):582-90. [pmid: 23078094].
178 Charman T, Taylor E, Drew A, et al. Outcome at 7 years of children diagnosed with autism at age 2: predictive validity of assessments conducted at 2 and 3 years of age and pattern of symptom change over time. J Child Psychol Psychiatry. May. 2005;46(5):500-13. [pmid: 15845130].
179 Risi S, Lord C, Gotham K, et al. Combining Information from Multiple Sources in the Diagnosis of Autism Spectrum Disorders. Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45(9):1094-103. [pmid: 16926617].
180 Stone WL, Lee EB, Ashford L, et al. Can autism be diagnosed accurately in children under 3 years?. J Child Psychol Psychiatry. Feb. 1999;40(2):219-26. [pmid: 10188704].
181 Landa R, Garrett-Mayer E. Development in Infants with Autism Spectrum Disorders: A Prospective Study. Journal of Child Psychology and Psychiatry. 2006;47(6):629-38. [pmid: 16712640].
182 Chawarska K, Klin A, Paul R, et al. Autism spectrum disorder in the second year: stability and change in syndrome expression. J Child Psychol Psychiatry. Feb. 2007;48(2):128-38. [pmid: 17300551].
183 Corsello CM, Akshoomoff N, Stahmer AC. Diagnosis of autism spectrum disorders in 2-year-olds: a study of community practice. J Child Psychol Psychiatry. Feb. 2013;54(2):178-85. [pmid: 22905987].
184 Fein D, Barton M, Eigsti IM, et al. Optimal outcome in individuals with a history of autism. J Child Psychol Psychiatry. Feb. 2013;54(2):195-205. [pmid: 23320807].
185 Lovaas OI. Behavioral treatment and normal educational and intellectual functioning in young autistic children. J Consult Clin Psychol. Feb. 1987;55(1):3-9. [pmid: 3571656].
186 Rutter M. Autistic children: infancy to adulthood. Semin Psychiatry. Nov. 1970;2(4):435-50. [pmid: 5527410].
187 Orinstein AJ, Helt M, Troyb E, et al. Intervention for optimal outcome in children and adolescents with a history of autism. J Dev Behav Pediatr. May. 2014;35(4):247-56. [pmid: 24799263].
188 Magiati I, Tay XW, Howlin P. Cognitive, language, social and behavioural outcomes in adults with autism spectrum disorders: a systematic review of longitudinal followup studies in adulthood. Clin Psychol Rev. Feb. 2014;34(1):73-86. [pmid: 24424351].
189 Howlin P, Moss P, Savage S, et al. Outcomes in Adult Life Among Siblings of Individuals with Autism. J Autism Dev Disord. 2014. Sep. 5. [pmid: 25189825].
190 Shattuck PT, Durkin M, Maenner M, et al. Timing of identification among children with an autism spectrum disorder: findings from a population-based surveillance study. J Am Acad Child Adolesc Psychiatry. May. 2009;48(5):474-83. [pmid: 19318992].
191 Goin-Kochel RP, Mackintosh VH, Myers BJ. How many doctors does it take to make an autism spectrum diagnosis?. Autism. Sep. 2006;10(5):439-51. [pmid: 16940311].
192 Fountain C, King MD, Bearman PS. Age of diagnosis for autism: individual and community factors across 10 birth cohorts. J Epidemiol Community Health. Jun. 2011;65(6):503-10. [pmid: 20974836].
193 Mandell DS, Ittenbach RF, Levy SE, et al. Disparities in diagnoses received prior to a diagnosis of autism spectrum disorder. J Autism Dev Disord. Oct. 2007;37(9):1795-802. [pmid: 17160456].
194 Mandell DS, Wiggins LD, Carpenter LA, et al. Racial/ethnic disparities in the identification of children with autism spectrum disorders. Am J Public Health. Mar. 2009;99(3):493-8. [pmid: 19106426].