# Peer Reviewers

- Maggie Brewinski Isaacs, MD, MPH, FAAP
  Office of Research on Women's Health
  U.S. National Institutes of Health
- Thomas D. Challman, MD, FAAP
  Geisinger Medical Center
- Tony Charman, PhD
  King's College London, Institute of Psychiatry
- Major Amy Costello, MD
  U.S. Department of Defense
- Alice Kau, PhD
  National Institute of Child Health and Human Development
  U.S. National Institutes of Health
- Michelle M. Macias, MD
  Medical University of South Carolina
- Diana Robins, PhD
  Georgia State University