# [Preface]

This systematic review was conducted to support the U.S. Preventive Services Task Force (USPSTF) in making new clinical preventive recommendations for screening for autism spectrum disorder in young children. The original literature searches were completed in August 2014.

There were three studies suggested for potential inclusion during the public comment period for the draft report that were not considered by the review team due to publication after the end of the search period. This systematic review has NOT been updated to consider inclusion of these studies. These studies may be important additions to this growing body of evidence but do not change the overall results or conclusions of this review. They should be considered for inclusion in any updates of this report.

## References

1 Estes A, Munson J, Rogers SJ, et al. Long-term outcomes of early intervention in 6-year old children with ASD. J Am Acad Child Adolesc Psychiatry. 2015;54(7):580-7. [pmid: 26088663].
2 Wetherby AM, Guthrie W, Woods J, et al. Parent-implemented social intervention for toddlers with autism: an RCT. Pediatrics. 2014;134(6):1084-93. [pmid: 25367544].
3 Baranek GT, Watson LR, Turner-Brown L, et al. Preliminary efficacy of adapted responsive teaching for infants at risk of autism spectrum disorder in a community sample. Autism Res Treat. 2015;2015:386951. [pmid: 25648749].