# Discussion

## Summary of Evidence

This systematic review assessed the evidence for screening and treatment of ASD applicable to primary care settings. We explicitly focused on studies examining screening strategies for young (<36 months of age), unselected populations (i.e., universal screening). We identified 17 unique screening studies in primary care populations consisting of approximately 13,884 participants who had not yet been identified as having a developmental concern. These studies are reported in 22 papers.39, 58, 59, 61-67, 69-79, 101 Although several ASD screening tools have been evaluated, only a small set of related tools have been adequately studied to provide data on young, unselected children (Tables 2 and 3). Most studies have evaluated versions of the same tool, the M-CHAT/F and M-CHAT-R/F. These screening approaches have been studied in more than 45,000 children, of which 76 percent (n=35,900/47,472) were in the United States and another 24 percent (n=11,572/47,472) used translated versions in Japan, Spain, and Sweden. Other screeners have either already been demonstrated to provide unsatisfactory results or are not typically used in the United States, so the discussion below focuses on M-CHAT/F and M-CHAT-R/F, which is the most likely screener to be used in the target population. The most current version is the M-CHAT-R/F.

### Findings for Well-Studied ASD Screening Instruments

#### M-CHAT-R and M-CHAT-R/F

The M-CHAT-R and M-CHAT-R/F have been studied in more than 30,000 low-risk toddlers in heterogeneous community-based primary care settings. PPV ranges from 48 to 54 percent to accurately identify children with ASD between 16 and 30 months of age. In both versions of the screening approach, the proportion identified is lower than the recognized population prevalence, as calculated by the CDC. However, in one study that specifically assessed it, most children who screened positive had not yet been identified as being at risk of ASD by either their parent(s) or pediatrician. Specifically, as a result of screening, 60 percent of identified cases of ASD were found before parents expressed concern, 50 percent were identified before pediatrician concern, and in only 20 percent of cases were both the parent and pediatrician concerned before the screener identified a problem. These percentages are not mutually exclusive.

Both studies use a low-risk population, excluding children already identified with developmental delay. It is unclear how the instrument operates in mixed populations that include children at increased risk for ASD. The study authors report that almost all children (cumulative 98%, including the ASD diagnoses) were identified to have “actionable” concerns but they do not provide detailed data other than general categories of diagnoses (e.g., language delay).

Of the two revised versions, the M-CHAT-R/F was most recently studied. It was developed to address potential concerns about over-identification and misuse of the tool, specifically an over-reliance on the questionnaire without the followup to validate results. Therefore, while the M-CHAT-R required a separate followup, the M-CHAT-R/F packages the initial assessment and followup together as one two-step process.

None of the studies followed either the complete sample of screen-negative children or a truly random sample in order to assess missed cases. Although true population estimates of how many children with ASD may screen negative on the M-CHAT or M-CHAT-R/F procedure are unavailable, comparing the proportions of children identified through the screeners to population estimates suggest this does occur. Given the prevalence rate of 1 in 68, as well as the resource-intensive nature of conducting the gold standard evaluations (i.e., in-person, time-intensive diagnostic assessments by skilled behavioral professionals, sometimes lasting a full day or more) in screen-negative children, almost no study has followed a large enough sample to truly assess false negatives on a population level.

The largest and most recent study followed up a quasirandom sample of 375 children who screened negative, of whom only six were eventually diagnosed with ASD (1.6%). An additional 42 out of 64 children who screened negative but were subsequently flagged by their pediatrician for further examination were also diagnosed with ASD, for a total of 11 percent (48/439) identified as false negatives. The false negative rate for those who were identified as screen negative by the screening methodology and by physician observation was very low (1.6%). Although the methodology is imperfect, it does offer reassurance that the screening tools are unlikely to miss large numbers of children.

One additional approach to understanding potential under-identification, which has significant inherent methodological limits, comes from examining ASD identification rates relative to current prevalence estimates. The best study of the M-CHAT identified 1 in 208 children who participated in the initial screen while the M-CHAT-R/F identified 1 in 153. These numbers appear modest in comparison to the current prevalence rate reported by the CDC of 1 in 68; however, it is important to note that screening studies have been conducted within research programs, rather than standard clinical care. This means that families must opt in, and resources are expended to track, assess, and confirm concerns about ASD. Prevalence estimates applying simple corrections for attrition from these same studies range from 1 in 98 to 1 in 109, numbers that are closer to the current estimated prevalence rate (Table 4).

Given the pervasive and ongoing nature of developmental disorders, however, false negatives are primarily a concern among borderline cases, such as those that fail one portion of the screening process. Rather than follow up with all screen negatives, some studies followed up with borderline cases that failed a portion of the screening process (e.g. failed the screener but not the interview).

#### Other Tools

There are preliminary data suggesting that screening at very young ages (e.g., 12 months) with the FYI might identify some children with social communication concerns. However, data have not yet been available to calculate estimates of psychometric properties of this instrument in low-risk populations. The ITC is designed as a general developmental screener for communication development that has also been used to screen for ASD. The ITC identifies many children with actionable developmental concerns, but using it in isolation may label 10 percent or more of the total low-risk population as at risk for ASD or other communication disorders. Identification of children via ITC screening may occur before parents and clinicians raise concerns.39, 63, 76 Preliminary evidence suggests that children with ASD screened with the ITC may be referred for and receive higher levels of service than children with other developmental concerns.

There are some emerging data from non-U.S.-based programs and adaptations (ESAT, FYI-Lite, SACS, YACHT) regarding the potential for combined screening/surveillance and prospective strategies involving community health visitation and trained providers (e.g., visiting home nurses, behavioral health screening) to identify ASD at early ages. However, these tools have not yet been studied in U.S.-equivalent primary care settings and practices.

### Screening in Special Populations

We did not identify any studies in primary care screening populations that specifically assessed the effect of individual risk factors such as prematurity or sibling status on performance characteristics of ASD screening tests. Our a priori review approach also precluded inclusion of screening studies in preselected populations, such as siblings of individuals with ASD. Later-born siblings of children with ASD are estimated to see an incidence rate between 7 and 19 percent. Screening siblings may be particularly challenging using measures that rely on parent report because these families evaluate their second child's behavior and development through a different lens. Further, these subgroups may have very complex profiles of developmental skills.

Within the neonatal intensive care unit graduate population, where ASD is estimated to occur 5 to 8 times more often than in the general population,158 it is difficult to discriminate children at risk of ASD from children at risk of other neurodevelopmental conditions. Several studies conducted to date have reported positive ASD screening rates of 10 to 25 percent when the M-CHAT is used in toddlers who were low birth weight babies.159, 160, 161

### Screening by Age

No studies focusing exclusively on primary care screening systematically examined the performance characteristics of early screening tools for children at different ages within our time frame (0 to 36 months) .

One study,70 representing a subsample of high- and low-risk children overlapping with populations reported in other studies in this review,101 attempted to examine screening characteristics of the M-CHAT at different ages. PPV was higher for children older than 24 months. However, many children were excluded from this sample as they had already received an ASD diagnosis. As such, the sample may not reflect true population estimates of PPV by age in pediatric settings.

Indirect evidence suggests that studies in which the target age was entirely or primarily below 16 months (ESAT, ITC, FYI) report both under-identification (low sensitivity and PPV) and over-identification (low specificity). Some instruments (e.g., M-CHAT) have not yet been thoroughly studied in very young populations, so performance characteristics are unavailable. Some instruments also recommend different cutoffs based on age (e.g., ITC), whereas some screeners rely on the same algorithm to determine risk across a wide span of development. In both cases there may be differences in performance characteristics that vary by age, but data are not yet available to assess these differences.

### Outcomes of Screening

Children who were screened have had earlier ages of concern, referral, and diagnosis compared to 1) parent and clinician ratings and 2) population estimates of age of diagnosis.39 Only one study to date has examined age of identification and service entry with an RCT of developmental screening in comparison to surveillance,162 but this study did not provide performance characteristics for an ASD diagnosis specifically, so was excluded from our analysis. It did, however, use the M-CHAT in addition to general developmental screening, with screening associated with earlier age of identification with developmental delay, earlier referral for service, and increased service access through early intervention systems. Children in the screening group had a 59 to 68 percent shorter time to identification of their particular diagnosis, and a 64 to 70 percent shorter time to referral for services. We did not find a corollary study for ASD alone.

In terms of access to services, children screened at risk and later diagnosed with ASD receive higher levels of service compared to children without such diagnosis. However, there have not been any systematic prospective studies that examine service access and the impact of service delivery for children screened at risk after they are diagnosed. Some information suggests that children screening positive for ASD are referred for and receive higher levels of early intervention service than children identified via clinical surveillance.39

### Outcomes of Treatment

#### Early Intensive Behavioral and Developmental Interventions

Evidence for the effects of early intensive behavioral intervention is primarily available for the outcomes of cognitive improvement and language (receptive and expressive), and the primary intervention is early intensive developmental and behavioral intervention. Twenty of the 30 studies of early intensive intervention assessed cognitive outcomes. Eleven of these 20 studies demonstrated significantly greater effects on cognitive outcomes among children in the treatment group compared to children who received eclectic community-based care (the comparator in 13/20 studies assessing cognitive outcomes) or other comparators. Among 15 of 17 studies of direct provision to children reporting cognitive outcomes, 10 studies demonstrated greater changes in cognitive outcomes in the treatment group relative to the comparison arm. Among five of 13 parent-focused studies reporting cognitive outcomes, one reported significantly improved outcomes in the treatment group compared to control.

For example, in the good-quality RCT of the ESDM, cognitive outcomes for children in the ESDM group improved by a mean of 17.6 points from baseline compared to a 7-point gain in the control group (p=0.044) after 2 years. Compared to children in preschools with teachers who received LEAP manuals and no specific instruction, children with teachers who received LEAP coaching and training gained significantly on cognitive measures (mean gain of 8.9 points vs. loss of 1.8 points on the Mullen Scales of Early Learning Early Learning Composite; p<0.01). In studies of the UCLA/Lovaas-based approach, children in the treatment group were significantly more likely to achieve cognitive scores in the average range at followup than the eclectic group (7/13 children vs. 2/12; p<0.05).

Because of the variability in test item content (e.g., nonverbal problem solving, verbal reasoning, motor skills) and scoring protocols (e.g., different cutoff points for basal and ceiling scores), it is difficult to directly translate numerical changes on a cognitive or language scale to specific developmental changes within an individual child. However, these overall scores, particularly on cognitive scales, can make a difference regarding a child's educational or diagnostic classification, particularly with regard to a co-occurring diagnosis, such as an Intellectual Disability. A boost of a few points in a cognitive score can make the difference between a Mild Intellectual Disability versus Borderline Intellectual Functioning versus a score in the Average range. The subsequent impact of these classifications on environmental or intervention factors, such as classroom placement, could offer children additional opportunities over time that, again, are difficult to quantify but are nevertheless important.

Another possibility is that shifts in cognitive scores partly reflect a child's increased ability to attend to an adult, understand spoken instructions, sit at a table, and respond in the correct way to a spoken question—all important skills that can help children participate in, and learn from, structured and unstructured social situations. Many young children with ASD have difficulty following the format of a standardized assessment in ways that reflect their underlying social-communication and play vulnerabilities. For example, instead of following the examiner's instruction to match objects, they may put the objects in a line, spin them in their peripheral vision, or not engage with the objects at all, instead exploring other sensory properties of the room. Increased cognitive scores, therefore, likely indicate to some degree a child's increased ability to attend to social interactions, one of the key deficits in ASD.

Given that these tests reference skills and mark change in relation to normative samples of typically developing children, substantial variation in the population of interest can often appear more moderated (i.e., children gaining 2 years in developmental age and children gaining only a month in developmental age) and/or profound effects of developmental floors of instruments. Nevertheless, they do reference change regarding normative development. As such, changes relative to standard scores indicate not just developmental progression, but progression outpacing what would be expected during typical developmental progress (i.e., more than a year of developmental progress within a chronological year). In this regard, there can be potential value in describing the normative skill gains in corresponding to developmental age equivalents in order to better understand the clinical functional impact, or lack thereof, in interventions.

Twenty-eight of 30 studies assessed language outcomes. In 13 of these 28 studies, outcomes were significantly improved in the treatment versus the comparison arms. In 19 of these 28 studies, the comparator was eclectic treatment, and outcomes were significantly improved in the treatment versus comparison group in 10 of these 19 studies.

Data on language outcomes was more mixed. ESDM was associated with statistically significant increases in language acquisition relative to community eclectic treatment. Two studies of LEAP assessed language outcomes with mixed results (improved outcomes in the full LEAP training arm compared to control in one study and no significant differences among groups in another). Among the studies of UCLA/Lovaas-based approaches, two studies demonstrated significantly greater improvements on the VABS Communication domain with treatment versus eclectic controls; results were mixed (one study positive and one neutral) when outcomes were measured on the Reynell Developmental Language Scale, and one study reported that UCLA/Lovaas-based treatment was associated with improvements in receptive but not expressive language, again when compared to eclectic comparators.

#### Clinical Implications of Changes in Cognitive and Language Measures

In order to benchmark scores, we provide descriptions of the age equivalent and corresponding item sets and abilities from the Mullen Scales of Early Learning in the Dawson (2010) study of ESDM and eclectic, community-based intervention. As the study was an RCT of two active treatments (e.g., manualized intensive developmental/behavioral intervention vs. eclectic community treatment), we can present a description of the indexed change for both samples.

##### Cognitive Outcomes

In the ESDM group at baseline, children at an average of age of 23.9 months had an Early Learning Composite score (SS mean, 100 ± 15) of 59.4 (1st percentile). This corresponded to domain scores (T score mean, 50 ± 10) of 21.1 (1st percentile) for language understanding (Receptive Language); 24.5 (1st percentile) for language use (Expressive Language); 33.2 (4th percentile) for nonverbal problem solving (Visual Reception); and 33.9 (4th percentile) for fine motor skills (Fine Motor).

Such baseline performance corresponds to receptive and expressive language skills equivalent to a 13-month-old. Children in this span of functioning are likely to be able to voluntarily babble, potentially produce a very small number of single words (<8), but not yet successfully label objects, pictures, or use phrases. In terms of language understanding, children at this level would be likely to understand simple contextualized instructions (e.g., no, let's go); however, they would not be able to follow simplistic novel directions (e.g., show me your nose/eyes, point to the cat). Nonverbal skills would correspond to 17-month-old developmental level (Visual Reception) with Fine Motor skills at an 18-month-old level. Children at this level of functioning would be able to explore objects with their hands, demonstrate object permanence, take small objects in and out of containers, and potentially place small inset puzzle shapes (e.g., circle, square inset). Children at this developmental level would have challenges stacking and building blocks in imitation of a town or train, stringing beads, as well as sorting or matching simple shapes.

At 52.4 months, the ESDM group had an average Early Learning Composite score (SS mean, 100 ± 15) of 78.6 (7th to 8th percentile). This corresponded to domain scores (T score mean, 50 [SD, 10]) of 40.1 (16th percentile) for language understanding (Receptive Language); 38.6 (12th percentile) for language use (Expressive Language); 41 (18th percentile) for nonverbal problem solving (Visual Reception); and 33.5 (4th percentile) for fine motor skills (Fine Motor). Children in the other treatment arm (community treatment) did not exhibit statistically significant differences on their cognitive profile.

The increase in skills seen in the ESDM group represents 30 to 31 months of progress in language skills, 29 months in nonverbal skills, and 24 months in fine motor skills. Children with developmental language skills on this level are commonly able to use three-word sentences, repeat number sequences, count, answer simple questions, follow novel two-step unrelated commands, and identify colors, shapes, and sizes.

In the community treatment group at outcome, children had new developmental age equivalents of approximately 37 months for Receptive Language; 36 months for Expressive Language; 41 months for Visual Reception; and 40 months for Fine Motor. This represents 24 to 25 months of progress in language skills, 25 months in nonverbal skills, and 23 months in fine motor skills.

Simply charting the corresponding age equivalents to the 17.6-point differential at outcome in the treatment arm (i.e., comparing age equivalents of baseline and outcome cognitive scores), this amounts to approximately 5 to 8 months of increased developmental acceleration during a 2- year span. It is important to note that this change is in addition to typical developmental progress of a normative sample, leaving open the possibility that this change may far exceed the developmental progress of untreated ASD groups who may actually progress at a much slower rate in terms of cognitive skills. Thus, both groups made progress, but the active treatment group (ESDM) made significantly greater gains, as described above.

These are average effects, and the range of effects is wide. Not all children experience such positive outcomes. Nonetheless, studies of long-term outcomes for individuals with ASD up to 19 years of age point to early cognitive scores as a primary predictor of success, including maximizing independence, so research continues to focus on early interventions that can move the bar on cognitive scores. New research suggests that not only cognitive scores themselves, but shifts in cognitive scores at the earliest ages, is associated with positive outcomes as well.163

As another example, a 25-point gain in cognitive scores from a baseline of 69 (which is within the range of Mild Intellectual Disability) would yield an IQ score of 94, within the Average range. This reflects an improvement of almost 2 standard deviations within most standardized cognitive instruments, shifting a child's score to a significantly higher percentile rank relative to other children who take that test. This score increase may reflect improved verbal and nonverbal reasoning skills (e.g., defining words or relationships between words), visual processing skills (e.g., matching pictures, replicating block designs), working memory (e.g., remember chains of letters and numbers), or processing speed (e.g., identifying a certain number of targets within a given time period), to name a few of the many areas that cognitive tests assess. It may also reflect an improved ability to respond to standardized items and questions, with the potential for broader understanding of social rules and ability to learn and implement adaptive behavior tasks. For example, a child with the ability to point to pictures as part of a cognitive test may also be able to point to pictures as part of a communication system. A child who can sort objects may respond to structured work systems to promote his or her independence across environments. A child who can verbally define a word also understands the meaning of that question which, in turn, could translate into understanding adult instructions and verbalizing thoughts and needs. All of these skills in turn promote participation in classrooms, therapy sessions, and, in the long term, employment settings. Although there is certainly not a one-to-one correspondence between cognitive scores and these types of clinical outcomes, increases in scores may reflect increased ability to understand, implement, and generalize these skills.

##### Language Outcomes

Regarding language measures, increases in scores may translate more directly to everyday applications. Increases in expressive language (ability to use words and phrases; may also include gestures) and receptive language (ability to understand words, such as follow instructions, find named objects) can have concrete meaning for families, even if the increases are small. For example, a child without any words who does not point may scream or use a parent's hand as a tool to request help. If that same child is able to point to a picture of what he wants, or use a handful of single words (e.g., juice, Mama), it can reduce the child's frustration, thereby promoting social engagement. The acquisition of verbal skills may also have a strong psychological impact on parents, many of whom identify a speech delay as their first concern about their child's development. Similarly to IQ, language skills also have impacts on children's classroom placements and functioning, including the kinds of communicative supports necessary for them to participate (e.g., Alternative and Augmentative Communication Devices, PECS) and understand what is going on, including daily schedules, classroom rules, and social interactions with peers.

#### Play-Based Studies

Studies incorporating play or interaction-based elements typically targeted joint attention skills and included younger children (21 to 82 months). Joint attention skills are thought to be pivotal skills central to the etiology and neurodevelopmental sequelae of ASD.164, 165 Pivotal skills, or social communication building blocks, are intended to enable children to learn from their natural social environment so that development continues as a result of having acquired the skill, even in the absence of continued treatment.166 At a basic level, “joint attention” refers to specific skills that involve sharing attention, particularly visual attention, with others (e.g., pointing, showing objects, coordinating gaze, and responding to such bids). These exchanges enable young children to socially coordinate their attention with other people to more effectively learn from their environments. Fundamental differences in early joint attention skills, which emerge and develop within and across infancy, have been linked to the deleterious neurodevelopmental cascade of ASD, and successful treatment of these deficits could substantially improve other skills across settings and the lifespan.151, 154, 165

Participants in play/interaction studies often received other early intervention services in addition to the targeted intervention, making disentangling effects of the intervention difficult, but studies reported positive effects for preschool children with ASD, particularly when targeting joint attention skills themselves as well as related social communication and language skills. Data are more limited about the ability of play-based studies to improve broad developmental skills (such as cognition, adaptive behavior, and ASD symptom severity) beyond communication and language gains over time. In one study, training regarding imitation skills showed positive results in improving not only imitation skills, but potentially other social communication skills such as joint attention as well. Studies focuses on changing parental responses to child behavior and communication reported limited effects on language.

### Moderators of Outcomes

Existing studies do not predict which children are most likely to benefit, although effects have a wide range, with some children exhibiting substantial improvement and others not at all. One of the challenges in this literature base is that many studies do not adequately characterize the participants, nor do they provide subgroup analyses that might be helpful in describing which children benefit most. However, higher baseline cognitive scores were associated with less improvement in some interventions. Since interventions are often targeted to individual baseline deficits, global measures may not capture individual effects. Even children who demonstrate clinically significant improvement in response to intervention often continue to display substantial impairment across some areas of functioning.

Indirect evidence suggests that earlier intervention may result in better outcomes. In ABA-based and parent training studies, younger age at enrollment emerged as a predictor of improvement in cognitive skills and language comprehension and production.126, 129, 138 In early intervention studies, younger age was associated with greater improvements; greater language gains were seen in children who were younger with lower functioning levels at baseline in one RCT of an approach incorporating parent training.138 Another study assessing parent-delivered ESDM reported greater increases in developmental quotient scores in children under 24 months of age in analyses combining the ESDM group with the control group, which received community-based treatment (effect size, -1.20; p=0.002).129

In a retrospective cohort study of a community-based early intervention program, outcomes were related to age at enrollment, treatment duration, and higher baseline adaptive scores. A significant interaction emerged between age at enrollment and group membership, with younger starting age influencing outcomes for the treatment group but not the waitlist control.109 However, these findings are not entirely consistent, and one study comparing preschool-delivered intensive early intervention and treatment as usual reported larger adaptive behavior gains for older children in the early intervention group.107 Such differences may be related to subgroups of participants who respond differentially to treatment due to factors that are not fully understood or to developmental issues limiting specific interventions, such as lesser ability to develop adaptive behaviors before a certain age; further, age at diagnosis may also be associated with severity, which could also confound response to treatment.

### Challenges in the Evidence Base

A remaining significant challenge to interpreting the early intensive intervention literature relates to how interventions are described and implemented. Although researchers are increasingly attempting to manualize (develop standardized treatment manuals) approaches as well as operationalize and measure treatment fidelity, most of the body of literature categorized in this report as “early intensive behavioral and developmental intervention” remains an eclectic grouping. This category of interpretation presently groups different treatment approaches (i.e., developmental, intensive behavioral, center based, and combinations), intensity (12 hours over 3 months vs. 30 hours over 1 week), and duration (weeks to years); varied inclusion and baseline assessment criteria; children of varying ages (intake age ranging from 18 months to 7 years); and many different outcome measurements over different periods of time (weeks to years). There are potent intrinsic challenges to manualizing intensive interventions to be delivered over months and years for a heterogeneous patient population. However, recent progress toward this end has shown that children will often respond differentially to early intensive approaches.

Few studies directly compared the effects of well-controlled treatment approaches, instead comparing interventions to nonspecific “treatment as usual.” Additionally, little data on the practical effectiveness or feasibility of these treatments beyond research studies exist, and questions remain about whether reported findings would generalize on a larger scale within communities. Similarly, no studies in this category reported harms of intervention in terms of child, family, or system impact.

### Findings in Context of Other Recent Reviews of Behavioral Interventions

We rated three meta-analyses evaluating early intervention for children with ASD as good quality;167-169 we also summarize two overview meta-analyses (not quality rated) addressing early intervention.170, 171 Of the 30 early intensive behavioral and developmental studies described in our review, four117-119, 122, 123 were included in three of the prior reviews167-169, 171 summarized here, and two19, 111 were included in four167-169, 171 of the reviews. One additional study107 was included in one prior review.169 Although none of the prior reviews used exactly the same set of studies, and most used many fewer studies than ours, these reviews were in general agreement with our assessment of the literature, finding significant positive effects of early intervention on cognitive and language outcomes, and also noting that the quality of the literature was not optimal and should be improved in future research.

One Cochrane review compared early intervention to treatment as usual and included RCTs or controlled trials with participants under 6 years of age at intake.167 The review included five studies (one RCT) with a total of 203 participants (mean age range, 30.2 to 42.5 months). The investigators rated all studies as having high risk of bias (low overall quality) and found positive effects for early intervention on all outcomes. Mean difference effect sizes were 0.76 for cognitive scores (95% CI, 0.40 to 1.11; p<0.0001), 0.69 for adaptive behavior (95% CI, 0.38 to 1.01; p<0.0001), and ranged from 0.42 to 0.74 for measures of communication, socialization, and daily living skills (p-values, 0.0005 to 0.03). Tests of heterogeneity and small sample sizes precluded assessment of moderators of effects.

One meta-analysis of ABA-based interventions included studies with at least five children with ASD receiving at least 10 hours of intervention per week for 45 weeks.169 Twenty-two studies met criteria and assessed outcomes including IQ, receptive and expressive language, and adaptive behavior (VABS composite and domain scores). Studies included 323 patients (mean age, 22.6 to 66.3 months; 55.6% to 97% male). Study quality was low to moderate, ranging from 1.2 to 3.6 on a 5-point scale (mean, 2.5). Thirteen studies had control groups (six with random/quasirandom assignment). Positive effects were associated with ABA-based intervention in 18 studies assessing the outcome with a pooled effect size of 1.19 (95% CI, 0.91 to 1.47; p<0.001). Similarly, ABA was associated with positive effects on language (general, expressive, and receptive; effect sizes ranging from 1.07 to 1.48) and adaptive behavior (communication, socialization, motor skills, and daily living skills domains as well as composite scores; pooled effect sizes ranging from 0.61 to 1.45). The effect size for the composite score was 1.09 (95% CI, 0.70 to 1.47; p<0.001), and total treatment duration was associated with better adaptive behavior and language outcomes but not IQ. Results restricted to studies with control groups were consistent with results for all studies across outcomes. Across outcomes, effect sizes were generally slightly better for clinic-based versus parent-delivered approaches. The investigators note the potential for publication bias for the cognitive and language outcomes and the adaptive behavior domains of communication and socialization.

Another meta-analysis of ABA-based early intervention included 11 small comparative studies (one RCT) with 344 children with ASD (mean age, 33.56 to 65.68 months; 65.7% male).168 The mean quality of studies as rated on the Downs and Black scale was 24.65 out of 32 (range, 23 to 27). The early intervention group had greater gains on all variables assessed compared to control group participants, with full scale IQ improving by 11.98 points over improvements in the control group. Receptive and expressive language scores for the early intervention group compared to control improved by more than 13 points, while improvements on VABS domain scores ranged from 4.96 to 10.44 points. Total effect sizes for daily living skills improvements were moderate (0.68) and were large for improvements in IQ, language, and adaptive behavior (effect sizes ranging from 0.91 to 2.00). The authors noted some evidence of publication bias. Table 15 outlines key characteristics of these early intervention meta-analyses.

Table 15 Summary of Meta-Analyses of Early Intervention Approaches

Author, year | Study type as defined in review (n) Total participants/group (n) | Mean participant age (months) | Treatment intensity, hours/week Treatment duration, mean months (range) | Effect sizes (95% CI)
Reichow 2012^167^ | RCT: 1 Controlled trial: 4 Early intervention: 116 Comparison: 87 | 30.2-42.5 | >24 hours/week 26.3 months (14-36) | IQ: 0.76 (0.40 to 1.11) Expressive language: 0.50 (0.05 to 0.95) Receptive language: 0.57 (0.20 to 0.94) Vineland adaptive behavior: 0.69 (0.38 to 1.01) Vineland communication: 0.74 (0.30 to 1.18) Vineland socialization: 0.42 (0.11 to 0.73) Vineland daily living: 0.55 (0.24 to 0.87)
Virues-Ortega 2010^169^ | Total studies (type not defined): 22 Early intervention: 323 Comparison: 180 | 22.6-66.3 | 12-45 hours/week 4-34 months | IQ: 1.19 (0.91 to 1.47) Expressive language: 1.47 (0.85 to 2.08) Receptive language: 1.48 (0.96 to 1.97) General language: 1.07 (0.34 to 1.79) Vineland adaptive behavior: 1.09 (0.70 to 1.47) Vineland socialization: 0.95 (0.53 to 1.37) Vineland communication: 1.45 (1.02 to 1.88) Vineland daily living: 0.62 (0.30 to 0.93) Vineland motor skills: 0.71 (0.19 to 1.22)
Peters-Scheffer 2011^168^ | RCT: 1 Pre-test/post-test with control: 10 Early intervention: 168 Comparison: 144 | 33.65-65.68 | 12.5-38.6 hours/week 10-24+ months | IQ: 2.00 Non-verbal IQ: 0.98 Expressive language: 1.10 Receptive language: 2.91 Vineland adaptive behavior: 0.91 Vineland communication: 1.32 Vineland daily living: 0.68 Vineland socialization: 1.49

CI=confidence interval; IQ=intelligence quotient; RCT=randomized controlled trial.

Note: Of the 30 early intensive behavioral and developmental studies described in this current review, four117-119, 122, 123 were included in three of the prior reviews167-169, 171 summarized in this report, and two19, 111 were included in four167-169, 171 of the reviews. One additional study107 was included in one prior review.169

A sequential or cumulative meta-analysis compiled data from 15 studies rated as adequate or high quality in five previously published meta-analyses (Eldevik 2009, Makrygianni 2010, Peters-Scheffer 2011, Reichow 2009, Spreckley 2009).171 The 15 studies included 263 children with ASD. The sequential meta-analysis found a medium treatment benefit for early intervention versus comparison interventions for the outcomes of intellectual functioning, language, and adaptive behavior. The magnitude of treatment benefit varied for outcomes when assessing pre- to post-differences in the early intervention group. For IQ, the standardized mean difference effect size for group differences was 0.61 (p<0.001) and the pre- to post-differences in the early intervention group was 0.71 (p<0.01). Between-group effect sizes for adaptive behavior and language were also considered medium (0.60 and 0.72, respectively; p-values <0.001). Pre- to post-effect sizes for adaptive behavior (0.35; p=not significant) and language (0.69; p<0.05) did not reach sufficiency and could not be considered as providing evidence of medium pre- to post- treatment benefit. The authors note that meta-analyses for pre- to post-differences in adaptive behavior and language were underpowered.

An overview of four of the same meta-analyses noted above plus one additional (Virues-Ortega 2010) described methodological limitations across the meta-analyses.170 Limitations included small sample sizes in included studies, inclusion of nonrandomized studies, lack of standardized control groups, errors in interpretation of studies, and variations in the early intervention approaches assessed. Four of the five meta-analyses concluded that early intervention was an effective approach. For IQ, the weighted mean effect size across meta-analyses ranged from 0.38 to 1.19 and from 0.30 to 1.09 for adaptive behavior. Despite the need for additional research, particularly in understanding effective treatment components and child characteristics associated with optimal outcomes, the authors conclude that early intervention can produce significant effects on cognitive skills and adaptive behavior for many young children with ASD.

Table 16 summarizes studies identified and findings across KQs addressed in the review.

Table 16 Summary of Evidence

Key Question | Number Studies Overall quality | Limitations | Consistency | Applicability | Summary of Findings
1. Outcomes of screening | No studies identified | NA | NA | NA | - No studies directly link screening to health outcomes
2. Performance characteristics | 18^39, 58, 59, 61-79^ Overall quality: Fair | - Few studies followed participants who screened negative to identify false negatives; - All studies demonstrated significant loss to followup across multiple steps from screening to diagnosis | Consistent | - Fair generalizability; - Population-based screening (well-child visits); - Studies of M-CHAT conducted in US, Sweden, Spain, Japan, Australia | - PPV for ASD in the two large studies of the most common screening process (M-CHAT-R and M-CHAT- R/F) was around 50%; - Few children receiving diagnostic evaluations were typically developing as most had some non-ASD developmental disorder
2a. Risk factors that modify screening performance | No studies identified | NA | NA | NA | NA
2b. Age as modifier of screening performance | 1^70^ | - Screen negatives not systematically followed | NA | - Fair generalizability; - Population-based screening in US | - PPV was higher for children above 24 months. Sample excluded many children with ASD limiting the ability of this analysis to comment on true population estimates.
2c. Other characteristics that modify screening performance | No studies identified | NA | NA | NA | NA
3. Harms of screening | No studies identified | NA | NA | NA | NA
4. Interventions for young children with ASD | 42 studies assessing interventions aimed at younger children; 5 systematic reviews Overall quality: Fair | - Multiple outcome measures; - Effects of potential modifiers unclear; - Participants often received multiple interventions thus disentangling effects is difficult | Consistent | - Good generalizability; - Overall studies were conducted in populations and settings similar to U.S. health care context. Many interventions broadly accessible in the United States | - Children in early intensive behavioral and developmental intervention made gains in cognitive and language skills (significant gains for treatment over control groups in 11 of 20 studies assessing cognitive outcomes; 13 of 28 studies assessing language; and 9 of 10 studies addressing joint attention outcomes)
4a. Effects of intervention timing on treatment outcomes | 4^107, 109, 129, 138^ Overall quality: Fair | - Few studies had specific modifier analyses; - Outcome measures varied across studies | Consistent | - Good generalizability; - Overall studies were conducted in populations and settings similar to U.S. health care context. Many interventions broadly accessible in the United States | - Younger age at intervention was associated with greater gains. Examples include: all children in one study with IQ gains of at least 30 were under age 6, with a mean of 3.5; in another study, age was an independent predictor in multivariate analyses of shifts in IQ at p<.001; in a third, baseline age (younger toddlers) was associated with a significant shift in developmental quotient, and in a fourth, age positively correlated with changes in adaptive behavior on the ABC scale. Nonetheless, studies need to be replicated as different interventions and outcome scales were used, and some other studies found no difference by age, particularly those with tight age bands in the preschool age group.
4b. Effect of ASD severity on intervention outcomes | 3^105-107^ Overall quality: Fair | - Few studies had specific modifier analyses; - Outcome measures varied across studies | Consistent | - Good generalizability; - Overall studies were conducted in populations and settings similar to U.S. health care context. Many interventions broadly accessible in the United States | - Having a diagnosis on the ASD spectrum other than Autism was associated with greater gains (e.g. Asperger Syndrome or PDD-NOS). Other data are inconsistent on whether symptom severity is associated with outcome achievement.
5. Harms of intervention | No studies of interventions aimed at younger children^a^ | - No studies of behavioral interventions reported harms | NA | NA | NA

ASD=autism spectrum disorder.

a Studies of medical interventions—typically including older children—reported significant harms.

## Review of Contextual Issues

### Contextual Question 1 Are Screening Resources Currently Adequate to Support Routine Screening in Primary Care or Affiliated Care Systems?

Current estimates suggest that approximately 42 to 55 percent of pediatricians regularly screen for ASD in toddlers,2 but providers are much less likely to screen toddlers from underrepresented ethnic and language groups (10% to 29%).3 While there is substantial variability in utilization of tools, limited information is available regarding characteristics of providers who are more likely to screen for ASD.

#### Availability and Training on Tools

The M-CHAT and companion interview, M-CHAT/R-F, as well as the ITC are available for free download and use in primary care settings. The original M-CHAT and ITC are available in numerous different languages (30 languages other than English at the time of this report for the M-CHAT). Behavioral coding, assessment, and interview procedures used to follow up ITC screens have varied substantially, are not always clearly stated within protocols,63 and may require additional resources and training to accomplish. Administration and scoring of the M-CHAT, M-CHAT/R-F, and ITC instruments requires no specific training and scoring takes less than 5 minutes. Utilization of the followup interviews embedded within M-CHAT and M-CHAT-R/F and specific referrals for children flagged with concerns may take substantially longer. However, this interviewing is designed to be employed only when concerns are in a questionable range (i.e., 3 to 6 failures; automatic failure if self-report score >7), which somewhat limits the time needed (estimated at 5 to 10 minutes by authors) to accomplish the interview.61, 101 Although designed to be used by extenders with limited resources, there may be some training and capacity issues related to how initial results of screeners and next steps would be conveyed to caregivers.

The SACS, YACHT, and ESAT all use assessment procedures that are not freely available. Their training requirements for use outside of specific research protocols are unclear (i.e., trained nurses and home-visiting psychologists).

#### Practice Supports for Screening

The “Autism Case Training (ACT): A Developmental Behavioral Pediatrics Curriculum” is available from the CDC and offers continuing education credit to providers accomplishing training. This series was written by developmental-behavioral faculty and fellows from 10 Maternal and Child Health Bureau Developmental-Behavioral Pediatrics Fellowship Training Programs and the CDC. In addition, AAP has developed an ASD Resource Toolkit for care providers that supports the medical home in identification and care for children with ASD. Finally, Autism Speaks maintains resources for both practitioners and families designed to ensure ready access to information about ASD care.

#### Referral Resources

Children who screen positive as a result of ASD screening practices are often referred for further evaluation and intervention services, in addition to additional surveillance and care facilitated by the primary care provider. For many primary care providers, the most common referral pathway is a referral to Early Intervention (Part C) programs within their states.45

The Program for Infants and Toddler with Disabilities (Part C of the Individuals With Disabilities Education Act [IDEA]) is a federal grant established by Congress. It assists states in operating a statewide program of early intervention services covering children ages birth through 2 years, 11 months. For a state to participate in the program, it must assure that early intervention will be available to every eligible child and its family. Currently, all states and eligible territories are participating in the Part C program.

The current IDEA Statute (P.L. 108-446) contains many requirements that states have to meet. However, states have some discretion in setting the criteria for child eligibility, including whether or not to serve at-risk children. As a result, service eligibility definitions differ significantly from state to state. Given this variability, not all children screening at risk for ASD are automatically eligible for services. However, all referred children are eligible for assessment through this program within a legally mandated time period. Eligibility does not hinge on a diagnosis of ASD and services are to be structured based on family goals. Available appropriate services for children eligible for Part C often differ dramatically by state, geographical regions within states, and by family and child. Historically, children with a specific ASD diagnosis have obtained higher-intensity, specialized intervention services than children without a diagnosis.39, 40 However, state Part C systems are increasingly incorporating specific ASD screens into their own eligibility process. They are also incorporating explicit mechanisms to follow up on provider screens in order to provide eligibility for intensive levels of ASD intervention that may, in some cases, be initiated prior to diagnosis.172 Many Part C systems also incorporate mechanisms for obtaining an ASD diagnosis into their eligibility and service process. Despite the variability across states, the focus of IDEA on children up to 36 months is consistent with a focus on early childhood screening as addressed in this report.

Providers may refer screen-positive children to private service providers (speech/language pathologists, occupational therapists, behavioral providers, center and school programs) in addition to, or in conjunction with, referrals to Part C systems. The availability and accessibility of such additional referral resources varies across communities and is difficult to catalogue.

### Contextual Question 2 Are Diagnostic and Treatment Resources Currently Adequate to Provide Services to Children Who Screen Positive for ASD?

Concerns about lengthy waiting lists and/or over-referral of children who meet screening criteria for reasons other than ASD have been postulated as contributing factors relating to incomplete incorporation of ASD screening into pediatric practice51, 52 and ultimately to the delays in diagnosis seen on a population level, with many children diagnosed after age 4 in spite of accurate diagnosis being feasible at younger ages.53, 173 Currently, there is substantial variability across communities in terms of access to diagnostic and treatment resources.

A formal ASD diagnosis is not necessarily a specific requirement for the initiation of services through many programs (e.g., state- and federally-funded early intervention [Part C] and school [Part B] systems, adjunctive therapy services). However, access to subsidized early intensive behavioral and developmental intervention (i.e., supported by health insurance, school systems, early intervention systems) is often limited without a confirmed diagnosis, and children commonly receive lower levels of service in the absence of such a diagnosis. Although some Part C systems offer pathways for children to receive diagnostic clarification and subsequent services, disparities still exist in access to diagnostic assessments. For some children, the time from screening to diagnosis and treatment may be estimated in weeks; however, for other children, waits for diagnostic assessment may be in excess of 6 months.49, 174

Data from the most recent CDC prevalence study indicate that more children were formally diagnosed with ASD in the 2014 Autism and Developmental Disabilities Monitoring (ADDM) report than at any previous time point. At the same time, a significant proportion of children with ASD did not have a clinical diagnosis either in their medical or educational record, which suggests capacity is not currently meeting the need. Additionally, only 44 percent of children with ASD diagnoses via ADDM monitoring had received evaluations for developmental concerns prior to age 3.

There are limited data available on the numbers of families able to access services on a community level. Currently, all states and eligible territories participate in the Part C early intervention program for children ages birth to 3 years. This system presumably allows children to receive services based on risk prior to diagnosis as well as postdiagnosis, but these services may range in intensity and focus. Children who are over age 3 may have access to additional services through their school district, but the nature of services provided within these systems is variable.

Most states (estimated at 34)175 have enacted ASD insurance reform legislation that provides for specific access to evidence-based intervention services through private insurance. The availability and accessibility of resources for referral varies across communities.

### Contextual Question 3 To What Degree Does Evidence Indicate That Children Can Be Accurately Diagnosed With ASD, Using the ADOS and/or Expert Clinical Opinion? What Does the Current Scientific Literature Demonstrate Regarding the Persistence of an ASD Diagnosis?

ASD is a behaviorally based diagnosis with clinical diagnosis the gold standard in diagnostic accuracy; this diagnosis incorporates information from multiple sources and depends on the professional training and expertise of the evaluator. Information about medical and developmental history, cognitive and developmental functioning, and behavioral observation are crucial components of ASD evaluation. Complex cases are particularly reliant on information from a skilled clinician and caregiver.

Increasingly, clinicians and researchers have specific tools to aid in assessing the core features of the disorder. The most well validated and commonly used measure in both research and clinical settings for diagnosing ASD is the ADOS. This measure is a semistructured assessment that rates key social communication skills and atypical behaviors associated with ASD. It has historically been considered crucial in research and is becoming more commonly used by clinical and educational professionals as well. The instrument is available for purchase from a U.S. publisher along with training materials and videos. The newest iteration of the ADOS, the ADOS-2, has sensitivity and specificity for diagnosing ASD from 91 to 94 percent for toddlers with few to no words and 88 to 94 percent for toddlers with some words.176 Similar discrimination and sensitivity for children in the second year of life have also been documented in samples not affiliated with the authors of the instrument.177 The administration of the ADOS-2 is one component of a full diagnostic evaluation for ASD. While it is considered the most common instrument in diagnostic assessment practice, it is not a necessary component for such a diagnosis. Information about medical and developmental history, cognitive and developmental functioning, and additional behavioral observations can be obtained via numerous methodologies and reports.

A growing body of work suggests that diagnoses of ASD delivered by an expert clinician using standardized assessment tools has use in predicting continued ASD diagnostic classification up to school age.93, 178-180 However, given some clinical recommendations for screening during the second year of life, there has been a growing need to understand how well we can diagnose young children and whether diagnoses in this younger age group are stable. Although most of the initial diagnostic accuracy evidence in children under age 2 was from studies conducted with experienced and highly trained staff in research settings,181, 182 there is some evidence that the ADOS-2 can be used for young children in community-based clinic environments.183 Pediatric providers can be trained to accurately diagnose ASD49, 174 and clinicians using community screening protocols may be able to accurately identify ASD between 15 and 23 months of age for most children.177

### Contextual Questions 4 and 5 To What Extent Does Overdiagnosis Exist in Young Children Referred to Diagnostic Evaluation After Screening? To What Extent Does Underdiagnosis Exist in Children Referred to Diagnostic Evaluation After Screening?

Our review found the CDC's ADDM Network provides some evidence of the degree to which there is over- or under-identification of ASD in children. In the most recent CDC review of health and special education records from 2010, roughly 20 percent of 8-year-old children who had been identified as having ASD through the ADDM classification process did not have a formal educational classification or clinical diagnosis in their medical or educational charts.1 In some catchment areas, this number was as high as 43 percent. Many of these children were identified under a different classification than ASD for obtaining educational services. This suggests that on a population level, the collective medical and educational systems may not be completely or accurately identifying ASD at early ages.

ASD has recently been redefined in DSM-5 to include individuals across the spectrum, and understanding of the attendant variations in natural history is incomplete. Although historically ASD has been thought of as a lifelong condition, there is increasing awareness that some children at later ages appear to have more “optimal outcomes.”184 Some children identified with ASD at early ages may demonstrate improvements in functioning, both in relation to maturation as well as intervention, such that a diagnosis of ASD may no longer be appropriate. This idea of “best outcome” and/or “recovery” is not novel.185, 186

Recent work suggests that even after receiving thorough, accurate diagnostic classification at young ages, there will be some individuals who no longer meet criteria for ASD and whose communication and socialization skills are on par with typically developing individuals, but research in this area is so new that estimates of how many individuals this includes are unavailable.184, 187 Nonetheless, preliminary numbers vary across studies. Although early estimates of “optimal outcomes” for children with ASD by Lovaas185 reached 47 percent with intensive levels of treatment (40 hours per week of individual ABA for at least 2 years), more recent estimates of such outcomes are smaller and variable,188 with some evidence that even in children with initially average intelligence, significant challenging behaviors across the lifespan may reduce ability to even complete standardized assessments by adulthood.189 Smith et al found that compared to a parent training group, children who received 30 hours of individual ABA per week (again, for a period of years) achieved significantly more regular education classroom placements (both with and without supports) than controls, but only 2/15 children in this group achieved regular education placement without support as well as IQs in the average range.120 It is unknown whether such groups represent diagnostic errors, correct diagnoses in children whose developmental pattern encompasses significant improvements in ASD-related impairments, or are the results of accurate early diagnosis and treatment. A review of the adult outcome literature suggests that improvements like these have not been common,190 but may become more common as cohorts of children receiving interventions are tracked to early adulthood.163

### Contextual Question 6 Do the Outcomes of ASD Screening and Efficacy and Harms of ASD Interventions for Young Children Differ by Pertinent Subgroups, Such as Racial/Ethnic Minority, Low-Income, and Uninsured Children?

Subgroup data are largely unavailable at this time. Most of the highest quality intervention studies have not adequately included families from traditionally underserved backgrounds. Children from underserved communities are less likely than children from other communities to be screened,3 in spite of data indicating that accurate primary care screening and referral are possible in diverse and traditionally underserved populations.39, 63, 162 The effects of socioeconomic characteristics on treatment outcomes have not been well explored. However, some data suggest that families with lower SES may be less likely to access higher intensity interventions.120 Families with greater annual incomes are more likely to have children diagnosed at young ages,191 whereas children of parents with lower socioeconomic or educational status are less likely to be diagnosed promptly.37, 190, 192-194 Research into the effects of racial/ethnic backgrounds on ASD diagnosis and intervention is similarly lacking. Existing evidence indicates that compared to children from other racial/ethnic groups, African American children are more likely to receive an inaccurate diagnosis before being identified correctly as having ASD.193 Additionally, CDC researchers have documented a historical trend for later identification of ASD in other racial/ethnic minority groups as well.1

## Limitations of the Review

There are several significant methodological issues in the currently available screening literature. First, many studies of purported ASD screeners have actually been conducted in settings with limited relevance to primary care and potential universal screening practices. These clinical and convenience samples do not adequately demonstrate the psychometric properties of screeners in practice for several reasons: they do not usually include children with a range of other concerns, they rely on parent-report of symptoms in children in whom ASD has been identified, or they include only the subset of individuals presenting to these defined clinical and research settings rather than the entire referral sample. We excluded these studies from our review, but were therefore left with a small number of studies to include.

A second significant concern is the lack of data on, and adequate methods for, capturing potential false negatives of the screening process. No study of the M-CHAT or ITC adequately followed a large enough random sample of children to be able to realistically comment on NPV, specificity, or sensitivity. Thoroughly following a population cohort of low-risk children for a disorder with a low prevalence rate (1.47%) is a substantial challenge that requires significant resources and may be unrealistic for specific research programs. Specifically, case confirmation ultimately necessitates either expert behavioral assessment at young ages and/or thorough review of system records to determine case-ness or lack thereof. Current studies have not yet had the resources to provide such numbers. Without such studies, screening properties are evaluated by comparing PPV with the estimated prevalence of the disorder, and in some studies by assessing a select group of screen negatives, typically individuals who failed one portion of the screener or whose results were borderline.

Third, the available studies have high rates of attrition and there is very little information available about the children and families who leave the studies.

Fourth, data are lacking regarding how performance characteristics of screeners in primary care settings may vary based on child (e.g., sibling status, sex, prematurity, age, symptom severity and presentation) and family risk factors (e.g., SES, literacy level, race/ethnicity, primary language). Screening at ages below 16 months may result in more classification errors, specifically false-positive screens for ASD in absence of other developmental concerns. Further, available data do not suggest an identifiable bias in terms of identification of children with more severe profiles. Specifically, developmental assessment of children within protocol confirmation samples identifies children with a range of cognitive, adaptive, and ASD symptom profiles. It is also important to note that such measurements are highly variable at young ages in that many children testing in ranges of impairment at very young ages may show substantial improvements via intervention and maturation at later ages.

Fifth, the majority of treatment studies are in clinically referred children, often older than the recommended screening age, and often with more severe manifestations of ASD than would be expected in a screen-detected population.

Finally, in terms of access to services, children screened at risk and later diagnosed with ASD receive higher levels of service in comparison to children without such diagnosis. However, systematic prospective studies have not yet been conducted that examine service access and the impact of service delivery postdiagnosis for children screened at risk.

## Future Research Needs

As noted, despite the resource-intensiveness and difficulty of execution, studies following large samples of both screen-positive and -negative participants would provide valuable data for understanding screening outcomes. Similarly, understanding of longer-term health outcomes of screening is largely lacking, and data on intermediate outcomes including time to diagnosis and treatment is sparse. Studies assessing potential modifiers of outcomes (age, sex, race/ethnicity) are also needed, as are studies evaluating specific risk factors such as prematurity and sibling status. Further, movement from screening, through diagnosis, to active engagement in evidence-based intervention is a complicated process inclusive of challenging child, family, and system factors. Future work elucidating the specific characteristics of children, families, and systems that are more and less effectively engaged in the process is needed to address barriers on all levels. This would include evaluating the costs and benefits of the population level identification process that result from any attempts at screening. Largely, studies have investigated the ability to accurately detect the disorder early, but have less effectively understood those missed by this process and those where initial concerns were present, but seen as consistent with another area of concern or lack thereof. Such work would help both individuals and systems of care better weigh the benefits and harms of large-scale screening programs. Importantly, the issues that affect families in whom children receive early false-positive screens for ASD are not described in the literature and certainly warrant further consideration.

Comparative implementation of different screening practices and tools (ideally using randomized designs) including repeated screening procedures, combined use of measurement strategies (e.g., clinical observation/assessment), and head-to-head comparisons of tools would be valuable. Development of improved tools that may be better able to isolate critical concerning behaviors (at even earlier ages) across reporters as well as methods for understanding and accounting for reporting bias may also be productive areas of future work. Further, methodologies for combining biological and behavioral risk may be appropriate over time and help identify ASD at even earlier ages. Finally, studies to assess the effectiveness of treatment in screen-detected populations are needed.

## Conclusion

Formal ASD screening in general pediatric practices with the M-CHAT-F and M-CHAT-R/F has a PPV for identifying children with ASD of around 50 percent. Very little information is available on the degree to which screening tools miss positive cases, and no studies directly relate screening to clinical outcomes. Screening tools are widely available and referral pathways to early intervention and special education systems are available in all states. The ability of individual families to access appropriate diagnostic and treatment resources within and across these settings is variable. Eleven of 20 early intensive intervention studies assessing cognitive changes demonstrated that treatment groups had statistically significant greater gains in cognitive outcomes than eclectic comparison groups. In 13 of 28 studies evaluating language outcomes and in nine of 10 evaluating joint attention outcomes, treatment was associated with significant improvements in outcomes relative to controls. Studies of long-term outcomes in populations with research identify early cognitive skills and shifts in cognitive outcomes as significant predictors of positive outcomes (including independence) at age 19.