# Results

## Literature Search

### Screening Studies

We identified 3,469 citations potentially addressing screening for ASD. We excluded 3,050 publications at the abstract review stage and 435 at the full text stage (Appendix E). We summarize results from 17 unique studies (reported in 22 publications; one publication reports two separate studies) meeting our inclusion criteria in this review. Figure 2 outlines the disposition of screening studies in primary care settings. We also summarize information about studies identified for the treatment-related KQs (4 and 5).

Figure 2 Disposition of Screening Studies Identified for This Review (KQs 1 to 3)

^a^ Numbers do not tally as studies could be excluded for multiple reasons.

^b^ One paper reported 2 unique studies; 3 studies comprised multiple publications.

This figure is a flow chart that summarizes the search and selection of screening (KQs 1–3) articles in the systematic review. There were 3,469 citations identified through literature databases. An additional 38 citations were identified from other sources. After duplicates were removed, 3,507 unique citations were screened at the title/abstract stage. The full text of 457 citations were examined for inclusion for one or more of the Key Questions. Seventeen articles were included for Key Question 2. Reasons for excluding the other articles are provided in Appendix E.

Among the 17 unique primary care screening studies described in this review,39, 58-78 we rated five as good quality,39, 61, 67-71, 75, 76 10 as fair quality,58, 59, 62, 63, 65, 66, 72-74, 78, 79 one as fair to poor quality,77 and one as poor quality.64 Most studies (n=6) were conducted in Europe,62, 64-66, 75, 78 six in the United States,39, 61, 63, 67-71, 76, 79 three in Japan,59, 72, 77 and one each in Australia and Israel.58, 73, 74 Participant ages ranged from 4 to 36 months, and studies screened between 583 and nearly 35,000 children. Box 2 summarizes the characteristics of these included studies, and Appendix C includes evidence tables for each study.

Box 2 Characteristics of Included Screening Studies

Study, Country, Quality | Instrument (Cut Point for Positive Screen) | Age Range | Total Screened | Group(s) Followed to Diagnosis
Baird 2000^75^ UK Good | CHAT—first screen (NR) | 18.7 ± 1.1 months | 16235 | Attempted to follow all, but had substantial loss to followup
VanDenHeuvel 2007^64^ Ireland Poor | CHAT+followup CHAT for participants at risk on first screen (NR) | 18-20 months | 2117 | Screen positive
Robins 2014^61^ US Good | M-CHAT-R/F (≥2) | 16-31 months | 16115 | Screen positive, 42 negative screen STAT positive and/or pediatric concerns
Chlebowski 2013^101^ US Good | M-CHAT+followup interview (3/23 items failed or 2/6 critical items) | Mean=20 months | 18989 | Screen positive
Kamio 2014^59^ Japan Fair | M-CHAT-Japanese+Followup interview | 17-26 months | 1851 | All
Nygren 2012^62^ Sweden Fair | M-CHAT+Followup interview (3/23 items failed or 2/6 critical items) | 2.5 years | 3999 | Screen positive
Canal-Bedia 2011^78^ Stage 1 Spain Fair | M-CHAT (Spanish)+Followup interview (3/23 items failed or 2/6 critical items) | 18-24 months | 2480 | Screen positive
Canal-Bedia 2011^78^ Stage 2 Spain Fair | M-CHAT (Spanish)+Followup interview (3/23 items failed or 2/6 critical items) | 18-24 months | 2055 | Screen positive
Inada 2011^77^ Japan Fair-Poor | M-CHAT-J—Full (2 of any 23 items failed) | 4-26 months | 1187 | Unclear – published analysis includes only children with both 18 month and 36 month data
Pierce 2011^39^ US Good | CSBS-ITC (10^th^ percentile) | 10.1-15.9 months | 10479 | Screen positive participants seen for ≥2 sessions and 41 randomly selected screen negative participants
Wetherby 2008^76^ US Good | ITC (bottom 10^th^ percentile on social or symbolic composite or total score or bottom 10^th^ percentile on 2 consecutive speech composite) | 6 - 24 months | 5385 | Screen positive + random screen negative participants (number not reported)
Miller 2011^63^ US Fair | M-CHAT+Followup Interview (3/23 items failed or 2/6 critical items) and ITC (bottom 10th percentile) | 14-32 months | 796 | Screen positive and 2 screen negative participants
Turner-Brown 2014^79^ US Fair | FYI (≥90^th^ percentile) | 12 months | 1305 | Screen positive
Ben-Sasson 2013^58^ Israel Fair | FYI | 11-13 months | 583 | Screen positive+12 screen negative+review of medical records of 148 screen negatives
Dietz 2007^65, 66^ Netherlands, Fair | ESAT- 4 item (≥3 items failed) | 14 – 15 months | 31724 | Screen positive
Barbaro 2011^73, 74^ Australia Fair | SACS (3 of 4-5 items failed) | 8-24 months | 20770 | Screen positive
Honda 2009^72^ Japan Fair | YACHT-18 (NR) | 18 months | 2814 | Screen positive + 4 screen negative participants

ASD=autism spectrum disorder; CHAT=Checklist for Autism in Toddlers; ESAT=Early Screen for Autistic Traits; ITC=Infant Toddler Checklist; JA-OBS=Joint Attention Observation Schedule; M-CHAT=Modified Checklist for Autism in Toddlers; M-CHAT-R/F=Modified Checklist for Autism in Toddlers, Revised with Followup; PPV=positive predictive value; SACS=Social Attention and Communication Study; YACHT=Young Autism and other developmental disorders Check-up Tool.

Among the excluded studies were a number that assessed screening in children who had already been identified as having some sort of concern for developmental delay and therefore did not reflect an unselected primary care screening population.80-100 Most studies included children with known developmental delay or those referred to specialized centers for suspected developmental issues; four papers, reporting on data from populations that likely overlap though the reporting is not clear, assessed children already receiving early intervention services for an unspecified developmental delay.84-87 Two studies evaluated screening in younger siblings of children with ASD but were not in a primary care setting or population.90, 94

### Intervention Studies

We identified 2,639 citations and abstracts (Figure 3). We excluded 2,012 studies at abstract review and assessed the full text of 627 studies. Among these, 55 publications, comprising 42 unique studies, met our criteria for intervention studies and were rated as good or fair quality. These studies included 26 RCTs (nine good and 17 fair quality), five nonrandomized trials (one good and four fair quality), 10 prospective studies (two good and eight fair quality), and one retrospective cohort study (fair quality). Studies were conducted in the United States (n=21), the United Kingdom (n=6), the Netherlands (n=3), Norway and/or Sweden (n=4), Australia (n=2), Canada (n=2), Israel (n=2), Belgium (n=1), and Italy (n=1). Studies used early intensive behavioral and developmental interventions, all based to varying degrees on Applied Behavioral Analysis (ABA). We grouped them into three categories: direct provision to the child (n=17), incorporating parent training (n=13), or play/interaction-focused (n=12).

Figure 3 Disposition of Intervention Studies Identified (KQ 4)

^a^ Numbers do not tally as studies could be excluded for multiple reasons.

n=number.

This figure is a flow chart that summarizes the search and selection of intervention (KQ 4) articles in the systematic review. There were 2,589 citations identified through literature databases. An additional 50 citations were identified from other sources. After duplicates were removed, 2,639 unique citations were screened at the title/abstract stage. The full text of 627 citations were examined for inclusion for one or more of the Key Questions. Fifty-five articles were included for Key Question 4. Reasons for excluding the other articles are provided in Appendix E.

## Results of Included Studies

### KQ 1 Is Screening for ASD Conducted in Children 12 to 36 Months Old Associated With Improved Short- and Long-Term Outcomes?

We did not identify studies that directly compared screening (vs. no screening) in terms of longer-term health and social outcomes.

### KQ 2 What Are the Performance Characteristics of ASD Screening Tests in Children 12 to 36 Months Old?

#### Checklist for Autism in Toddlers

##### Key Summary Points

- In one good-quality study, the sensitivity of the Checklist for Autism in Toddlers (CHAT) for first-round screening conducted by nurses was 35.1 percent (specificity, 99.9%). For the second screen of children who screened positive on the first round, the PPV at a high risk threshold was 83.3 and 58.8 percent using a medium risk threshold. Overall, the tool was specific (>95%), but sensitivity for detecting ASD was low (21.3%).
- Use of the CHAT resulted in substantial under-identification of ASD (i.e., low sensitivity and modest PPV) in a low-risk population. Due to this concern it has been in limited use in the United States since publication of these findings and is largely replaced by the Modified Checklist for Autism in Toddlers (M-CHAT).

##### Description of Measure

The CHAT was one of the first formal screeners developed in the United Kingdom for early identification of ASD and was designed in an attempt to identify autism at 18 months. The CHAT assesses pretend play, pointing, and gaze monitoring by both parent report and practitioner observation via direct testing.

##### Detailed Analysis

One good-quality study (Baird 2000) followed up on a 12-month birth cohort of children in the United Kingdom who were screened using the CHAT at 18 months of age.75 Additional screening took place at 3 and 5 years of age using the Checklist for Referral and the Pervasive Developmental Disorders Questionnaire. The population was then reexamined at 7 years of age to determine the performance characteristics of the CHAT. This was accomplished through a broad examination of available data potentially identifying ASD in this population, including examining referrals to clinical centers and medical/educational/social service and other available records. Children identified at risk by any of these screenings were directly assessed by a research team and assigned ICD-10 diagnoses.

A sample of 16,235 toddlers was administered (13,694) or mailed (2,541) the CHAT at 18 months of age by their primary health care providers, who were primarily nurses (1-stage). Those who screened positive were rescreened 1 month later by the research team (2-stage), with children with severe developmental delays excluded at the discretion of the home visitor. At both stages toddlers were placed into a high risk (failure of five critical items) or medium risk category (failure of item A7 and B4, both items regarding pointing). During the first round of screening, 38 children met the threshold for high risk and 369 met the threshold for medium risk. The sensitivity of the CHAT for this first round of screening using both medium and high risk thresholds was 35.1 percent (specificity, 99.9%). During the second round of screening, 12 children continued to meet the threshold for high risk and 22 continued to meet it for medium risk. Due to resource constraints, investigators rescreened only half of the medium-risk cases. For the second screen, the PPV of the high risk threshold was 83.3 percent and 58.8 percent for the medium risk threshold. Overall, while the measure was quite specific (>95%), the sensitivity for detecting ASD was low (21.3%). The investigators hypothesized that false negatives may have resulted from the following concerns: 1) asking parents if they had “ever” demonstrated a behavior versus “rarely” doing so might be a less sensitive measurement strategy, 2) identification of communicative pointing by parents at young ages may be challenging, and 3) the potential of a late-onset and/or regressive form of ASD manifesting more clearly at later ages. Important limits of the study included only 40 percent representation of population cohort, exclusion of children with “handicaps,” screening conducted via researchers versus clinicians, and lack of reliability data on the instrument.

An additional poor-quality study (VanDenHeuvel 2007) examined the use of the CHAT at 18- month well-check visits with public health nurses.64 The sample included 2,117 18-month-olds (1,029 females, 1,088 males). Due to methodological limitations, true sensitivity, specificity, NPV, and PPV were not able to be calculated. However, the identification of only seven children from this cohort is in line with concerns about the sensitivity of the CHAT as a stand-alone instrument documented in previous work.75

#### M-CHAT Studies, M-CHAT With Followup Interview

##### Key Summary Points

- Two good- and four fair-quality studies assessed the use of the M-CHAT and the M-CHAT Followup Interview (M-CHAT/F) in children 12 to 36 months of age without previously identified symptoms of developmental delay.
- PPV using the M-CHAT questionnaire and followup interview as recommended was 54 percent in a large, good-quality study of over 18,000 children in the United States.
- In that study, nearly all 171 screen-positive children who underwent a diagnostic evaluation received a final diagnosis of either ASD (n=92) or some other developmental concern (n=75). Four received a final diagnosis of normal development.
- Not using the followup interview component results in substantial over-identification, with approximately 10 percent initially identified as screen positives.
- Attrition rates were approximately 24 percent between the initial screen and followup and 39 percent between followup interview and diagnostic evaluation.
- There are not currently good estimates of how many children with ASD screen negative on the M-CHAT, although validation procedures and population estimates suggest this number may be substantial.

##### Description of Measure

The M-CHAT is a 23-item parent-report (Yes/No) ASD screening tool initially designed for children 16 to 30 months of age. It differs from the original CHAT in that: 1) it covers a more extensive set of developmental domains (e.g., sensory, motor) and 2) it relies exclusively on parent report without clinical observation. To address concerns about potential over-identification of risk based on parent report alone, the authors of the instrument later formally described and studied a specific followup interview (M-CHAT/F). This followup interview is conducted in person or via phone. Current use of the instrument is the combination of the parent report with the followup interview (for children in the moderate risk range), with the authors explicitly noting that questionnaire use alone probably results in increased false-positive identification of ASD risk. This tool is the most common approach to ASD screening in the United States and is recommended by the AAP.

##### Overview

We identified six studies—two good- (one reported in multiple publications) and four fair-quality studies (reported in three publications)—assessing the use of the M-CHAT and the M-CHAT/F in children 12 to 36 months of age without previously identified symptoms of developmental delay.59, 62, 67, 69-71, 77, 78, 101 One good-quality study is reported in five publications and includes data on the initial sample of children for whom reliability and validity of the measure were assessed. These publications provide results on the use of the M-CHAT alone and use of the M-CHAT and M-CHAT-F. Several of the studies include information drawn from both primary care (e.g., low risk) and clinical referral (e.g., high risk) samples. Another publication includes two separate studies.78 One study was conducted in the United States,67, 69-71, 101 two were conducted in Japan,59, 77 two (reported in one paper) were conducted in Spain,78 and one was conducted in Sweden.62

##### Detailed Analysis

One good-quality study (Chlebowski 2013) reported in multiple publications67, 69-71, 101 included 18,989 toddlers 18 to 24 months of age (mean, 20.4 [SD, 3.1]; 9,388 female, 9,601 male; 6,184 white/non-Hispanic, 1,186 nonwhite) who were screened at pediatric well-child visits in two regions of the United States (Georgia State University and University of Connecticut catchments). Results for some of the toddlers had been previously reported in other studies and were compiled with additional participants here. Toddlers were excluded if they had already received an ASD diagnosis or risk classification, had a severe sensory or motor disability (e.g., blindness, deafness) or if their parents were not fluent in English or Spanish.

M-CHAT forms were distributed at participating pediatric offices and sent to research staff for scoring. Parents of toddlers who screened positive on the M-CHAT (screening positive on two of the six critical items or any three of the 23-item measure) were called and completed the M-CHAT/F over the phone. Children who screened positive on the M-CHAT/F were offered a free comprehensive diagnostic evaluation. This evaluation, conducted by a licensed clinical psychologist or developmental pediatrician plus one or more doctoral trainees/research staff, included the ADOS and, for some participants, the ADI-R, as well as cognitive and adaptive measures. Diagnoses were made based on the DSM-IV.

Of the 18,989 children screened with the M-CHAT, 1,737 (9.1%) screened positive. About three quarters (1,295 [74.6%]) of these children went on to complete the M-CHAT/F. After this screen (M-CHAT/F), 272/1,295 children (1.4% of total screened sample) continued to screen positive and were offered evaluations. Evaluations were completed on 165 of the children who screened positive on the M-CHAT (questionnaire) and M-CHAT/F (followup interview), as well as six children who screened positive on such a high number of items on the M-CHAT (≥7) that the M-CHAT/F was not conducted (total n evaluations=171). Evaluations were also completed on 36 children who were identified as potential missed cases. These children were either “red flagged” by their pediatricians due to concerns or screened positive on a separate screening measure. Although all pediatricians were instructed to flag ASD concerns, these screeners and flags were not used systematically for the entire sample.

Out of the 171 evaluations completed on children considered as screening at risk, 92/171 received a diagnosis of ASD, 60/171 received a non-ASD DSM-IV diagnosis (n=37 developmental delay [21.6%], n=18 language disorder [10.5%], n=5 other behavioral diagnoses [2.9%]), 15/171 (8.8%) were noted to have developmental concerns but did not receive a diagnosis, and 4/171 (2.3%) were typically developing. The PPV for identifying ASD with the M-CHAT and M-CHAT/F was 54 percent. In the previous publications that included subsamples of the overall group of toddlers,67, 69-71 PPV for identifying ASD including a followup procedure (M-CHAT/F) ranged from 57 to 79 percent. The PPV for identifying any developmental concern (ASD, other diagnosis or developmental concern) in this population is 98 percent.

Of the 36 children receiving evaluations due to pediatrician flags as potential missed M-CHAT screen positives, six received an ASD diagnosis, 18/36 received non-ASD DSM-IV diagnoses (50%), nine were identified with developmental concerns (25%), and three were typically developing (8.3%).

The methods used for following screen negatives do not permit calculations of sensitivity, specificity, or NPV. The total number of children successfully identified by this screening study (0.48%) at an average age of 20 months is significantly below the currently estimated population prevalence (1.47%), but expected prevalence in the current sample would likely be lower because it excluded children identified early by parent or clinical concern or lost to followup (40% of screen-positive cases did not receive diagnostic evaluation). The investigators evaluated different scoring systems post-hoc and found that a revised scoring algorithm (≥3 total and no use of critical scores) would yield the best identification of screen-positive children. Additionally, 82.2 percent of children with a score of 7 or greater continued to screen positive when administered the M-CHAT/F, which may suggest that the followup interview could be unnecessary for very high M-CHAT questionnaire scores.

An additional fair-quality study conducted in the United States (Miller 2011) screened toddlers ages 14 to 30 months at all scheduled medical appointments (well-child, sick, followup, injection visit) during a 6-month period at a large community-based pediatric practice.63 Caregivers were given an M-CHAT, the Infant Toddler Checklist (ITC), or both to fill out when they checked in. The ITC is a 24-item developmental screener of language and communication that also includes a yes/no question about whether the caregiver is concerned about their child's development. Children failing the M-CHAT (≥3 total or ≥2 critical items) or the ITC (<10th percentile on Social, Symbolic, or Total scores) were then referred to research staff. If the child failed the M-CHAT, the M-CHAT followup interview was completed. If the child failed the ITC, items were reviewed over the phone by trained graduate students. Children administered either test who had a confirmed positive screen based on interview were invited to a full evaluation using the ADOS, the Mullen Scales of Early Learning, and the Vineland Adaptive Behavior Scales (VABS). During the study, 990 toddlers had appointments at the clinic, and 796 were screened. Of these, 192 (24%) screened positive on either the M-CHAT or the ITC, with 47 of 192 (24.5%) continuing to screen positive after the followup call/interview. Ninety-eight of 192 screened negative (51%), and 47 of 192 (24%) either declined or were not reached by telephone. Of those that were not lost to followup or that declined (n=145), the proportion screening positive (n=47) was 32.4 percent.

The 47 children screening positive, plus two children who screened negative but whose parents raised developmental concerns after the children were screened (total n=49), were referred for in-person evaluations. Thirty of these 49 received evaluations, as 12 did not show up and seven declined. After full evaluation, 13 of 30 children were diagnosed with or at high risk for ASD (43%), 16 had delays other than ASD (53%), and one was typically developing (3%). However, of the 13 children who were identified as having ASD or at high risk, three had been previously diagnosed with ASD and should thus be excluded for calculations of the performance characteristics of the screener (therefore, the total N for calculating performance characteristics is 27, of which 25 screened positive). Of the 10 new diagnoses, three screened negative on the questionnaires and were therefore identified using means other than the screening process. In one of those cases, the child subsequently screened positive on the M-CHAT and is therefore considered to be a screen positive-case positive; thus, there were a total of eight children who both screened positive and were diagnosed as positive. PPV for the combined use of ITC plus interview or M-CHAT plus interview as an ASD screener was, therefore, 32 percent (8/25). No information on the PPV of either tool alone was presented in this study.

As a result of screening, 60 percent of identified cases of ASD were found before parents expressed concern, 50 percent were identified before pediatrician concern, and in only 20 percent of cases were both the parent and pediatrician concerned before the screener identified a problem. These percentages are not mutually exclusive. Two children who did not screen positive in this process were flagged and referred for further evaluation by providers based on clinical concerns. Both of these cases showed early signs of ASD during the in-person evaluation.63

Four additional publications reported on the use of the M-CHAT/F in different language groups in different countries (Japan, Sweden, Spain).59, 62, 77, 78 All studies translated and back-translated the screener in accordance with guidelines set by authors, and made cultural-linguistic alterations to certain items to preserve item intent. Such subtle alterations and applications to varied cultural groups may affect reported psychometric properties of instrument use. However, to be comprehensive, and because even within the United States universal screening requires linguistic, if not cultural adaptation, we report results of these studies here.

One fair- to poor-quality, population-based study (Inada 2011) examined the use of the M-CHAT-Japanese (M-CHAT-J) questionnaire without the followup interview in a group of 1,187 (575 female, 612 male) children in whom data were available at the 18- and 36-month checkup in Munakata City, Japan.77 Twenty of the 1,187 children (2%) were diagnosed with ASD. These diagnoses were made based on developmental history, clinical assessment, and DSM-IV criteria. Diagnoses were confirmed by consensus between two psychiatrists and a psychologist with experience in child development. Several scoring cutoffs were explored, as well as the use of a shorter nine-item version of the M-CHAT-J. A cutoff of 2 or greater on the 23-item version resulted in a sensitivity of 75 percent, specificity of 89.3 percent, PPV of 10.7 percent, and a NPV of 99.5 percent. The traditional cutoff of 3 or greater resulted in a sensitivity of 55 percent, specificity of 96 percent, PPV of 19 percent, and NPV of 99 percent. The low PPV across groups reflects a large number of false positives in this sample, in which no embedded followup procedure or interview was clearly specified.

Another fair-quality population-based study (Kamio 2014) examined the use of the M-CHAT/F-Japanese (M-CHAT/F-J) in 2,113 toddlers attending their 18-month well-check visit in Fukuoka City, Japan.59 Parents of 1,851 children completed the screening and had followup data available. It is unclear from the description whether any toddlers were lost to followup and whether the number described represents only those with followup, or whether the entire population did receive followup assessment. Modified M-CHAT/F-J scoring cutoffs were used that included labeling additional items as “critical” and lowering the threshold for ASD concern on the parent checklist. Original scoring criteria were used for the followup interview. Screen-positive children were invited for diagnostic evaluations by a team of child psychologists, psychiatrists, and nurses at age 2. These children were then invited back for full evaluations at ages 3, 4, and 5. The investigators created a 20-item checklist in order to follow up potential false negatives via well- visits at age 3 (i.e., children failing this questionnaire were also offered evaluation along with screen-positive children). Among the 1,851 children screened, 319 (17%) screened positive using the M-CHAT and 1,532 (83%) screened negative. Among the 319 children screening positive, 195 completed the followup interview and 124 did not. Among the 195 of 319 who completed the followup interview (61%), 44/195 (23%) continued to screen positive and 151/195 (77%) screened negative. Twenty children (45%) among the 44 screening positive on the followup interview were diagnosed with ASD.

In addition, because most children attended daycare or local kindergarten, the investigators sought additional information available at those locations to identify cases in the 3- to 5-year-old range. In total, 51 children were identified with ASD through the combination of screening and case-seeking. Forty-two of these children had participated in research screening, with 20 screening positive via the modified M-CHAT/F-J scoring procedure.

One publication (Canal-Bedia 2011) reported two separate fair-quality studies (one considered a validation study and one a reliability study) completed in Madrid, Spain and using the M-CHAT/F translated into Spanish.78 The first study (validation of the translated M-CHAT) included 2,480 children ages 18 to 36 months (1,163 female, 1,254 male) who were recruited during their mandatory 18-month vaccination appointment or their 24-month well-child visit. This population also included 63 children who were considered high risk for ASD and who had developmental ages of 18 to 24 months (maximum chronological age, 48 months; range not provided). Primary care pediatricians and nurses distributed the M-CHAT, which was completed by parents, and psychologists with training in child development conducted the followup interview with parents of those children who screened positive. Out of the 2,480 children screened, 429 screened positive on the initial questionnaire (17%), and 86/429 (20%) continued to screen positive after followup. All 86 children who screened positive underwent a diagnostic assessment based on DSM-IV criteria. As a result of this assessment, 23/86 children (27%) were identified as having ASD. Nineteen of these cases were from the high-risk sample. The PPV of the M-CHAT/F in this study was 27 percent.

The second study (reliability study) reported in the same publication78 was a population-based study in Madrid and included 2,055 children (949 female, 1,106 male) 18- to 36-month-olds attending their vaccination or well-child visit. The procedures were the same (i.e., primary care pediatrician or nurse distributing the questionnaire, psychologist completing the followup interview). Out of the 2,055 screened, 336 (16%) screened positive on the M-CHAT, and 31/336 (9%) continued to screen positive following the M-CHAT/F. All 31 completed a diagnostic assessment, and 6/31 (19%) were ultimately diagnosed with ASD, resulting in a PPV of 19 percent. This was a population with no known cases at high risk initially.

Another fair-quality study (Nygren 2012) screened 3,999 children (1,912 female, 2,087 male) at their 2.5-year checkup at child health centers in Gothenburg, Sweden.62 This study is part of a larger effort to implement a screening program in Gothenberg. The authors estimated that 80 percent of all 2.5-year-olds (approximately 5,000) in the area were screened. This analysis focused on those children who were younger than 24 months or older than 36 months. The M-CHAT questionnaire and followup interview were translated into Swedish with the guidance of the original authors to ensure integrity of the instrument. The questionnaire was mailed to the family before their appointment. Nurses (who had been trained on scoring the M-CHAT/F) administered the followup interview in person to those children who had screened positive on the initial questionnaire. These nurses were also trained on developmental milestones, early signs of ASD, as well as a Joint Attention Observation of Toddlers (JA-OBS) screen. The JA-OBS consists of observations by the examiner of child response to name, eye contact, response to examiner's direction of attention (finger pointing), child's use of finger pointing to direct attention, and pretend play. Failure of 2 or more items constitutes a positive screen. Both screening approaches were used for all children.

If a child screened positive on either the M-CHAT/F or JA-OBS or if there was a suspicion of ASD for other (undefined) reasons, a separate appointment was made with a pediatrician to take family medical history and screen for other possible medical problems. The pediatrician then referred children who still had a high level of ASD concerns to a specialist. Of 3,999 children screened using the M-CHAT/F and JA-OBS, 64 were considered at risk on either tool: 62 detected via the screening process and two referred from speech pathologists. Ten children who screened positive on any mechanism were lost to followup.

Of the total of 64 children screening positive, 36 were identified using the M-CHAT/F, 33 of whom received a diagnosis of ASD after neuropsychiatric confirmatory examination. The PPV for the M-CHAT/F was therefore 91.7 percent. Forty children screened positive on the JA-OBS; 37 of these children ultimately received a diagnosis of ASD (92.5%). The PPV for the JA-OBS was 92.5 percent (95% CI, 79.6% to 98.4%). Of the 54 who had a positive screen through any mechanism and went on to a diagnostic assessment, 51 had been screened with both the M-CHAT/F and the JA-OBS, and 45 of the 48 who ultimately received an ASD diagnosis had been screened with both tools. Of these, 43 screened positive on either one or both of the tools, yielding an overall PPV for screening of 89.6 percent (95% CI, 77.3 to 96.5).

#### Modified Checklist for Autism in Toddlers, Revised With Followup

##### Key Summary Points

- The Modified Checklist for Autism in Toddlers, Revised With Followup (M-CHAT-R/F) is a two-part screening process assessed in one good-quality U.S. study including 16,115 toddlers between 16 and 31 months of age.
- Using the M-CHAT-R/F identified significantly more children with ASD than the M-CHAT/F (67 per 10,000 vs. 45 per 10,000; p=0.003).
- Use of the M-CHAT-R/F procedure (e.g., questionnaire and formal interview) within diverse community-based primary care settings had a PPV of 48 percent.
- Eighteen percent of participants were lost to followup between the initial screening and followup interview, and 57 percent were lost between the followup interview and diagnostic evaluation.
- Diagnoses included: ASD (n=123), global developmental delay (n=61), language delay (n=25), other unspecified diagnosis (n=1), no diagnosis (n=30), and typically developing (n=23).
- It is unclear as to how many children with ASD screen negative on the M-CHAT-R/F at young ages or how the procedure operates in high-risk samples.

##### Description of Measure

The M-CHAT-R/F is a two-stage screening process. Parents complete a 20-item parent-report (Yes/No) ASD screening tool. Modifications from the original M-CHAT questionnaire include: 1) deletion of items with reported poor performance, 2) reordering of items to guard against agreement bias in reporting, 3) simplification of language to improve comprehension, 4) and provision of specific examples to anchor behavioral reporting. If children screen positive, parents then participate in a structured followup interview to obtain additional examples to assess risk. The tool is designed to be completed by a pediatric extender or support staff. Scoring of the M-CHAT-R/F is based on total scores from parent report and/or interview (i.e., scoring not based on critical item scores). This modified tool became available for free use in January 2014.

##### Detailed Analysis

The most recent study in the United States of population-level screening for autism used the M-CHAT-R/F (Robins 2014).61 The study included 16,115 toddlers 16 to 31 months of age (mean 20.95 ± 3.3; 7,570 female, 7,793 male; 6,184 white/non-Hispanic, 1,186 nonwhite) who were screened at 85 pediatric clinics (41 metropolitan Atlanta, 44 University of Connecticut catchment areas).61 Toddlers were excluded if they had already received an ASD diagnosis or risk classification, had a medical condition that precluded evaluation, or if their parents were not proficient in English.

M-CHAT-R/F forms were distributed during 18- or 24-month well-care visits. Pediatricians were also asked to indicate any clinical concern about ASD on top of the screening form. Research staff scored the completed forms and completed followup telephone interviews. Toddlers who failed the screening protocol (questionnaire plus followup) or whose physician had indicated concerns were offered a free diagnostic evaluation. This evaluation, supervised by a licensed clinical psychologist or developmental pediatrician, included the ADOS, the Childhood Autism Rating Scale-2, the Toddler Autism Symptom Interview, and cognitive and adaptive measures. Diagnoses were based on the DSM-IV using all available information.

Of the 16,115 children screened with the questionnaire, 1,155 (7.2%) initially screened positive. Of these, 946 (81.9%) completed the followup interview, thus completing the screening process. After this screen, 348/946 children (2.2% of total screened sample and 30% of those who had initially screened positive) continued to screen positive and were offered evaluations. Of the 348 children (64%) who screened positive on the combined questionnaire and followup interview, 221were evaluated for ASD. About half received an ASD diagnosis (n=105/221 [47.5%]). In addition, 79/221 (35.7%) had “other delays,” 25/221 (11.3%) had developmental delays not associated with a diagnosis, and 12/221 (4.5%) were typically developing. The authors calculated a PPV for any diagnosis as 0.946 (95% CI, 0.92 to 0.98) but do not indicate what the specific “other delays” diagnosed were.

A small, quasirandom sample of children who had screened negative at the Atlanta site (n=375) were given a second screener, the Screening Tool for Autism in Two-Year Olds (STAT). The STAT is a brief (20 minute) interactive ASD specific screener administered by a trained clinical researcher designed to yield an overall ASD risk classification based on assessment of core communication and play skills. Children who had initially scored positive on the M-CHAT-R/F but negative on the followup were most heavily recruited for this assessment. Of the 375 children recruited, 20 screened positive on the STAT and were sent for further evaluation. Six (30%) of these 20 children went on to receive ASD diagnoses. With regard to physician ASD concerns (i.e., box for primary care provider to indicate ASD concerns on M-CHAT), 45 of 64 identified cases of concern attended an evaluation, with 42 diagnosed with ASD (n=30) or other concerns (n=12).

The criteria for assessing screen failure based on the followup interview were altered during the course of the study. Initially a total cutoff score of 3 or greater on both the questionnaire and followup interview was used. However, five of seven cases who had screened negative on this basis, and who had a cutoff of 2 but were identified as a concern by clinicians, were found to have ASD, so the cutoff was lowered to 2. Performance characteristics after the change showed improved sensitivity. The authors also noted that all children scoring above 7 on the parent questionnaire ultimately were identified with ASD or an actionable developmental concern, suggesting that referral for diagnostic evaluation after one-step screening with M-CHAT-R/F may be appropriate for such cases.

The total number of children successfully identified by this screening study (rate of 0.65%) at an average age of 21 months is significantly below the known population prevalence (1.47%), but expected prevalence in the current sample would likely be lower because children identified early by parent or clinical concern, or lost to followup (29% of screen-positive cases were not followed up) were excluded. If one assumed no differential attrition, projected prevalence of screen-detected ASD would be 0.92 percent at 20 months.

#### ITC

##### Key Summary Points

- The ITC is a general developmental screener for communication development, not an ASD- specific tool. Studies have significant limitations.
- Two good-quality studies conducted in the United States and including a total of 15,864 children between the ages of 6 and 24 months assessed the ITC.
- Use of the ITC questionnaire in isolation may designate 10 percent or more of the total low-risk population as screening positive for ASD, many of whom clearly will not go on to an ASD or other developmental diagnosis.
- When considering the ITC's original purpose to identify all types of delays (including ASD, language delay, developmental delay, and other), PPV was 75 percent.
- Assessing only the ASD diagnoses results in a PPV of 18 percent.

##### Description of Measure

The ITC is a component of the Communication and Symbolic Behavior Scales Developmental Profile (CSBS).102 The CSBS is an assessment methodology for attempting to identify and gauge a broad range of developmental risks in young children. In contrast to the ASD-specific measures of the CHAT and M-CHAT, the ITC is designed as a screener for general developmental concerns to identify communication delays and disorders, including ASD. This parent-report questionnaire includes 24 items focused on social communication milestones rated on a Likert scale, and an open-ended question about current concerns. The ITC has been standardized in a normative sample; its results can be reported as screening cutoffs (e.g., risk cutoffs) or as standard scores for infants and toddlers between 6 and 24 months.

##### Detailed Analysis of Primary Care Studies

One good-quality study examined the effectiveness of the ITC as an ASD screener for young children in primary care settings (Pierce 2011).39 Children (n=10,479) across San Diego County, California were screened at their 12-month well-child pediatric visit (mean age at screening, 12.54 months; range, 10.08 to 15.97) using the ITC. Children who failed the screener, and were further evaluated using medical chart review, along with a selected sample of children who passed the screener (screen negative), were referred for a complete developmental evaluation. Participants were recruited via a flyer, and study personnel were not allowed to contact those failing the screening directly. The diagnostic evaluation included the ADOS and the Mullen Scales of Early Learning. Children were re-evaluated every 6 months until the age of 3. Children eventually diagnosed with ASD had a mean of 6.0 ± 2.5 visits. Re-evaluations included a re-administration of the ITC, ADOS, and the Mullen Scales.

After initial 1-year administration, 1,318/10,479 children failed the screener (12.6%, with failure defined as scoring <10th percentile) and 346/1,318 (26.3%) were referred for further evaluation after chart review. The authors do not explain why the majority (n=972 [73.7%]) of children failing the screening were not referred for evaluation. Of the 346 referred, 208 enrolled in the study, but 24 dropped out or did not respond to followup requests, leaving 184 screen-positive children who completed the initial screener as well as all of the followup appointments. The study also included 41 children who initially passed the screener at the 12-month well-child visit and were considered controls (total n=225). Five children were initially identified as having ASD, but this diagnosis was later removed. The authors did not include these children as false- positive results in their own calculations of performance characteristics. Of the 184 screen-positive children who received diagnostic evaluation, 32 (17%) were diagnosed with ASD, 56 (30%) had a language delay, nine (5%) had a developmental delay, 36 (20%) had another diagnosis (“Other”), five had prior ASD diagnoses as noted above, and 46 (25%) were false-positive results (no additional detail provided). All 41 children who passed the screener were identified as typically developing. When considering the ITC's original purpose to identify all types of delays (including ASD, language delay, developmental delay, and other), PPV was calculated to be 75 percent. When considering the ITC as an ASD-specific screener, PPV was calculated to be 17.4 percent.

The authors also tracked treatment engagement subsequent to screening, with 100 percent of toddlers with ASD and developmental delay and 89 percent of the sample with language delay referred for early intervention as soon as delay was documented via ITC scores and clinical concerns. Treatment on average began at approximately 17 months of age, with children in the ASD group receiving 11.5 hours per week of treatment compared to those in the language delay group (1.9 hours per week).39

In a second good-quality study (Wetherby 2008),76 a cumulative community sample of 5,385 children between the ages of 6 and 24 months was recruited from a variety of health and child care settings in the United States. Service providers were encouraged to administer the ITC each time the child was seen, so some children had multiple assessments. If children screened positive on the ITC or if their parents raised concerns, they were assessed using the Behavioral Sample of the CSBS. Screening data were then linked to ongoing ASD prevalence studies being conducted by this research group to identify children who received ASD diagnoses using 1) scoring from the Behavioral Sample, 2) responses to a questionnaire asking about ASD diagnosis, and 3) information from state-funded ASD agencies. Children identified as positive through the linking were then invited for diagnostic assessments by the research team.

In total, 60/5,385 children (1.11% of population) with ASD were identified, with 56 of these 5,385 children (1.03% of population) having positive screens on at least one ITC (93% sensitivity) during the first years of life. Some ITCs were positive prior to 12 months. However, in other cases, initial screens between 9 and 11 months were negative and did not become positive until later. Some families declined evaluation until two or more screenings were failed. Parental concerns were also tracked independent of ITC status over time. Most parents of children with ASD identified concerns by 24 months of age. The sensitivity of the ITC was above 90 percent at 12 to 14 months through 21 to 41 months, while the proportion of parents indicating concern was less than half under 15 months, increasing to about three fourths at 21 to 24 months.

As reviewed above in the section on the M-CHAT, an additional fair-quality study (Miller 2011) screened toddlers ages 14 to 30 months with either the ITC, M-CHAT, or both.63 The authors did not clearly present the properties of the ITC beyond their combined discussion of performance of the total screening protocol, leaving no information on the PPV of the ITC in isolation.

#### First Year Inventory

##### Key Summary Points

- Two-fair quality studies conducted in the United States and in Israel assessed the First Year Inventory (FYI) and included a total of 611 children screened at 12 months of age.
- Attrition between identification of high risk and diagnostic assessment was over 80 percent.
- No valid performance characteristics are available for this screener.

##### Description of Measure

The FYI is a 63-item parent-report questionnaire designed to assess ASD risk in 12-month-old children. It consists of social-communication and sensory-regulatory domains that sum to form a total risk score.

##### Detailed Analysis of Primary Care Studies

A fair-quality study conducted in the United States79 examined the use of the FYI in a community sample of 1,305 12-month-old children (Turner-Brown 2014) whose parents completed a mailed copy of the FYI. Over 1,000 (n=1,192) of these families agreed to participate in future research and were recontacted within 6 months following their child's third birthday. Of these, 699 families responded and completed a mailed packet including the Social Responsiveness Scale-Preschool (SRS-P) and Developmental Concerns Questionnaire (DCQ). Of these 699 responders, researchers invited back any responding family whose child was deemed at risk based on one of four criteria: 12-month FYI scores above the 90th percentile, SRS-P at or above a total score of 60, ASD-related concerns noted on the DCQ, or mild collective concerns noted across measures. Although 153 children met these criteria, only 28/153 (18%) completed diagnostic evaluations; we do not provide performance characteristics due to the extremely high attrition (82%).

Another fair-quality pilot study conducted in Israel examined the use of a 24-item version of the FYI, the FYI-Lite (FYI-L-Hebrew), to determine ASD risk in a sample of 583 children at 12-month well-child visits (Ben-Sasson 2013).58 Fifteen of the 583 (3%) children screened positive using a cutoff score of 0.42 (the U.S. 98th percentile cutoff and Israeli 95th percentile cutoff). Three of them (20%) did not complete followup evaluations. Of the remaining 12, 10 (two refused) completed research evaluations consisting of the Mullen Scales and Autism Observation Scale for Infants. Six of these 10 (60%) were referred due to developmental concerns, and one of the 10 (10%) was determined to be at ASD risk. A control group of 12 children also completed evaluations. Researchers then reviewed the medical records of those at-risk children who reached age 24 months during the course of the study. Five of the original 15 screen-positive children had medical record information available. Three of these five were noted to have social-communication concerns in the record. In addition to the group who received research evaluations, medical records were reviewed for a subset of children who screened negative on the FYI-L (n=148). Seven of those 148 (5%) had documented social-communication delays in the medical record.

#### Early Screening of Autistic Traits Questionnaire

##### Key Summary Points

- Use of two-stage Early Screening of Autistic Traits Questionnaire (ESAT) screening at 14 to 15 months of age identified only a small number of children with ASD in a large population sample (n=31,724) in one fair-quality study conducted in the Netherlands.
- Targeted clinical surveillance and concern identified more children (n=39) with ASD than use of the ESAT (n=18).
- The instrument has not been studied extensively in primarily English-speaking populations, although many translations of the instrument are available.

##### Description of Measure

The ESAT tool is a 14-item screening instrument and procedure designed to help identify ASD between 14 and15 months of age in combination with specific developmental surveillance. Children are prescreened with a four-item version of the ESAT at well-child visits; subsequently, for children screening positive on the four-item measure, a 14-item version of the questionnaire is completed by a home behavioral professional with parental input. Items on both instruments refer to key areas of social development and play behavior.

##### Detailed Analysis of Primary Care Studies

One fair-quality study conducted in the Netherlands followed the two-step screening process (Dietz 2006).65, 66 Screen 1 used a four-item version of the ESAT (available in English, Arabic, and Turkish) to screen a random population sample of 31,724 children in well-baby clinics at ages 14 to 15 months. Children screened positive if their providers in collaboration with parents endorsed one of four items. Of the 31,724 children, 370 (1%) screened positive on the four-item ESAT, of whom 255/370 (69%) completed Screen 2 at approximately 16 months of age. An additional 109 children were identified based on clinician concern. Screen 2 used the 14-item ESAT and was conducted in the home by a psychologist. One hundred children screened positive at Screen 2 by failing at least three items. Of these, 73 children completed a more comprehensive diagnostic assessment by the study team, including a child psychiatrist. Eighteen of 73 children (25%) were identified with ASD as a result of this process, with 55/73 (75%) receiving other diagnoses (13 intellectual disability, 18 language delay, and 25 other behavioral diagnoses). The proportion of children identified as having ASD was substantially lower (0.57 per 1,000) than the known population prevalence, even with high followup (61%). More children with ASD were identified via clinician concern (n=39) than with the ESAT.

#### Social Attention and Communication Study

##### Key Summary Points

- One fair-quality Australian study including 20,770 children screened between 8 and 24 months of age assessed the Social Attention and Communication Study (SACS).
- The prevalence of children identified with the SACS is 0.43 percent. No information is available regarding false negatives.
- The instrument required specialized training of providers in use of the key observational checklists.

##### Description of Measure

The SACS measure is an observational tool designed to be completed by maternal and child health nurses conducting well-visits with infants and toddlers. Specifically, nurses complete observational ratings of children on a variety of social and communication developmental milestones at 8-, 12-, 18-, and 24-month well-child visits. Children failing specific combinations of critical items at these specified time points are identified as at risk for ASD from 12 months onward.

##### Detailed Analysis of Primary Care Studies

This fair-quality, population-based (20,770 children) study included children attending their well-child visits at maternal and child health centers within a 20-km radius of Melbourne University in Victoria, Australia (Barbaro 2011).73, 74 Maternal and child health nurses, who had been trained to administer and score the measure, screened the children. The nurses were trained to look for a pattern of key items associated with ASD at the different age points (8, 12, 18, or 24 months). If children failed a series of these items they were referred for further evaluation. Of the 20,770 children, 216 (1.04%) were referred for a comprehensive developmental assessment (i.e., screened positive on the assessment), and 110/216 children (51%) completed diagnostic followup. Of these 110 children, 89 (81%) were classified with ASD, with 20 (18%) children receiving diagnoses of developmental delay or language disorder.

#### Young Autism and Other Developmental Disorders Check-up Tool

##### Key Summary Points

- One fair-quality study conducted in Japan and including 2,814 toddlers screened at 18 months of age assessed the Young Autism and Other Developmental Disorders Checkup Tool (YACHT).
- Screening with elements of the YACHT as early as 18 months of age identified some cases of ASD within community samples of Japanese children.
- Little information is available about screen negatives.
- The proportion of children identified with elements of the YACHT is 0.39 percent.

##### Description of Measure

The YACHT consists of a developmental questionnaire (i.e., motor functioning, communication, social interaction), a caregiver interview regarding pointing and language comprehension, and a specific examination of children asking them to point to identified picture cards.

##### Detailed Analysis of Primary Care Studies

A fair-quality study conducted in Yokohoma, Japan used a children's health surveillance program to attempt to increase the efficacy of early detection (Honda 2009).72 Public health nurses screened children at their routine 18-month checkup using the YACHT-18 in two stages. Children who screened positive on the YACHT-18 received a followup with a telephone call or home visit as well as individual psychological consultations and a weekly group program for mothers and children. Those needing specialized assessment were seen at a clinic and evaluated by a developmental psychiatrist, a clinical psychologist, and a social worker along with public health nurses. Those with strong suspicion of a developmental disorder were referred to the Yokohama rehabilitation outpatient clinic for diagnostic evaluation (methodology not explained). Those screening negative or children not taking part in the 18-month checkup were assessed again at the 3-year checkup/screening. Those screening positive at the 3-year checkup along with those referred based on community concern (i.e., from kindergartens, nursery schools, other medical clinics, and child guidance clinics) received diagnostic evaluations.

Of 2,814 toddlers screened, 402 screened positive and 2,412 screened negative for any developmental disorder at 18 months. Among those screening positive and followed up (number not provided), 19 (7%) were referred for diagnosis (mean age, 2 years 11 months). Four children who screened negative were also referred later (mean age, 4 years 4 months), two because of parental concern and two who screened positive at the 3-year checkup. Of the 23 cases screening positive or referred for followup, 14/23 (61%) were diagnosed with ASD (five with autistic disorder and nine with PDD-NOS). YACHT-18 correctly identified 11/14 cases (79%) of ASD. YACHT-18 missed three actual cases of ASD (22%), including two children with autistic disorder and one with PDD-NOS. One child with language disorder, five with attention deficit hyperactivity disorder, and two with intellectual disability received false-positive scores on the YACHT-18. Among those identified by YACHT-18 to be at risk for ASD, 58 percent were actually confirmed by diagnostic evaluation. Of note, the study did not clearly define criteria for screening positive and did not follow the same age criteria for diagnostic evaluation.

Tables 3 and 4 summarize performance characteristics for all studies, and Table 5 summarizes findings from larger studies with correction for attrition.

Table 3 Performance Characteristics of Screeners in Primary Care/Unselected Samples Without Accounting for Attrition

Study, Country, Quality Age Range | Instrument (Cut Point for Positive Screen) | Step 1: Total Screen Positive/Total Screened LFU from Step 1 to Step 2, n (%) | Step 2: Total Screen Positive/Total Screened LFU from Screening to Diagnosis, n (%) | Diagnostic Workup: Total diagnosed with ASD via the Screening Tool/Total evaluated | % Identified With ASD via Screening Rate Identified with ASD per 1000 | Study PPV (%) | Other Available data
Baird 2000^75^ UK Good Age: 18.7 ± 1.1 months | CHAT (NR) | 407/16235 347 (85.3) | 34/60 0 | 20/34 | 0.12% 2 per 1000 | 58.8 | Se: 35.1 Sp: 97.7 PPV for any developmental issue: 18.9%:
VanDenHeuvel 2007^64^ Ireland Poor Age: 18-20 months | CHAT+followup CHAT for participants at risk on first screen (NR) | 29/2117 10 (34.5) | 7/19 0 | 7 /12 | 0.33% 3 per 1000 | 58.3 | PPV for any developmental issue: 75%
Robins 2014^61^ US Good Age: 16-30 months | M-CHAT-R/F (≥2) | 1155/16115 209/1155 | 348/946 156/946 (16.5) | 105/221 | 0.65% 6.5 per 1000 | 48 | PPV for any developmental issue: 95%
Chlebowski 2013^101^ US Good Age: 20 months | M-CHAT+ followup interview (3/23 items failed or 2/6 critical items) | 1737/18989 442 /1737 (25.4) | 272/1295 107/272 (39.3) | 98/207 | 0.48% 5 per 1000 | 54 | PPV for any developmental issue: 97.5%
Kamio 2014^59^ Japan Fair Age: 17-26 months | M-CHAT+ Followup-Japanese (3/23 items failed or 1 or 2 critical items) | 319/1851 124/319 (38.9) | 44/195 0 | 42/1727 | 1.08% 11 per 1000 | 45.5 | PPV for any developmental issue: 54.5%
Nygren 2012^62^ Sweden Fair Age: 2.5 years | M-CHAT+ Followup interview (3/23 items failed or 2/6 critical items) | 36/3999 NR | - | 33 /49 | 0.83% 8 per 1000 | 91.7 | Se: 76.7%
Canal-Bedia 2011^78^ Stage 1 Spain Fair Age: 18-24 months | M-CHAT (Spanish)+ Followup interview (3/23 items failed or 2/6 critical items) | 429/2480 NA | - 343/429 (80) | 23/86 | 0.93% 9 per 1000 | 26.7 | PPV for any developmental issue: 50%
Canal-Bedia 2011^78^ Stage 2 Spain Fair Age: 18-24 months | M-CHAT (Spanish)+ Followup interview (3/23 items failed or 2/6 critical items) | 336/2055 NA | - 305/336 (90.8) | 6/31 | 0.29% 2.9 per 1000 | 19 | NR
Inada 2011^77^ Japan Fair-Poor Age: 4-26 months | M-CHAT-J—Full (2 of any 23 items failed) | NR/1187 | NR | NR | 1.68% 17 per 1000 | 10.7 (data to re-calculate not provided) | Predicted: PPV:10.7 Se: 75 Sp:89 NPV:99.5
Pierce 2011^39^ US Good Age: 10.1-15.9 months | CSBS-ITC (10^th^ percentile) | 1318/10479 NA | - 1134/1318 (86) | 32/184 | 0.31% 3 per 1000 | 17.4 | PPV for any developmental issue: 72.3%
Wetherby 2008^76^ US Good Age: 6-24 months | ITC (bottom 10^th^ percentile on social or symbolic composite or total score or bottom 10^th^ percentile on 2 consecutive speech composite) | 482/5385 NA | - 422/482 (87.6) | 56/60 | 1.04% 10 per 1000 | NR | NR
Miller 2011^63^ US Fair Age: 14-32 months | ITC (bottom 10th percentile) or M-CHAT+ Followup Interview (3/23 items failed or 2/6 critical items) | 47/796 0 | - | 13 /27 | 1.38% 14 per 1000 | 32 | PPV for any developmental issue: 96.4%
Ben-Sasson 2013^58^ Israel Fair Age: 11-13 months | FYI (total score 0.42) | 15/583 | NA | NR | NR | 60 (social commuication delay) | NR
Turner-Brown 2014^79^ US Fair Age: 12 months | FYI (≥90^th^ percentile) | 64/1305 NR | - 46/64 (71.9) | 4/699 | 0.31% 3 per 1000 | NR | NR
Dietz 2007^65, 66^ Netherlands, Fair Age: 14-15 months | ESAT- 4 item (≥3 items failed) | 370/31724 115/370 (31) | 100/255 34/100 (34) | 19/66 | 0.06% 0.6 per 1000 | 29 | NR
Barbaro 2011^73, 74^ Australia Fair Age: 8-24 months | SACS (3 of 4-5 items failed) | 216/20770 NR | - 106/216 (49.1) | 89/110 | 0.43% 4.3 per 1000 | 81 (24 months) | PPV for any developmental issue: 99%
Honda 2009^72^ Japan Fair Age: 18 months | YACHT-18 (NR) | 402/2814 NR | - 379/402 (94.3) | 14/23 | 0.39% 3.9 per 1000 | 58 | NR

ASD=autism spectrum disorder; CHAT=Checklist for Autism in Toddlers; ESAT=Early Screen for Autistic Traits; ITC=Infant Toddler Checklist; JA-OBS=Joint Attention Observation Schedule; LFU=loss to followup; M-CHAT=Modified Checklist for Autism in Toddlers; PPV=positive predictive value; SACS=Social Attention and Communication Study; Se=sensitivity; Sp=specificity; YACHT=Young Autism and other developmental disorders Check-up Tool.

Table 4 PPV of Screeners in Primary Care/Unselected Samples Without Accounting for Attrition

Study, Country, Quality Age Range | Instrument (Cut Point for Positive Screen) Time to Administer | Number Screening Positive at Step 1/Total Number Screened at Step 1 (%) | Number Screening Positive at Step 2/Total Number Screened at Step 2 (%) | PPV for ASD, % | N False Positive | N (%) Diagnosed with ASD | Rate of ASD
Robins 2014^61^ US Good 16-30 months | M-CHAT-R/F (≥2) 5 minutes | 1155/16115 (7.2) | 348/946 (37) | 48 | 116 | 123 (46.8) | 6.5 per 1000
Chlebowski 2013^101^ US Good Mean=20 months | M-CHAT+followup interview (3/23 items failed or 2/6 critical items) 5-10 minutes | 1737/18989 (9.1) | 272/1295 (21) | 54 | 79 | 98 (47.3) | 5 per 1000
Kamio 2014^59^ Japan Fair 17-26 months | M-CHAT-Japanese (3/23 items failed or 1 or 2/critical items) 5-10 minutes | 319/1851 (17.2) | 44/195 (22.6) | 45.5 | 24 | 42 (2.43) | 11 per 1000
Nygren 2012^62^ Sweden Fair 2.5 years | M-CHAT+Followup interview (3/23 items failed or 2/6 critical items) 5-10 minutes | 36/3999 (0.9) | NA | 91.7 | 3 | 33 (67.3) | 8 per 1000
Canal-Bedia 2011^78^ Stage 1 Spain Fair 18-24 months | M-CHAT (Spanish)+ Followup interview (3/23 items failed or 2/6 critical items) 5-10 minutes | 429/2480 (17.2) | NA | 26.7 | 63 | 23 (26.7) | 9 per 1000
Canal-Bedia 2011^78^ Stage 2 Spain Fair 18-24 months | M-CHAT (Spanish)+ Followup interview (3/23 items failed or 2/6 critical items) 5-10 minutes | 336/2055 (16.4) | NA | 19 | 25 | 6 (19.4) | 2.9 per 1000
Inada 2011^77^ Japan Fair-Poor 4-26 months | M-CHAT-J—Full (2 of any 23 items failed) 5-10 minutes | NR/1187 | NR | 10.7^*^ | 125^*^ | 20 (1.69)^*^ | 17 per 1000
Pierce 2011^39^ US Good 10.1-15.9 months | CSBS-ITC (10^th^ percentile) 5-10 minutes | 1318/10479 (12.6) | NA | 17.4 | 152 | 32 (17.4) | 3 per 1000
Wetherby 2008^76^ US Good 6-24 months | ITC (bottom 10^th^ percentile on social or symbolic composite or total score or bottom 10^th^ percentile on 2 consecutive speech composite) 5-10 minutes | 482/5385 (9) | NA | NR | NR | 56 (93.3) | 10 per 1000
Miller 2011^63^ US Fair 14-32 months | ITC (bottom 10th percentile) or M-CHAT+ Followup Interview (3/23 items failed or 2/6 critical items) 5-10 minutes | 47/796 (5.9) | NA | 32 | 17 | 13 (43.3) | 14 per 1000

* Predicted.

ASD=autism spectrum disorder; CHAT=Checklist for Autism in Toddlers; ITC=Infant Toddler Checklist; M-CHAT=Modified Checklist for Autism in Toddlers; PPV=positive predictive value.

Table 5 Performance Characteristics of Screeners in Large Primary Care/Unselected Samples (>15,000 Participants) Correcting for Attrition and Other Developmental Concerns Warranting Further Evaluation for Early Intervention

Study, Country, Quality | Instrument (Cut Point for Positive Screen) | Total Screen Positive/Total Screened | Diagnosed With ASD/Total Evaluated | % Identified With ASD Correcting for Attrition | Imputed Rate of ASD Correcting for Attrition
Chlebowski 2013^101^ US Good | M-CHAT+followup interview (3/23 items failed or 2/6 critical items) | 272/18989 | 92/171 | 1.01 | 1 in 98
Robins, 2014^61^ US Good | M-CHAT-R/F (≥2) | 348/16115 | 105/221 | .92 | 1 in 109

ASD=autism spectrum disorder; M-CHAT=Modified Checklist for Autism in Toddlers.

### KQ 2a Do Certain Risk Factors Modify the Performance Characteristics of ASD Screening Tests?

We did not identify any studies that took place in primary care settings that assessed the effect of risk factors, such as prematurity or sibling status, on performance characteristics of ASD screening tests.

### KQ 2b Does the Age at Which ASD Screening Is Performed Modify the Performance Characteristics of ASD Screening Tests?

The above reviewed studies of primary care screening did not systematically examine the performance characteristics of early screening tools for children at different ages. However, one study,70 including a subsample of high- and low-risk children also reported in other M-CHAT studies,101 attempted to examine screening characteristics of the M-CHAT at different ages but all within the very young age group of younger than 30 months. The researchers examined outcomes for low-risk children between 17 and 23 months of age (n=4,265; mean age, 18.57 months) and at 24 to 30 months of age (n=1,785; mean age, 24.74 months). PPV for children at older ages (0.61) was better than the younger group (0.28). Because this study had already excluded children who had previously been identified as being of concern for developmental delays, the performance characteristics are likely not reflective of what might be seen in the complete population. It also provides no data on screening children at preschool ages versus older ages. Data on false-negative results were unavailable.

### KQ 2c Do Other Characteristics of the Child or Family Modify the Performance Characteristics of ASD Screening Tests?

No studies were available to assess whether characteristics of the child and family modify performance characteristics of screening tests.

### KQ 3 What Are the Harms of ASD Screening for the Child and Family?

No studies assessed or addressed harms of screening.

### KQ 4 What Is the Effect of Interventions Targeting Young Children on the Following Outcomes: Core ASD Symptoms, Cognitive and Intellectual Functioning, Language and Communication Skill Development, Challenging Behavior, Adaptive Behavior, Educational Placement/Achievement, and Quality of Life for the Child and Family?

Treatments for young children in the target age group for routine screening for ASD are primarily behavioral interventions, particularly early intensive behavioral and developmental interventions, which may include approaches incorporating ABA principles and/or approaches incorporating parent training components, and play/interaction-based interventions. Table 6 outlines key cognitive and language outcome measures, and we present the results of early intervention studies below and in Tables 7–14 and summarize them in the discussion. Because the most evidence is available for the effects of ABA-based interventions on cognitive and language outcomes, we describe these in most detail below. Data on other outcomes are available in tables in Appendix F. Finally, we very briefly summarize play-based therapies, which have a substantially weaker body of evidence.

Table 6 Summary of Cognitive and Language Outcome Measures Frequently Used in Intervention Studies Included in the Review

Measure | Description/Purpose | Age Range for Administration | Total Score Range | Range for Abnormal Scores
British Ability Scales | Multi-scale tool to assess cognitive ability and educational achievement; includes vocabulary, pattern, reading, and recall tests | 2.5 or 3 years to 17 years 11 months | | High scores indicate more abilities
Bayley Scales of Infant Development | Describes the current developmental functioning of infants and to assist in diagnosis and treatment planning for infants with developmental delays or disabilities. The test is intended to measure a child's level of development in three domains: cognitive, motor, and behavioral. | From 1 to 42 months of age | Mean=10, SD=3 (range from 1-19) Mean=100, SD=15 (range from 40-160) | Average: 90-109 Low Average: 89-89 Borderline: 70-79 Extremely Low: < 69
Differential Abilities Scale | In-depth analysis of children's learning abilities. General Conceptual Ability (GCA)—summarizes developmentally appropriate ability domains Special Nonverbal Composite (SNC)—summarizes the nonverbal domains (the SNC is particularly valuable when testing children who are not proficient in spoken English) | Lower Preschool (ages 2 years, 6 months through 3 years, 5 months), Upper Preschool (aged 3 years, 6 months through 5 years, 11 months), and School-Age (6 years, 0 months through 17 years, 11 months) | Standard scores with mean of 100 (50^th^ percentile) and SD of 15. | Higher scores indicate more abilities Average range: 85-115
Developmental Assessment of Young Children | The five subtests relate to the areas of development that are evaluated for early intervention eligibility and children's developmental performance (Cognition, Communication, Social-Emotional, Physical Development, Adaptive Behavior) | Birth through 5 years and 11 months of age | 0-1 (0=skill not observed; 1=skill was observed) Add up the 1's to calculate the raw score. Then convert raw score to standard score based on age group | Higher scores indicate more skills shown
Early Social Communication Scales | Structured assessment designed to provide measures of individual differences in nonverbal communication skills in children with mental ages between 8 and 30 months of age; | 8 months to 30 months | Codes frequency of social-communication behaviors based on developmental stage, communicative goal, and whether they were child-initiated. | Higher scores indicate more skills shown Frequency counts are compared to means from a small standardization sample based upon the category, with values varying by subscale
Gilliam Autism Rating Scale | Identifying autism in individuals and estimating its severity; six subscales: Restrictive/Repetitive Behaviors, Social Interaction, Social Communication, Emotional Responses, Cognitive Style, and Maladaptive Speech | 3 to 22 years | Cutoff scores based on standardization sample | > 85: Likely ASD 70-85: Possible ASD < 70: Unlikely ASD Higher scores indicate more impairment
Griffiths Mental Development Scales | Measure the rate of development of young children related to motor, social, and reasoning skills. | 2 to 8 years | Ratio transformation: divide mental age by chronological age, which yields different means and standard deviations for each subscale. Means tend to be around 100 and SDs tend to be around 16, but this is variable depending on the scale and the participant's age | Higher scores indicate more abilities
MacArthur-Bates Communicative Development Inventories | Evaluate the communicative skills of young typically developing children from their “early signs of comprehension, to their first nonverbal gestural signals, to the expansion of early vocabulary and the beginnings of grammar”; Pt 1. Early words and Pt 2. Actions and gestures | 8 to 18 months | Total words and gestures used are compared to maximum values within each domain and percentile ranks are calculated. | Percentile ranks are used to calculate deviation from the norm, with >2 SDs from the mean typically considered significantly impaired Higher scores indicate more abilities
Merrill-Palmer Scale of Mental Tests | Intelligence test that primarily assesses nonverbal skills. The scale evaluates both the content of thinking (that is, the material that is actually processed by the child) and the process of thinking (that is, the way in which this material is used to form new concepts). | 18 months to four years | Mental age | Average: 85-115 Below Average: 70-84 Low: < 70 Higher scores indicate more abilities
Mullen Scales of Early Learning | Assesses early intellectual development and school readiness, permitting targeted intervention at a young age - Five scales: Gross Motor, Visual Reception, Fine Motor, Expressive Language, and Receptive Language. | Birth to 5 years, 8 months | Standard scores with mean of 100 (50^th^ percentile) and SD of 15. | Higher scores indicate more abilities Average range: 85-115
Psychoeducational Profile | Assesses skills and behaviors of children with autism and communication disabilities, identifying learning strengths, uneven development, emerging abilities, and other information useful in educational programming - Communication, Motor, and Maladaptive Behaviors | 6 months through 7 years | Yields a total developmental score but inconsistently correlates with other IQ measures. All items within each subscale are summed to provide subscale and overall total scores. | Higher scores indicate more abilities
Preschool Language Scale | Interactive assessment of developmental language skills. Total language, auditory comprehension, expressive communication standard scores, growth scores, percentile ranks, language age equivalents | Birth to 7 years, 11 months | Standard scores with mean of 100 (50^th^ percentile) and SD of 15. | Higher scores indicate more abilities Average range: 85-115
Peabody Picture Vocabulary Test | A measure of receptive vocabulary for Standard American English; verbal ability and scholastic aptitude | 4-5 and 10-11 years of age | Standard scores with mean of 100 (50^th^ percentile) and SD of 15. | Higher scores indicate more abilities Average range: 85-115
Reynell Developmental Language Scale | Standardized measure of language development. The Verbal Comprehension Scale measures language understanding of nouns, verbs, and prepositions and following of simple directions and more complex directions. The Verbal Comprehension Scale also provides information on early developing inferencing skills. The Expressive language Scale measures spoken language in the areas of syntax, vocabulary, and content. | 1-6 years | | Higher scores indicate more abilities
Wechsler Intelligence Scale for Children-Revised, WISC-III, or WISC-IV | A general test of intelligence; defined as “the global capacity of the individual to act purposefully, to think rationally, and to deal effectively with his environment.” Full Scale IQ, Verbal IQ and Performance IQ | 6 to 16 years 11 months | Mean = 100, SD = 15 Standard score of 100 = 50^th^ percentile rank | Higher scores indicate more abilities ≥130: Very Superior 120-129: Superior 110-119: High Average 90-109: Average 80-89: Low Average 70-79: Borderline ≤69: Extremely Low
Wechsler Preschool and Primary Scale of Intelligence, Revised | Intelligence test; The Verbal Scale measures language expression, comprehension, listening, and the ability to apply these skills to solving problems. The examiner gives the questions orally, and the child gives a spoken response. The Performance Scale assesses nonverbal problem solving, perceptual organization, speed, and visual-motor proficiency. Included are tasks like puzzles, analysis of pictures, imitating designs with blocks, and copying. | 2 years, 6 months to 7 years, 3 months | Same as WISC | Same as WISC

Table 7 Overview of Intervention Studies Reporting Cognitive Outcomes

Intervention Approach | N Studies Reporting Cognitive Outcomes | Intervention > Control, n studies | No Significant Between Group Differences, n studies
Direct to Child
UCLA/Lovaas | 8 | 4 | 4
ESDM | 1 | 1 | 0
LEAP | 1 | 1 | 0
Preschool-delivered models | 5 | 4 | 1
Parent Training
Parent-delivered ESDM | 1 | 0 | 1
AEPS | 1 | 0 | 1
Clinic and/or home-based | 2 | 1 | 1
Parent training in communication responsiveness | 1 | 0 | 1
TOTAL | 20 | 11 | 9

Intervention > Control=outcomes were significantly improved in the intervention vs. comparison arm.

Table 8 Overview of Intervention Studies Reporting Language Outcomes

Intervention Approach | N Reporting Language Outcomes | Intervention > Control, n studies | No Significant Between Group Differences, n studies
Direct to Child
UCLA/Lovaas | 7 | 3 | 4
ESDM | 1 | 1 | 0
LEAP | 2 | 1 | 1
Preschool-delivered models | 6 | 5 | 1
Parent Training
Parent-delivered ESDM | 1 | 0 | 1
AEPS | 1 | 0 | 1
Clinic and/or home-based | 2 | 2 | 0
Parent training in communication responsiveness | 5 | 1 | 4
DIR/Floortime | 1 | 0 | 1
More than Words | 1 | 0 | 1
Pivotal Response Training | 1 | 0 | 1
TOTAL | 28 | 13 | 15

Intervention > Control=outcomes were significantly improved in the intervention vs. comparison arm.

Table 9 Overview of Intervention Studies Reporting Joint Attention Outcomes

Intervention Approach | N Reporting Joint Attention Outcomes | Intervention > Control, n studies | No Significant Between Group Differences, n studies
Play/interaction based | 10 | 9 | 1

Intervention > Control=outcomes were significantly improved in the intervention vs. comparison arm.

Table 10 Summary of Cognitive Outcomes in Direct Provision to Child Early Intervention Studies (k=15)

Author, Year, Country Groups, N Enrollment/N Final | Age at Intake Mean, months±SD | Measure | Baseline Score, Mean±SD | Followup Score, Mean±SD | Analytic Data
RCTs
Strain et al, 2011^112^ US IG: LEAP program with coaching and training, 28 classrooms (27 analyzed)/177 children CG: LEAP intervention manuals only, 28 classrooms (23 analyzed)/117 children Quality: Fair | IG: 50.1 ± 4.6 CG: 50.7 ± 4.2 | MSEL, composite | IG: 59.6±6.9 CG: 63.2±6.6 | IG: 68.6±7.5 CG: 61.4±9.0 | IG change: 0.89 CG change: -1.8 Intervention group had MSEL-Early Learning Composite scores significantly higher than controls at 2 years, with an effect size of 0.89, range: 0.59 to 1.22, p<0.01
Dawson et al, 2012^103, 104^ US IG: ESDM, 24/24 CG: Eclectic community-based interventions, 24/21 Quality: Good | IG: 23.9 ± 4.0 CG: 23.1 ± 3.9 | MSEL, composite | IG: 61 ± 9.2 CG: 59.4 ± 8.6 | IG: 78.6 ± 24.2 CG: 66.3 ±15.3 | At 2 years, MSEL composite increased by 17.6 in the treated group versus 7.0 in the comparator Group × Time (baseline vs. 2 year): F=4.31, p=0.044
Sallows et al, 2005^122^ US IG: Clinic directed UCLA/Lovaas-based early intensive intervention, 13/13 CG: Parent-directed UCLA/Lovaas-based early intensive intervention, 10/10 Quality: Good | IG: 33.23 ± 3.89 CG: 34.20 ± 5.06 | BSID, MPSMT Full IQ | IG: 50.85 ± 10.57 CG: 52.10 ± 8.98 | IG: 73.08 ± 33.08 CG: 79.60 ± 21.80 | No significant differences between groups at pre- or posttest
Sallows et al, 2005^122^ US IG: Clinic directed UCLA/Lovaas-based early intensive intervention, 13/13 CG: Parent-directed UCLA/Lovaas-based early intensive intervention, 10/10 Quality: Good | IG: 33.23 ± 3.89 CG: 34.20 ± 5.06 | Non-Verbal IQ | IG: 70.58 ± 16.54 CG: 82.67 ± 14.94 | IG: 77.58 ± 25.24 CG: 89.44 ± 18.35 | No significant differences between groups at pre- or posttest
Smith et al, 2000^120^ US IG: UCLA/Lovaas-based intervention, 15/15 CG: Parent training from Lovaas manual, 13/13 Quality: Fair | IG: 36.07 ± 6.00 CG: 35.77 ± 5.77 | Stanford Binet-IQ | IG: 50.53 ± 11.18 CG: 50.69 ± 13.88 | IG: 66.49 ± 24.08 CG: 49.67 ± 19.74 | Increase in IQ in IG significantly greater than comparison group; using pooled variance t tests, for group differences, P<0.05
Smith et al, 2000^120^ US IG: UCLA/Lovaas-based intervention, 15/15 CG: Parent training from Lovaas manual, 13/13 Quality: Fair | IG: 36.07 ± 6.00 CG: 35.77 ± 5.77 | PSMT | IG: 21.60 ± 4.49 CG: 21.92 ± 5.5 | IG: 64.33 ± 18.74 CG: 49.17± 21.43 | Increase in IQ in IG significantly greater than comparison group; using pooled variance t tests, for group differences, P<0.05
Nonrandomized trials
Peters-Scheffer et al, 2013^121^ Netherlands IG: Low intensity Lovaas-based intervention + specialized preschool, 20/20 CG: Specialized preschool, 20/20 Quality: Good | IG+CG: 62.52 ± 16.96 | MSEL | IG: 23.34 (7.32) CG: 23.43 (6.34) | At 24 months: IG: 39.70 (11.99) CG: 32.44 (11.55) | Significantly greater effects in IG compared to preschool in developmental age (d=1.09, p=0.001) and IQ (d=0.40, p<0.001)
Peters-Scheffer et al, 2013^121^ Netherlands IG: Low intensity Lovaas-based intervention + specialized preschool, 20/20 CG: Specialized preschool, 20/20 Quality: Good | IG+CG: 62.52 ± 16.96 | Developmental age, in months | IG: 40.66 (20.07) CG: 40.14 (18.27) | IG: 48.12 (19.71) CG: 39.42 (19.89) | Significantly greater effects in IG compared to preschool in developmental age (d=1.09, p=0.001) and IQ (d=0.40, p<0.001)
Peters-Scheffer et al, 2010^114^ Netherlands IG: Specialized preschool + UCLA/Lovaas-based intervention, 12/12 CG: Eclectic preschool, 22/22 Quality: Fair | IG: 53.5 ± 5.52 CG: 52.95 ± 11.14 | WPPSI-R, BSID, Snijders-Oomen Nonverbal Intelligence Test–Revised | Developmental age in months IG: 25.92 ± 7.57 CG: 23.32 ± 6.33 | Developmental age in months IG: 34.83 ± 10.89 CG: 25.73 ± 8.26 | GLM repeated measures assessed group differences over time: Developmental Age: F(1,32)=23.37, Mental Development Index/IQ: F(1,32)= 26.96
Peters-Scheffer et al, 2010^114^ Netherlands IG: Specialized preschool + UCLA/Lovaas-based intervention, 12/12 CG: Eclectic preschool, 22/22 Quality: Fair | IG: 53.5 ± 5.52 CG: 52.95 ± 11.14 | WPPSI-R, BSID, Snijders-Oomen Nonverbal Intelligence Test–Revised | Mental developmental index/IQ IG: 47.00±10.33 CG: 45.73±15.99 | Mental developmental index/IQ IG: 55.83±14.94 CG: 43.73±16.74 | After baseline equivalence established, significantly greater improvement in IG vs. CG, p<0.01
Hayward et al, 2009^115, 116^ UK IG: Intensive clinic-based UCLA/Lovaas-based intervention, 23/20 CG: Intensive parent-managed treatment, 21/19 Quality: Fair | IG: 35.7 ± 6.2 CG: 34.4 ± 5.7 | BSID | IG: 53.5 ±15.1 CG: 54.1 ± 15.1 | IG: 70.9 ± 19.6 CG: 68.9 ±22.1 | Nonsignificant group differences both at intake and at followup (independent t-tests).
Hayward et al, 2009^115, 116^ UK IG: Intensive clinic-based UCLA/Lovaas-based intervention, 23/20 CG: Intensive parent-managed treatment, 21/19 Quality: Fair | IG: 35.7 ± 6.2 CG: 34.4 ± 5.7 | WPPSI–R | IG: 74.8 ± 22.6 CG: 76.2 ± 18.2 | IG: 89.4 ± 29.2 CG: 82.1± 28.0 | Nonsignificant group differences both at intake and at followup (independent t-tests).
Reed et al, 2007^123^ UK IG: High intensity intervention, 14/14 IGa: High intensity with focus on Lovaas techniques, 4/4 IGb: High intensity with focus on verbal behavior, 5/5 IGc: High intensity with focus on CABAS methods, 5/5 CG: Low intensity intervention in home-based direct teaching sessions, 13/13 Quality: Fair | IG: 42.9 (14.8) IGa: 47.5 (13.5) IGb: 38.0 (9.9) IGc: 44.2 (20.5) CG: 40.8 (5.6) | PEP-R | IG: 57.2 ± 17.8 IGa: 58.0 ± 30.7 IGb: 50.2 ± 7.7 IGc: 63.6 ± 12.4 CG: 49.3 ± 13.2 | Overall score, mean change (ES): IG: NR IGa: NR (0.91) IGb: NR (0.82) IGc: NR (1.11) CG: NR | Change scores for educational functioning were statistically higher in the high intensity arms compared to the low intensity arm t(25)=2.54, p <0.01 between groups
| IG: 42.9 (14.8) IGa: 47.5 (13.5) IGb: 38.0 (9.9) IGc: 44.2 (20.5) CG: 40.8 (5.6) | BAS, cognitive ability score | IG: 60.1 ± 22.4 IGa: 72.0 ± 30.6 IGb: 48.0 ± 4.6 IGc: 62.8 ± 23.9 CG: 52.4 ± 9.9 | BAS cognitive ability score, mean change (ES): IG: NR IGa: NR (0.58) IGb: NR (3.74) IGc: NR (3.74) CG: NR | Change scores for educational functioning were statistically higher in the high intensity arms compared to the low intensity arm t(25)=2.54, p <0.01 between groups
Eikeseth et al, 2002^117, 118^ Norway IG: UCLA/Lovaas-based intervention, 13/13 CG: Eclectic therapy, 12/12 Quality: Fair | IG: 66.31 ± 14.71 CG: 65 ± 10.95 | WPPSI-R, WISC-R, BSID, MPSMT | IQ: IG: 61.92 ± 11.31 CG: 65.17 ± 14.97 | IQ: IG: 79.08 ± 18.09 CG: 69.50 ± 18.38 | Change scores: IQ: IG: 17.15 ± 10.97 CG: 4.33 ± 7.55 p<0.01 1.5 years later, differences were maintained, with significantly greater improvement in IQ in the Lovaas group (25 points) compared to eclectic therapy (7 points), p<0.05 Performance IQ: IG: 17.46 ± 30.70 CG: 8.33 ± 16.12, p=ns
Eikeseth et al, 2002^117, 118^ Norway IG: UCLA/Lovaas-based intervention, 13/13 CG: Eclectic therapy, 12/12 Quality: Fair | IG: 66.31 ± 14.71 CG: 65 ± 10.95 | WPPSI-R, WISC-R, BSID, MPSMT | Performance IQ: IG: 77.54 ± 30.21 CG: 81.83 ± 21.05 | Performance IQ: IG: 95 ±16.91 CG: 90.17 ± 19.97
Cohort studies
Eldevik et al, 2012^107^ Norway IG: Preschool-based early intensive intervention, 31/31 CG: Eclectic preschool, 12/12 Quality: Fair | IG: 42.2 ± 9.0 CG: 46.2 ± 12.4 | BSID, Stanford-Binet, WPPSI-R | Intellectual functioning, mean ± SD (range) IG: 51.6 ± 16.9 (24-94) CG: 51.7 ± 18.1 (30-89) | Intellectual functioning, mean ± SD (range) IG: 66.6 ± 24.8 (23-110) CG: 52.2 ± 22.0 (23-86) | Mean change in intellectual functioning in treatment group was 15.1 (SD 14.9) compared to 0.5 (SD 9.5) in treatment as usual group
Flanagan et al, 2012^109, 141^ Canada IG: Intensive behavioral intervention, 61/61 CG: Eclectic interventions, 61/61 Quality: Fair | IG: 42.93 ± 11.53 CG: 42.79 ± 10.51 | MSEL, WPPSI, Stanford-Binet | IG: NR CG: NR | Mean ± SD: IG: 55.80±26.97 CG: 39.50±18.93 Marginal mean scores: IG: 55.71 CG: 36.46 | Higher cognitive scores in IG vs. CG at followup (19-point difference), p=0.003 Effect size=0.83
Itzchak et al, 2011^105, 106^ Israel IG: ABA-based approach, 45/45 CG: Eclectic approach, 33/33 Quality: Fair | IG: 25.1 ± 3.9 CG: 26.0 ± 4.6 | MSEL Verbal | IG+CG: 60.9 ± 24.4 | IG+CG: 75.0 ± 27 | MANOVA repeated measures over time: F=422.3, n=63, p<0.001, ES=0.406
Itzchak et al, 2011^105, 106^ Israel IG: ABA-based approach, 45/45 CG: Eclectic approach, 33/33 Quality: Fair | IG: 25.1 ± 3.9 CG: 26.0 ± 4.6 | Non-Verbal | IG+CG: 73.9 ± 23.7 | IG+CG: 75.5 ± 29.2 | No group difference in non-verbal scores F=0.1, ES=0.001 (n=63)
Zachor et al, 2007^110^ Israel IG: UCLA/Lovaas-based intervention, 53/53 CG: Eclectic approach, 15/15 Quality: Fair | IG: 25.1 ± 3.8 CG: 26.3 ± 4.6 | BSID, Stanford-Binet | IG: 76.1 ± 15.2 CG: 79.6 ± 17.0 | NR | After treatment, significant group difference in IQ favoring IG, ES=0.324, F(2,29)=6.96, p<0.01
Cohen et al, 2006^119^ US IG: UCLA/Lovaas-based intervention, 21/21 CG: Eclectic, 21/21 Quality: Fair | IG: 30.2 ± 5.8 CG: 33.2 ± 3.7 | BSID | IG: 61.6 ± 16.4 CG: 59.4 ± 14.7 | IG: 87 CG: 73 | Mean IQ increased 25 points in the treatment group and 14 points in the comparison group. The difference was significant in ANCOVA testing: F=5.21 <0.05
Cohen et al, 2006^119^ US IG: UCLA/Lovaas-based intervention, 21/21 CG: Eclectic, 21/21 Quality: Fair | IG: 30.2 ± 5.8 CG: 33.2 ± 3.7 | MPSMT | IG: 82.4 ± 17.3 CG: 73.4 ± 11.9 | Mean change: IG: 13 CG: 13 | No group difference, p=ns
Howard et al, 2005^111^ US IG: UCLA/Lovaas-based intervention, 37/29 CG1: Intensive eclectic therapy CG2: Nonintensive eclectic therapy CG2+CG3: 41/32 Quality: Fair | IG: 30.86 ± 5.16 CG1: 37.44 ± 5.68 CG2: 34.56 ± 6.53 | BSID, WPPSI-R, Stanford-Binet, DAS, DAYC, PEP-R, MPSMT | Standard Scores: Composite IG: 70.46 ± 11.85 CG1: 69.81 ± 10.48 CG2: 71.62 ± 10.47 | Composite Standard Scores, mean ±­ SD: IG: 81.32 ± 11.14 CG1: 69.25 ± 12.91 CG2: 68.25 ± 9.86 | Improvements in all cognitive outcomes were greater in the Lovaas group compared to comparators. All had p<0.01
Howard et al, 2005^111^ US IG: UCLA/Lovaas-based intervention, 37/29 CG1: Intensive eclectic therapy CG2: Nonintensive eclectic therapy CG2+CG3: 41/32 Quality: Fair | IG: 30.86 ± 5.16 CG1: 37.44 ± 5.68 CG2: 34.56 ± 6.53 | BSID, WPPSI-R, Stanford-Binet, DAS, DAYC, PEP-R, MPSMT | Cognitive IG: 58.84 ± 18.15 CG1: 53.69 ± 13.50 CG2: 59.88 ± 14.85 | Cognitive: IG: 89.88 ± 20.87 CG1: 62.13 ± 19.63 CG2: 68.81 ± 15.32 | Improvements in all cognitive outcomes were greater in the Lovaas group compared to comparators. All had p<0.01
Howard et al, 2005^111^ US IG: UCLA/Lovaas-based intervention, 37/29 CG1: Intensive eclectic therapy CG2: Nonintensive eclectic therapy CG2+CG3: 41/32 Quality: Fair | IG: 30.86 ± 5.16 CG1: 37.44 ± 5.68 CG2: 34.56 ± 6.53 | BSID, WPPSI-R, Stanford-Binet, DAS, DAYC, PEP-R, MPSMT | Non-verbal: IG: 80.14 ± 11.86 CG1: 67.44 ± 16.69 CG2: 77.69 ± 12.33 | Non-verbal: IG: 101.67 ±1 9.14 CG1: 73.56 ± 24.94 CG2: 82.53 ± 16.76 | Improvements in all cognitive outcomes were greater in the Lovaas group compared to comparators. All had p<0.01

ABA=applied behavior analysis; ACS=Autism Characteristics and Severity; ADOS=Autism Diagnostic Observation Schedule; BAS=British Abilities Scale; BSID= Bayley Scales of Infant Development; CABAS=Comprehensive Application of Behaviour Analysis; DAYC=Developmental Assessment of Young Children; DQ=developmental quotient; ESDM=Early Start Denver Model; IQ=Intelligence Quotient; LEAP=Learning Experiences and Alternative Program; MPSMT=Merrill-Palmer Scale of Mental Tests; MSEL=Mullen Scales of Early Learning; NR=not reported; PEP-R=Psychoeducational Profile-Revised; UCLA=University of California, Los Angeles; VABS=Vineland Adaptive Behavior Scale; WISC-R=Wechsler Intelligence Scale for Children-Revised; WPPSI-R=-Wechsler Preschool and Primary Scale of Intelligence, Revised.

Table 11 Summary of Language Outcomes in Direct Provision to Child Early Intervention Studies (k=16)

Author, Year, Country Groups, N Enrollment/N Final | Age at Intake Mean months±SD | Measure | Baseline Score, Mean±SD | Follow-Up Score, Mean±SD | Analytic Data
RCTs
Strain et al, 2011^112^ US IG: LEAP program with coaching and training, 28 classrooms (27 analyzed)/177 children CG: LEAP intervention manuals only, 28 classrooms (23 analyzed)/117 children Quality: Fair | IG: 50.1 ± 4.6 CG: 50.7 ± 4.2 | PLS-4, total language score | IG: 32.8 ± 7.5 CG: 34.4 ± 7.2 | IG: 51.3 ± 8.1 CG: 43.8 ± 7.7 | Significantly greater improvement in both receptive and expressive language in the intervention group compared to the comparison. PLS-4 language score mean group differences: ES=0.92, delta=9.4, p<0.01 MSEL receptive language: ES=0.89, delta=7.3, p<0.01 MSEL expressive language: ES=0.60, delta=5.6, p<0.05
| IG: 50.1 ± 4.6 CG: 50.7 ± 4.2 | MSEL, Receptive | IG: 30.8 ± 7.6 CG:33.4 ± 9.0 | IG: 49.3 ± 7.9 CG: 40.7 ± 7.7
| IG: 50.1 ± 4.6 CG: 50.7 ± 4.2 | MSEL expressive language | IG: 28.9 ± 7.4 CG: 30.3 ± 8.2 | IG: 38.7 ± 6.4 CG: 35.9 ± 4.4
Dawson et al, 2012^103, 104^ US IG: ESDM, 24/24 CG: Community-based interventions, 24/21 Quality: Good | IG: 23.9 ± 4.0 CG: 23.1 ± 3.9 | MSEL, composite | IG: 61.0 ± 9.2 CG: 58.4 ± 8.6 | IG: 78.6 ±24.2 CG: 66.3 ± 15.3 | After 2 years, the intervention group had significantly greater improvements in language than the comparison group. Composite score: F=4.31, MS=1264.38, p=0.044 Receptive language: F=4.14, MS=843.56, p=0.048 Expressive language: F=4.88, MS=748.07, p=0.033
Dawson et al, 2012^103, 104^ US IG: ESDM, 24/24 CG: Community-based interventions, 24/21 Quality: Good | IG: 23.9 ± 4.0 CG: 23.1 ± 3.9 | MSEL, receptive language | IG: 21.1 ± 4.7 CG: 21.2 ± 3.8 | IG: 40 ± 16.3 CG: 31.5 ± 10.6
Dawson et al, 2012^103, 104^ US IG: ESDM, 24/24 CG: Community-based interventions, 24/21 Quality: Good | IG: 23.9 ± 4.0 CG: 23.1 ± 3.9 | MSEL, expressive language | IG: 24.5 ± 7.2 CG: 26.0 ± 8.6 | IG: 36.6 ± 13.6 CG: 30.0 ± 9.2
Sallows et al, 2005^122^ IG: Clinic-directed UCLA/Lovaas-based early intensive intervention, 13/13 CG: Parent-directed UCLA/Lovaas-based early intensive intervention, 10/10 Quality: Good | IG: 33.23 ± 3.89 CG: 34.20 ± 5.06 | RDLS, CELF-III | Receptive language IG: 38.85 ± 6.09 CG: 38.78 ± 6.44 | IG: 55.85 ± 36.23 CG: 65.78 ± 25.81 | No significant differences between groups at pre- or post- test on either measure
Sallows et al, 2005^122^ IG: Clinic-directed UCLA/Lovaas-based early intensive intervention, 13/13 CG: Parent-directed UCLA/Lovaas-based early intensive intervention, 10/10 Quality: Good | IG: 33.23 ± 3.89 CG: 34.20 ± 5.06 | RDLS, CELF-III | Expressive language IG: 47.92 ± 6.17 CG: 48.44 ± 6.96 | IG: 53.38 ± 31.91 CG: 59.22 ± 25.13 | No significant differences between groups at pre- or post- test on either measure
Sallows et al, 2005^122^ IG: Clinic-directed UCLA/Lovaas-based early intensive intervention, 13/13 CG: Parent-directed UCLA/Lovaas-based early intensive intervention, 10/10 Quality: Good | IG: 33.23 ± 3.89 CG: 34.20 ± 5.06 | VABS-Communication | IG: 57.46 ± 4.97 CG: 63.20 ± 5.58 | IG: 73.69 ± 32.32 CG: 81.40 ± 24.33 | No significant differences between groups at pre- or post- test on either measure
Smith et al, 2000^120^ US IG: UCLA/Lovaas-based intervention, 15/15 CG: Parent training from Lovaas manual, 13/13 Quality: Fair | IG: 36.07 ± 6.00 CG: 35.77 ± 5.77 | RDLS, comprehension | IG: 13.47 ± 3.60 CG: 13.69 ± 3.73 | IG: 42.87 ± 22.29 CG: 33.0 ± 16.86 | Total scores on receptive and expressive language had significantly greater improvement in the intervention group compared to the parent training group (p<0.05) although subscales did not.
Smith et al, 2000^120^ US IG: UCLA/Lovaas-based intervention, 15/15 CG: Parent training from Lovaas manual, 13/13 Quality: Fair | IG: 36.07 ± 6.00 CG: 35.77 ± 5.77 | RDLS, expressive language | IG: 15.13 ± 0.52 CG: 16.31 ± 2.69 | IG: 44.53 ± 23.48 CG: 36.23 ± 21.19 | Total scores on receptive and expressive language had significantly greater improvement in the intervention group compared to the parent training group (p<0.05) although subscales did not.
Smith et al, 2000^120^ US IG: UCLA/Lovaas-based intervention, 15/15 CG: Parent training from Lovaas manual, 13/13 Quality: Fair | IG: 36.07 ± 6.00 CG: 35.77 ± 5.77 | RDLS, total score | IG: 28.60 ± 4.07 CG: 30.0 ± 6.34 | IG: 87.40 ± 46.21 CG: 61.33 ± 31.88 | Total scores on receptive and expressive language had significantly greater improvement in the intervention group compared to the parent training group (p<0.05) although subscales did not.
Nonrandomized trials
Peters-Scheffer et al, 2013^121^ Netherlands IG: Low intensity Lovaas-based intervention+ specialized preschool, 20/20 CG: Eclectic preschool, 20/20 Quality: Good | IG+CG: 62.52 ± 16.96 (median) | PPVT, receptive language | IG: 25.00 ± 4.48 CG: 24.70 ± 3.21 | IG: 34.30 ± 10.54 CG: 29.30 ± 7.42 | Significantly greater progress in the treatment group, (repeated ANOVA): F(2,76)=3.35, p=004 ES: dividing the difference in change score by the original standard deviation of the sample, d=1.22 No significant effect on expressive language: F(1.40, 53.18)=1.50; p=0.23, d=0.40
Peters-Scheffer et al, 2013^121^ Netherlands IG: Low intensity Lovaas-based intervention+ specialized preschool, 20/20 CG: Eclectic preschool, 20/20 Quality: Good | IG+CG: 62.52 ± 16.96 (median) | Schlichting Test, expressive language | IG: 18.35 ± 6.72 CG:17.65 ± 6.64 | IG: 34.15 ± 14.54 CG: 30.80 ± 15.12
Peters-Scheffer et al, 2010^114^ Netherlands IG: Specialized preschool +UCLA/Lovaas-based intervention, 12/12 CG: Specialized preschool, 22/22 Quality: Fair | IG: 53.5 ± 5.52 CG: 52.95 ± 11.14 | VABS-Communication | IG: 26.92 ± 12.12 CG: 25.00 ± 10.00 | IG: 39.42 ± 15.39 CG: 29.92 ± 13.39 | Greater improvement in IG vs. CG, p=0.02
Hayward et al, 2009^115, 116^ UK IG: Intensive clinic-based UCLA/Lovaas-based intervention, 23/20 CG: Intensive parent-managed treatment, 21/19 Quality: Fair | IG: 35.7 ± 6.2 CG: 34.4 ± 5.7 | RDLS, comprehension | IG: 20.0 ± 0.0 CG: 20.7 ± 2.8 | IG: 26.7 ± 7.0 CG: 28.4 ± 9.5 | Nonsignificant group differences but significant improvement on both measures between intake and followup (combined groups), p<0.01 (t-tests)
Hayward et al, 2009^115, 116^ UK IG: Intensive clinic-based UCLA/Lovaas-based intervention, 23/20 CG: Intensive parent-managed treatment, 21/19 Quality: Fair | IG: 35.7 ± 6.2 CG: 34.4 ± 5.7 | RDLS, expressive language | IG: 20.2 ± 1.0 CG: 20.7 ± 3.3 | IG: 26.4 ± 6.1 CG: 27.6 ± 7.6 | Nonsignificant group differences but significant improvement on both measures between intake and followup (combined groups), p<0.01 (t-tests)
Eikeseth et al, 2002^117, 118^ Norway IG: UCLA/Lovaas-based intervention, 13/13 CG: Eclectic therapy, 12/12 Quality: Fair | IG: 66.31 ± 14.71 CG: 65 ± 10.95 | RDLS, comprehension | IG: 49.03 ± 16.42 CG: 50.38 ± 15.46 | IG: 58.47 ± 17.11 CG: 47.55 ± 17.25 | IG showed more gains than CG on all 3 language measures, p<0.05
Eikeseth et al, 2002^117, 118^ Norway IG: UCLA/Lovaas-based intervention, 13/13 CG: Eclectic therapy, 12/12 Quality: Fair | IG: 66.31 ± 14.71 CG: 65 ± 10.95 | RDLS, expressive | IG: 45.12 ± 13.44 CG: 51.24 ± 19.24 | IG: 67.39 ± 17.81 CG: 49.00 ± 18.69 | IG showed more gains than CG on all 3 language measures, p<0.05
Eikeseth et al, 2002^117, 118^ Norway IG: UCLA/Lovaas-based intervention, 13/13 CG: Eclectic therapy, 12/12 Quality: Fair | IG: 66.31 ± 14.71 CG: 65 ± 10.95 | RDLS, total | IG: 51.83 ± 17.42 CG: 60.00 ± 24.22 | IG: 76.85 ± 26.67 CG: 61.58 ± 24.34 | IG showed more gains than CG on all 3 language measures, p<0.05
Cohort studies
Boyd et al, 2013^113^ US IG: TEACCH preschools, 85/81 CG1: LEAP preschools, 54/48 CG2: Nonmodel specific preschools, 59/56 Quality: Fair | IG: 48 ± 6.84 CG1: 47.52 ± 8.4 CG2: 48.84 ± 7.68 | PLS-4, expressive communication | IG: 0.214 ± 0.86 CG1: 0.081 ± 1.045 CG2: -0.403 ± 0.784 | IG: 0.441 ± 0.937 CG1: 0.238 ± 1.102 CG2: - 0.317 ± 0.878 | Significant baseline group difference, p<0.001 Pairwise group comparison on gain scores not significant (p=ns)
Eikeseth et al, 2012^108^ Norway, Sweden IG: Early intervention, 35/35 CG: Eclectic, 24/24 Quality: Fair | IG: 3.9 ± 0.9 years CG: 4.4 ± 1.2 years | VABS-Communication | IG: 67.10 ± 14.0 CG: 65.5 ± 14.2 | IG: 81.30 ± 16.90 CG: 63.60 ± 16.0 | Greater improvement in IG vs. CG, p<0.001
Eldevik et al, 2012^107^ Norway IG: Preschool-based early intensive intervention, 31/31 CG: Usual care preschool, 12/12 Quality: Fair | IG: 42.2 ± 9.0 CG: 46.2 ± 12.4 | VABS-Communication | IG: 61.90 ± 10.20 CG: 60.0 ± 9.60 | IG: 70.50 ± 16.90 CG: 60.0 ± 14.50 | Greater improvement in IG vs. CG, p<0.05 Mean ± SD change: IG: 8.6 ± 14.6 CG: 0.0 ± 12.6
Flanagan et al, 2012^109, 141^ Canada IG: Intensive behavioral intervention, 61/61 CG: Waitlist control (matched by age), 61/61 Quality: Fair | IG: 42.93 ± 11.53 CG: 42.79 ± 10.51 | VABS Communication | IG: 25.47 ± 15.81 CG: 25.50 ± 11.97 | Mean ± SD: IG: 46.60 ± 29.91 CG: 30.33 ± 16.98 Estimated marginal mean score: IG: 43.45 CG: 29.80 | Greater improvement in IG vs. CG, p=0.006 Effect size=0.56
Itzchak et al, 2011^105, 106^ Israel IG: ABA-based approach, 45/45 CG: Eclectic approach, 33/33 Quality: Fair | IG: 25.1 ± 3.9 CG: 26.0 ± 4.6 | MSEL receptive language | IG: 34.40 ± 15.20 CG: 29.60 ± 14.80 | IG: 40.10 ± 14.20 CG: 37.70 ± 12.80 | No significant group differences on any measure
Itzchak et al, 2011^105, 106^ Israel IG: ABA-based approach, 45/45 CG: Eclectic approach, 33/33 Quality: Fair | IG: 25.1 ± 3.9 CG: 26.0 ± 4.6 | MSEL expressive language | IG: 28.80 ± 11.30 CG: 31.40 ± 12.50 | IG: 35.60 ± 15.00 CG: 39.00 ± 14.30 | No significant group differences on any measure
Itzchak et al, 2011^105, 106^ Israel IG: ABA-based approach, 45/45 CG: Eclectic approach, 33/33 Quality: Fair | IG: 25.1 ± 3.9 CG: 26.0 ± 4.6 | VABS-Communication | IG: 67.00 ± 7.80 CG: 69.50 ± 10.70 | IG: 72.90 ± 14.70 CG: 78.80 ± 16.20 | No significant group differences on any measure
Zachor et al, 2007^110^ Israel IG: UCLA/Lovaas-based intervention, 53/53 CG: Eclectic approach, 15/15 Quality: Fair | IG: 25.1 ± 3.8 CG: 26.3 ± 4.6 | ADOS language and communication | IG: 13.80 ± 4.30 CG: 11.80 ± 4.30 | IG: 7.20 ± 4.10 CG: 9.70 ± 3.00 | Greater improvement in IG vs. CG, p<0.01
Cohen et al, 2006^119^ US IG: UCLA/Lovaas-based intervention, 21/21 CG: Local services, 21/19 Quality: Fair | IG: 30.2 ± 5.8 CG: 33.2 ± 3.7 | RDLS, language comprehension | IG: 51.7 ± 15.2 CG: 52.7 ± 15.1 | IG: 72 CG: 62 | ANCOVA--Significant group difference, n=40, F=3.82, p<0.10 in language comprehension favoring IG No significant group difference in expressive language, n=39, p=0.13
Cohen et al, 2006^119^ US IG: UCLA/Lovaas-based intervention, 21/21 CG: Local services, 21/19 Quality: Fair | IG: 30.2 ± 5.8 CG: 33.2 ± 3.7 | RDLS, expressive language | IG: 52.9 ± 14.5 CG: 52.8 ± 14.4 | IG: 78 CG: 66 | ANCOVA--Significant group difference, n=40, F=3.82, p<0.10 in language comprehension favoring IG No significant group difference in expressive language, n=39, p=0.13
Howard et al, 2005^111^ US IG: UCLA/Lovaas-based intervention, 37/29 CG1: Intensive eclectic therapy CG2: Nonintensive eclectic therapy CG2+CG3: 41/32 Quality: Fair | IG: 30.86 ± 5.16 CG1: 37.44 ± 5.68 CG2: 34.56 ± 6.53 | RDLS, receptive language | Standard Scores: IG: 52.16 ± 18.44 CG1: 45.38 ± 14.97 CG2: 49.00 ± 13.61 | Standard Scores: IG: 71.31 ± 22.72 CG1: 49.93 ± 19.62 CG2: 49.21 ± 16.08 | On both receptive and expressive language the intervention group demonstrated significantly greater improvement, p<0.05
Howard et al, 2005^111^ US IG: UCLA/Lovaas-based intervention, 37/29 CG1: Intensive eclectic therapy CG2: Nonintensive eclectic therapy CG2+CG3: 41/32 Quality: Fair | IG: 30.86 ± 5.16 CG1: 37.44 ± 5.68 CG2: 34.56 ± 6.53 | RDLS, expressive language | IG: 51.88 ±12.91 CG1: 43.88 ± 6.69 CG2: 48.77 ± 11.61 | IG: 70.46 ± 22.88 CG1: 47.67 ± 23.39 CG2: 46.79 ± 12.81 | On both receptive and expressive language the intervention group demonstrated significantly greater improvement, p<0.05

ABA=applied behavior analysis; ADOS=Autism Diagnostic Observation Schedule; CABAS=Comprehensive Application of Behaviour Analysis; ESDM=Early Start Denver Model; LEAP=Learning Experiences and Alternative Program; MSEL=Mullen Scales of Early Learning; NR=not reported; PLS=Preschool Language Scale; PPVT=Peabody Picture Vocabulary Test; RDLS=Reynell Developmental Language Scale; UCLA=University of California, Los Angeles; VABS=Vineland Adaptive Behavior Scale.

Table 12 Summary of Cognitive Outcomes in Parent Training Studies (k=5)

Author, Year, Country Groups, N Enrollment/N Final | Age at Intake Mean months±SD | Measure | Baseline Score, Mean±SD | Followup Score, Mean±SD | Analytic Data
RCTs
Landa et al, 2012^124, 125^ US IG: Assessment Evaluation and Programming System for Infants and Children (AEPS) curriculum + additional joint attention and social interaction opportunities, 25/24 CG: AEPS curriculum, 25/24 Quality: Good | IG: 28.6 ± 2.6 CG: 28.8 ± 2.8 | MSEL Expressive language | IG: 23.92 ± 5.50 CG: 25.92 ± 8.12 | IG: 34.52 ± 12.33 CG: 31.36 ± 12.12 | No between group differences on any measure
| IG: 28.6 ± 2.6 CG: 28.8 ± 2.8 | CSBS DP | IG: 2.29 ± 3.16 CG: 2.79 ± 3.62 | IG: 8.83 ± 13.22 CG: 4.42 ± 4.82 | No between group differences on any measure
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver model (ESDM), 49/49 CG: Community treatment as usual, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | Mullen DQ | IG: 64.88 ± 17.22 CG: 63.08 ± 15.93 | IG: 69.82 ± 17.9 CG: 67.92 ± 17.93 | No significant difference between groups on DQ measures Change from baseline, Cohen's d: Mullen DQ: IG: 0.44, CG:0.37 Verbal DQ: IG: 0.56, CG: 0.53 Non-verbal DQ: IG:0.08, CG:-0.01
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver model (ESDM), 49/49 CG: Community treatment as usual, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | Mullen Verbal DQ | IG: 47.78 ± 22.19 CG: 44.45 ± 20.37 | IG: 56.65 ± 23.65 CG: 54.35 ± 21.94 | No significant difference between groups on DQ measures Change from baseline, Cohen's d: Mullen DQ: IG: 0.44, CG:0.37 Verbal DQ: IG: 0.56, CG: 0.53 Non-verbal DQ: IG:0.08, CG:-0.01
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver model (ESDM), 49/49 CG: Community treatment as usual, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | Mullen Nonverbal DQ | IG: 80.96 ± 16.68 CG: 80.73 ± 15.51 | IG: 81.98 ± 14.82 CG: 80.57 ± 18.45 | No significant difference between groups on DQ measures Change from baseline, Cohen's d: Mullen DQ: IG: 0.44, CG:0.37 Verbal DQ: IG: 0.56, CG: 0.53 Non-verbal DQ: IG:0.08, CG:-0.01
Drew et al, 2002^136^ UK IG: Parent training, 12/12 CG: Local/eclectic services, 12/12 Quality: Fair | IG: 21.4 ± 2.7 CG: 23.6 ± 3.8 | Griffiths Scale of Infant Development NVIQ | IG: 88.1 ± 11.2 CG: 23.6 ± 3.8 | IG: 77.9 ± 14.8 CG: 66.1 ± 17.1 | Significant baseline group difference IG had a higher NVIQ than CG (F[1, 23]= 14.8, p<0.001). At followup no group differences in NVIQ
Prospective cohort studies
Strauss et al, 2012^126, 127^ Italy IG: Staff and parent mediated early intervention, 24/24 CG: Eclectic, 20/20 Quality: Good | IG: 55.67 ± 17.63 CG: 41.94 ± 13.07 | Griffiths Mental Development Scale-ER GQ (Mental developmental standard score) | IG: 55.65 ± 20.06 CG: 74.29 ± 29.37 | IG: 68.75 ± 19.58 CG: 76.00 ± 26.08 | Change over time: IG had significant gains (t=4.639, p<0.0001) CG: t=0.332, p=0.75 Age did not influence between group difference, (F (44) = 0.729, p =0.493)
Reed et al, 2012^132^ UK IG: ABA, 14/14 CG1: Special nursery, 21/21 CG2: Portage, 18/18 CG3: Local authority-developed parent training, 13/13 Quality: Fair | IG: 39.0 ± 6.9 CG1: 41.5 ± 4.0 CG2: 39.5 ± 6.3 CG3: 40.2 ± 6.3 | PEP-R (Intellectual functioning) | IG: 55.1 ± 17.3 CG1: 52.2 ± 17.7 CG2: 54.0 ± 15.4 CG3: 51.7 ± 14.5 | Change score IG: 14.5 ± 16.0 CG1: 10.4 ± 28.5 CG2: 0.6 ± 11.1 CG3: 3.2 ± 16.4 | No between group differences, p>0.10

ABA=Applied Behavior Analysis; CG=Control Group; DQ=Developmental Quotient; ESDM=Early Start Denver Model; IG=Intervention Group; IQ=Intelligence Quotient; NVIQ=Nonverbal Intelligence Quotient; PEP-R=Psychoeducational Profile Revised.

Table 13 Summary of Language Outcomes in Parent Training Studies (k=12)

Author, Year, Country Groups, N Enrollment/N Final | Age at Intake Mean months ± SD | Measure | Baseline Score, Mean ± SD | Follow-Up Score, Mean ± SD | Analytic Data
RCTs
Schreibman et al, 2013^140^ US IG: Pivotal Response Training, 20/20 CG: PECS, 19/19 Quality: Good | IG: 29.5 ± 6.9 CG: 28.9 ± 4.2 | MSEL-Expressive communication (n=38) | IG: 20.3 ± 3.2 CG: 18.5 ± 2.8 | IG: 28.7 ± 16.5 CG: 23.7 ±11.2 | Significant time effect for expressive communication, F=9.95, p=0.000, ES=0.216 No significant group × time interaction, F=0.551, p=0.51 Significant time effect for words produced, F=31.26, p=0.000, ES=0.486 No significant group × time interaction, F=0.313, p=0.645
Schreibman et al, 2013^140^ US IG: Pivotal Response Training, 20/20 CG: PECS, 19/19 Quality: Good | IG: 29.5 ± 6.9 CG: 28.9 ± 4.2 | MacArthur CDI- Words produced (n=35) | IG: 5.3 ± 9.4 CG: 11.9 ± 20.5 | IG: 129.8 ± 117.9 CG: 113.3 ± 108.3
Landa et al, 2012^124, 125^ US IG: Assessment Evaluation and Programming System for Infants and Children (AEPS) curriculum + additional joint attention and social interaction opportunities, 25/24 CG: AEPS curriculum, 25/24 Quality: Good | IG: 28.6 ± 2.6 CG: 28.8 ± 2.8 | MSEL | Expressive language T scores: IG: 23.92 ± 5.50 CG: 25.92 ± 8.12 | Expressive language T scores: IG: 34.08 ± 14.59 CG: 31.92 ± 13.67 | No significant group differences in expressive language T scores, p=0.44
Roberts et al, 2011^131^ Australia IG: Individualized home-based program, 34/27 CG1: Small group center-based program combined with parent training and support group, 33/29 CG2: Waitlist, 28/28 Quality: Fair | IG: 41.5 CG1: 43.1 CG2: 43.7 | RDLS- Standard scores Comprehension | IG: 4.2 ± 9.2 CG1: 5.5 ± 10.6 CG2: 7.2 ± 15.2 | IG: 2.6 ± 8.4 CG1: 10.5 ± 17.4 CG2: 5.7 ± 12.1 | Mean group difference, 95% CI IG vs. CG1: 7.3 (0.7, 13.9), p=0.03 IG vs. CG2: 1.8 (-4.9, 8.4), p=0.60 CG1 vs. CG2: 5.5 (-1.2, 12.2), p=0.10 3-group comparison: p=0.08
| IG: 41.5 CG1: 43.1 CG2: 43.7 | Expression Standard scores | IG: 3.4 ± 8.3 CG1: 8.2 ± 16.6 CG2: 6.0 ± 10.9 | IG: 2.8 ± 7.5 CG1: 7.0 ± 15.1 CG2: 4.4 ± 8.7 | Mean group difference, 95% CI IG vs. CG1: 3.0 (-2.9, 9.0), p=0.31 IG vs. CG2: 0.9 (-4.9, 6.8), p=0.75 CG1 vs. CG2: 2.1 (-3.8, 8.0), p=0.48 3-group comparison: p=0.58 Significant greater improvement in Reynell comprehension standard score for CG1 compared with IG. All other group differences were not significantly different for both comprehension and expression scores
Aldred et al, 2012^137, 138^ UK IG: Parent training in social communication intervention plus community intervention, 14/14 CG: Eclectic intervention, 14/14 Quality: Good | IG: 51.4 ± 11.8 CG: 50.9 ± 16.3 | MacArthur CDI- Language comprehension | IG: 71.7 ± 2383 CG: 95.4 ± 426 | IG: 222.7 ± 40,431 CG: 146.8 ± 11,426 | No significant group difference in language comprehension, F=2.93, p=0.1
Aldred et al, 2012^137, 138^ UK IG: Parent training in social communication intervention plus community intervention, 14/14 CG: Eclectic intervention, 14/14 Quality: Good | IG: 51.4 ± 11.8 CG: 50.9 ± 16.3 | Expressive language | IG: 28 ± 467 CG: 25.6 ± 683 | IG: 199.4 ± 25,606 CG: 33.1 ± 683 | Significant group difference in expressive language, F=18.5, p<0.001
Casenhiser et al, 2013^128^ Canada IG: MEHRIT (developmental individualized relationship-based intervention), 25/25 CG: Eclectic community-based treatment, 26/26 Quality: Fair | IG: 42.5 ± 8.8 CG: 46.4 ± 8.3 | PLS-4, CASL | Developmental quotient (DQ): IG: 0.64 ± 0.32 CG: 0.54 ± 0.26 | DQ: IG: 0.72 ± 0.39 CG: 0.64 ± 0.32 | Both groups significantly different from baseline scores IG: p = 0.038, d =0.451 CG: p<0.001, d=0.915 No significant group difference in DQ scores after treatment, F (1,48)=1.589, p=0.214, η^2^ =0.022
Oosterling et al, 2010^133^ IG: Nonintensive parent training + specialized preschool, 40/36 CG: Eclectic preschool, 35/31 Quality: Fair | IG: 35.2 ± 5.5 CG: 33.3 ± 6.4 | MacArthur CDI Words understood | IG: 177.9 ± 122.5 CG: 181.5 ± 121.4 | Change from baseline IG: 62.0 ± 75.0 CG: 35.2 ± 66.1 | No significant group difference in words understood, F=2.12, p=ns
Oosterling et al, 2010^133^ IG: Nonintensive parent training + specialized preschool, 40/36 CG: Eclectic preschool, 35/31 Quality: Fair | IG: 35.2 ± 5.5 CG: 33.3 ± 6.4 | Words said | IG: 106.8 ± 122.2 CG: 101.7 ± 109.7 | IG: 75.5 ± 78.8 CG: 56.1 ± 97.2 | No significant group difference in “words said,” F=2.92, p=ns
Oosterling et al, 2010^133^ IG: Nonintensive parent training + specialized preschool, 40/36 CG: Eclectic preschool, 35/31 Quality: Fair | IG: 35.2 ± 5.5 CG: 33.3 ± 6.4 | Gestures produced | IG: 29.1 ± 13.7 CG: 30.1 ± 13.6 | IG: 6.7 ± 10.2 CG: 6.3 ± 9.0 | Significant group difference in gestures produced, F=3.91, p=ns
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver mode (ESDM), 49/49 CG: Eclectic community treatment, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | MacArthur CDI Part I: Phrases Understood | IG: 8.22 ± 7.02 CG: 9.38 ± 7.95 | IG: 12.73 ± 9.11 CG: 14.77 ± 8.14 | Baseline vs. Visit2 : Cohen's d: Phrases Understood: IG: 0.62, CG: 0.87 Vocabulary Comprehension: IG: 0.66, CG:0.84 Vocabulary Production: IG: 0.69, CG:0.57 Total Gestures: IG: 0.83, CG:1.02 Significant group difference in number of intervention hours, p<0.05 and Intervention hours had a significant interaction effect on MacArthur CDI Vocabulary production, p=0.005
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver mode (ESDM), 49/49 CG: Eclectic community treatment, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | MacArthur CDI Part I: Vocabulary Comprehension | IG: 64.53 ± 65.73 CG: 70.31 ± 78.34 | IG: 106.51 ± 96.81 CG: 125.72 ± 106.39
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver mode (ESDM), 49/49 CG: Eclectic community treatment, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | MacArthur CDI Part I: Vocabulary Production | IG: 12.24 ± 35.6 CG: 12.44 ± 39.72 | IG: 42.27 ± 61.99 CG: 38.87 ± 73.71
Rogers et al, 2012^129, 130^ US IG: Parent-delivered Early Start Denver mode (ESDM), 49/49 CG: Eclectic community treatment, 49/49 Quality: Fair | IG: 21.02 ± 3.51 CG: 20.94 ± 3.42 | MacArthur CDI Part II: Total Gestures | IG:19.89 ± 10.12 CG: 20.33 ± 11.15 | IG: 28.02 ± 12.62 CG: 29.79 ± 13.51
Carter et al, 2011^134^ US IG: More than Words, 32/29 CG: Eclectic, 30/26 Quality: Fair | IG: 21.11 ± 2.71 CG: 21.51 ± 2.82 | Mullen Expressive Language Age | IG: 8.22 ± 6.01 CG: 7.33 ± 3.71 | IG: 16.20 ± 7.23 CG: 16.68 ± 7.88 | No significant between group differences No significant group difference in PIA-CV nonverbal communication residualized Gain scores: ES=-0.19 (95% CI: -0.81, 0.43) No significant group difference in ESCS initiating joint attention residualized Gain scores: ES= 0.12 (95%CI: -0.46, 0.70) No significant group difference in PCFP frequency of intentional communication residualized Gain scores: ES=0.15 (95% CI: -0.57, 0.88)
Carter et al, 2011^134^ US IG: More than Words, 32/29 CG: Eclectic, 30/26 Quality: Fair | IG: 21.11 ± 2.71 CG: 21.51 ± 2.82 | Mullen Receptive Language Age | IG: 8.41 ± 5.42 CG: 8.17 ± 4.44 | IG: 15.52 ± 6.93 CG: 17.48 ± 8.33
Carter et al, 2011^134^ US IG: More than Words, 32/29 CG: Eclectic, 30/26 Quality: Fair | IG: 21.11 ± 2.71 CG: 21.51 ± 2.82 | PIA-CV nonverbal communication | IG: 2.30 ± 0.64 CG: 2.28 ± 0.73 | IG: 2.89 ± 0.67 CG: 2.92 ± 0.65
Carter et al, 2011^134^ US IG: More than Words, 32/29 CG: Eclectic, 30/26 Quality: Fair | IG: 21.11 ± 2.71 CG: 21.51 ± 2.82 | ESCS initiating joint attention | IG: 5.90 ± 5.41 CG: 5.59 ± 6.14 | IG: 10.33 ± 9.82 CG: 8.68 ± 9.26
Carter et al, 2011^134^ US IG: More than Words, 32/29 CG: Eclectic, 30/26 Quality: Fair | IG: 21.11 ± 2.71 CG: 21.51 ± 2.82 | PCFP weighted frequency of intentional communication | IG: 5.55 ± 6.29 CG: 8.20 ± 12.63 | IG: 18.91 ± 20.50 CG: 20.75 ± 21.14
Green et al, 2010^135^ UK IG: Preschool autism communication intervention (PACT), 77/74 CG: Eclectic treatment, 75/72 Quality: Fair | IG: 45 CG: 45 | PLS-Receptive raw scores | IG: 15.6± 9.8 CG: 15.0±9.7 | IG: 21.5±13.0 CG: 20.3 ±12.8 | Change from baseline, mean (SD): IG: 6.0 (6.7) CG: 5.3 (5.9) Change from baseline, mean (SD): IG: 5.1 (5.6) CG: 4.9 (5.2) Change from baseline, mean (SD): IG: 74.2 (66.9) CG: 47.0 (68.2) Change from baseline, mean (SD): IG: 78.5 (89.3) CG: 51.8 (73.2) Significant group differences, mean (95% CI): 30.28 (6.90 to 53.68) for the MacArthur CDI receptive scores and 21.37 (-6.42 to 49.16) for the MacArthur CDI I expressive scores
Green et al, 2010^135^ UK IG: Preschool autism communication intervention (PACT), 77/74 CG: Eclectic treatment, 75/72 Quality: Fair | IG: 45 CG: 45 | Expressive raw scores | IG: 15.0±8.1 CG: 15.1±7.9 | IG: 20.0 ±11.2 CG: 20.0±11.3
Green et al, 2010^135^ UK IG: Preschool autism communication intervention (PACT), 77/74 CG: Eclectic treatment, 75/72 Quality: Fair | IG: 45 CG: 45 | Parent rated MacArthur CDI: Receptive raw score | IG: 159.5±114.4 CG: 162.0± 122.4 | IG: 233.7±129.6 CG: 209.0±131.3
Green et al, 2010^135^ UK IG: Preschool autism communication intervention (PACT), 77/74 CG: Eclectic treatment, 75/72 Quality: Fair | IG: 45 CG: 45 | MacArthur CDI:Expressive raw score | IG: 93.5± 114.8 CG: 111.1± 128.6 | IG: 171.9±150.7 CG: 163.8±144.3
Drew et al, 2002^136^ UK IG: Parent training, 12/12 CG: Eclectic services, 12/12 Quality: Fair | IG: 21.4 ± 2.7 CG: 23.6 ± 3.8 | MacArthur CDI: Words understood | IG: 52 ± 60.5 CG: 53.0 ± 63.7 | IG: 176.1 ± 121.9 CG: 100.3 ± 80.2 | Words and gestures produced were not significantly different between the 2 groups (p >0.05) Significantly more children in the IG moved from being nonverbal to having single word or phrase speech (N=7) than in the CG (N=2 and one child went from single words to fewer than five words from the initial to the follow-up assessment) (Fisher exact test, p<0.05)
Drew et al, 2002^136^ UK IG: Parent training, 12/12 CG: Eclectic services, 12/12 Quality: Fair | IG: 21.4 ± 2.7 CG: 23.6 ± 3.8 | Words said | IG: 6.8 ± 20.9 CG: 6.6 ± 13.7 | IG: 96.6 ± 118.8 CG: 44.0 ± 50.2
Drew et al, 2002^136^ UK IG: Parent training, 12/12 CG: Eclectic services, 12/12 Quality: Fair | IG: 21.4 ± 2.7 CG: 23.6 ± 3.8 | Total gestures produced | IG: 20.9 ± 7.0 CG: 20.9 ± 14.4 | IG: 38.6 ± 12.5 CG: 29.1 ± 18.4
Drew et al, 2002^136^ UK IG: Parent training, 12/12 CG: Eclectic services, 12/12 Quality: Fair | IG: 21.4 ± 2.7 CG: 23.6 ± 3.8 | ADI-R overall language rating | IG: Nonverbal (<5 words): 11 Single words: 1 Phrase speech: 0 CG: Nonverbal (<5 words): 11 Single words: 1 Phrase speech: 0 | IG: Nonverbal (<5 words): 4 Single words: 5 Phrase speech: 3 CG: Nonverbal (<5 words): 9 Single words: 3 Phrase speech: 0
Prospective cohort studies
Strauss et al, 2012^126, 127^ Italy IG: Staff and parent mediated early intervention, 24/24 CG: Eclectic, 20/20 Quality: Good | IG: 55.67 ± 17.63 CG: 41.94 ± 13.07 | MacArthur CDI: Comprehension | IG: 53.83 ± 28.81 CG: 47.17 ± 27.80 | IG: 70.33 ± 27.04 CG: 61.33 ± 32.37 | Comprehension: Change over time significant for both groups, p≤0.012 Children in IG outperformed children in CG at T2 on early language comprehension (t(23)=6.460, p ≤0.001) vs. (t(19)=3.885, p≤0.05) Production: Change over time significant for IG (t=3.41, p=0.003) but not significant for CG (t=1.69, p=0.151) No age effect influencing between group differences in CDI language comprehension (F(44)=1.492, p=0.249) or CDI language production, (F(44)=1.553, p=0.233)
Strauss et al, 2012^126, 127^ Italy IG: Staff and parent mediated early intervention, 24/24 CG: Eclectic, 20/20 Quality: Good | IG: 55.67 ± 17.63 CG: 41.94 ± 13.07 | Production | IG: 35.29 ± 35.97 CG: 19.17 ± 28.12 | IG: 51.81 ± 35.23 CG: 33.17 ± 42.27
Keen et al, 2010^139^ Australia IG: Professional parent intervention, 17 families/NR CG: Self-directed video based parent intervention, 22 families/NR Quality: Good | IG: 36.38 ± 7.54 CG: 35.71 ± 6.92 | CSBS DP Caregiver | IG: 69.10 ± 24.16 CG: 62.82 ± 28.01 | IG: 91.67 ± 28.80 CG: 80.83 ± 27.68 | Greater improvement in IG vs. CG on parent-rated caregiver measure but not observer-rated behavior sample
Keen et al, 2010^139^ Australia IG: Professional parent intervention, 17 families/NR CG: Self-directed video based parent intervention, 22 families/NR Quality: Good | IG: 36.38 ± 7.54 CG: 35.71 ± 6.92 | CSBS DP Behavior Sample | IG: 56.36 ± 31.84 CG: 55.57 ± 38.24 | IG: 75.84 ± 39.73 CG: 73.57 ± 48.92 | Greater improvement in IG vs. CG on parent-rated caregiver measure but not observer-rated behavior sample

ADI-R=Autism Diagnostic Interview Revised; CASL=Comprehensive Assessment of Spoken Language; CSBS DP=Communication and Symbolic Behavior Scales Developmental Profile; MacArthur CDI=MacArthur Communication Development Inventory; CG=Control Group; CI=Confidence Interval; ES=effect size; IG=Intervention Group; MSEL=Mullen Scales of Early Learning; PACT=Preschool Autism Communication Intervention; PECS=Picture Exchange Communication System; PLS-4=Preschool Language Scale; RDLS=Reynell Developmental Language Scales.

Table 14 Key Outcomes of RCTs of Play/Interaction-Based Interventions (k=12)

Author, Year, Country Groups, N Enrollment/N Final Study Quality | Age, Mean Months ± SD IQ, Mean ± SD | Key Outcomes
Joint attention studies
Kasari et al, 2014^142^ US IG: Caregiver-mediated joint attention/symbolic play intervention, 60/51 CG: Caregiver education, 52/44 Quality: Fair | IG: 41.9 ± 10 CG: 42.8 ± 10.21 IG: 23.6 ± 11.6 CG: 26.3 ± 11.8 | - 66% of participants were non-white and from families with low SES status; - Joint engagement improved in both groups over time with significantly greater improvement in IG vs. CG, p=0.003; - Time engaged increased to over half of interaction period in IG, rate of difference between groups=44.7%. Effect size for difference in joint engagement=0.21. Differences in joint engagement maintained at followup 3-months post-intervention for IG, p=0.02; - Initiating joint attention improved in both groups with greater improvement in IG, p=0.05, effect size=0.14. Increases in both groups maintained at followup.; - No significant improvements in functional play types in either group
Goods et al, 2013^155^ US IG: Joint attention intervention, 8/6 CG: Control, 7/5 Quality: Good | IG: 48.73 ± 11.68 CG: 54.68 ± 10.25 IG: 37.70 ± 15.21 CG: 26.67 ± 10.12 | - IG demonstrated more spontaneous play types, spent less time unengaged in classroom, and initiated more requesting gestures than CG (effect sizes 0.81, 1.63, 1.51 respectively, p values ≤0.05); - No significant group differences on the Early Social Communication Scales measures of joint attention
Kasari et al, 2010^154^ US IG: Immediate joint attention intervention, 19/19 CG: Waitlist control, 19/19 Quality: Good | IG: 30.35 ± 0.93 CG: 31.31 ± 0.90 IG: 64.80 ± 5.35 CG: 59.81 ± 3.14 | - Children in IG exhibited significantly less object-focused play, more responsiveness to joint attention, more functional play types, and greater joint engagement than CG at initial followup (p<0.05); gains in joint engagement, responsiveness to joint attention, and types of functional play were maintained at 1-year followup of IG; - Groups did not differ on other/unengaged play time at followup
Wong 2013^143^ US IG: Joint attention-symbolic play interventions, 14/14 CG: Symbolic play-joint attention intervention, 10/10 G3: Waitlist, 9/9 Quality: Fair | IG: 56.2 ± 10.4 CG: 54.5 ± 5.1 G3: 59.7 ± 10.6 NR | - Increased time in joint engaged state for IG and CG vs. G3 (effect size=0.63); - For IG+CG, joint engagement time, joint attention responses/minute, joint attention initiations/minute, symbolic play acts/minute increased significantly from baseline to post-intervention (effect sizes of 0.41, 0.43, 0.21, and 0.51 respectively); - Increases in joint attention responses from baseline for IG+CG as measured on the Early Social Communication Scales; no significant increases in functional play level or structured play; - No significant modifiers identified
Warreyn et al, 2013^144^ Belgium IG: Joint attention/imitation intervention, 18/18 CG: Treatment as usual, 18/18 Quality: Fair | IG: 5.7 ± 0.6 years CG: 5.7 ± 0.7 years IG: 78.9 ± 15.5 CG: 76.9 ± 16.8 | - Total joint attention scores more improved for IG vs. CG (p<0.01); gaze following, initiating requests also significantly improved for IG vs. CG (p values <0.05); - IG increased number of elicited joint attention acts by 1.88, number spontaneous declarative joint attention actions by 0.83, and number correct imitations by 7.01 from baseline in both groups from baseline to followup (p<0.05); - Verbal IQ significantly correlated with growth in imitation for IG (p<0.05); age, mental age, full scale IQ baseline imitation and joint attention skills, performance IQ were not significant modifiers of outcomes
Schertz et al, 2013^153^ US IG: Joint attention-focused parent training, 11/11 CG: Treatment as usual, 12/12 Quality: Fair | IG: 24.6 ± 4.0 CG: 27.5 ± 3.4 NR | - Scores on responding to joint attention significantly improved for IG vs. CG at 4-week post-intervention followup (effect size for differences=1.39), as were scores on focusing on faces (effect size=1.24); effects sizes at 8-week followup were 1.18 (responding to joint attention) and 0.84 (faces)
Lawton et al, 2012^148^ US IG: Immediate joint attention intervention, 9/9 CG: Delayed treatment, 7/7 Quality: Fair | IG: 46.0 ± 5.00 CG: 43.01 ± 6.00 IG: 30.3 ± 5.01 CG: 33.8 ± 8.74 | - Joint attention intervention delivered by preschool teachers; - In classroom observations, IG demonstrated greater initiations of joint attention vs. CG (effect size=1.85, p<0.005) and used more pointing and showing gestures (effect sizes 2.02, 1.85 respectively); no differences in looking or giving; - Total joint attention scores on the Early Social Communication Scales did not differ between groups; - On intervention exit play observations, no group differences in any joint attention skills; - IG demonstrated less object engagement (effect size=1.41) and more supported engagement (effect size=1.24) compared with CG
Kaale et al, 2012^146^ Norway IG: Joint attention intervention, 34/34 CG: Control, 27/27 Quality: Fair | IG: 47.6 ± 8.30 CG: 50.3 ± 8.3 IG: 53.3 ± 19.2 CG: 59.9 ± 19.7 | - Joint attention intervention delivered by preschool teachers; - IG demonstrated more frequent joint attention skills in play with teachers vs. CG, with IG nearly 5 times more likely to demonstrate initiation of joint attention vs. CG (effect size=0.44); duration of joint engagement with teachers did not differ between groups; - IG spent longer time in jointly engaged play with mothers vs. CG post-intervention (effect size=0.67); frequency of joint attention skills with mothers did not differ between groups
Kasari et al, 2012^149-152^ US IG: Joint attention intervention, 20/20 CG: Symbolic play intervention, 16/16 G3: Control, 16/16 Quality: Fair | IG: 43.05 ± 6.863 CG: 41.41 ± 6.491 G3: 41.31 ± 4.542 NR | - Joint attention interventions delivered by interventionists; children in the intervention groups showed greater growth in expressive language, initiation of joint attention, and duration of child-initiated joint attention than did control group children (p≤0.01, <0.05); receptive language growth not significantly affected by intervention; - Amount of intervention services received post-intervention was not related to growth in skills at followup 12 months after the ~6 week intervention, except for child-initiated joint attention: children receiving fewer hours of additional services showed greater growth in child-initiated joint attention; - Quality of joint attention (shared positive affect, shared positive affect with utterances) improved in IG and CG at 6 and 12 month followups; - At followup of 40/58 participants 5 years post-intervention, 32/40 had passing scores on the Expressive Vocabulary Test of spoken language; only baseline play level predicted ability to use spoken language.; - Younger age at baseline, initiation of joint attention, and play level were predictors of spoken language ability at 5-year followup; - Greater functional play types at baseline predicted better overall cognitive ability at 5-year followup
Imitation studies
Ingersoll 2010^156, 157^ US IG: Reciprocal imitation training, 15/14 CG: Control, 14/13 Quality: Good | IG: 41.36 ± 4.30 CG: 37.20 ± 7.36 NR | - Pilot evaluation of a reciprocal imitation training program; - IG made greater gains in spontaneous and prompted imitation, object imitation, gesture imitation, initiation of joint attention, and on the Social-Emotional Scale than CG (p values ≤0.05); - Number of spontaneous play actions associated with gains in spontaneous imitation and gesture imitation (p<0.05); - Changes in imitation skills not associated with social functioning changes in mediation analysis
Parent-child communication studies
Siller et al, 2013^147^ US IG: Parental responsiveness intervention, 36/31 CG: Control, 34/31 Quality: Fair | IG: 58.3 ± 12.7 CG: 55.9 ± 11.9 NR | - Intervention focused on increasing parents' responsiveness to child communication; - Mothers of children in IG demonstrated greater synchronization with child communication vs. CG (p<0.05, effect size=0.08); - No significant effects of intervention on expressive language; - Mothers rated as more insightful at baseline had greater gains in synchronization
Venker et al, 2011^145^ US IG: Parental responsiveness intervention, 7/7 CG: Delayed treatment, 7/7 Quality: Fair | IG+CG: 41.14±10.40 NR | - Intervention targeting parents' verbal responsive and engagement with child play; - Both groups increased prompted communication acts from baseline to followup; in between group comparisons, IG had greater increases vs. CG (p<0.03); - Number of children increasing spontaneous communication acts did not differ between groups

BASC=Behavioral Assessment System for Children; CG=comparison group; DQ=developmental quotient; G=group; IG=intervention group; IQ=intelligence quotient; N=number; NR=not reported; SD=standard deviation

#### Early Intensive Behavioral and Developmental Interventions

##### Key Summary Points

- Forty-two unique studies addressed early intensive behavioral and development interventions for children with ASD. These included 26 RCTs (nine good and 17 fair quality), five nonrandomized trials (one good and four fair quality), 10 prospective studies (two good and eight fair quality), and one retrospective cohort study (fair quality). None of the studies focused on screen-detected children.
- All studies compared a minimum of two treatment groups. No study included a control group that was not receiving some type of intervention (including school enrollment or eclectic community-based therapies, such as medication or occupational therapy), although some limited the number of behaviorally-based treatment hours that control participants could receive.
- Data are inadequate to predict which children are most likely to benefit from early intervention, although benefits achieved differ by child characteristics and interventions offered.
- No studies reported harms.

##### Direct Provision to Child

- Seventeen studies (two good- and two fair-quality RCTs; one good- and four fair-quality nonrandomized trials; eight fair-quality cohort studies) assessed studies of early intervention involving direct provision of treatment to the child.
- Some young children receiving high-intensity, child-focused interventions over 8 months to 2 years demonstrated statistically significant improvements in cognitive and language outcomes compared to eclectic community-based interventions.

##### Parent Training

- Thirteen studies included parent training approaches (four good- and six fair-quality RCTs; two good- and one fair-quality cohort studies).
- Studies with parent training components reported some improvements in language, with inconsistent results for other outcomes.

##### Play/Interaction-Focused

- Twelve unique RCTs (three good and nine fair quality) addressed play or interaction-based approaches.
- Most studies targeted aspects of joint attention and reported statistically significant gains in joint attention skills in treatment groups compared to controls, typically over a short duration (8 to 12 weeks). Children in both treatment and comparison groups typically received early intervention in addition to the targeted intervention.
- This body of evidence for the effects of play-based interventions is limited due to very small studies, few total participants across all studies (n=483), and outcomes too heterogeneous to pool.

We identified 42 studies (reported in 55 publications) of good (n=12) and fair (n=30) quality addressing early intensive behavioral and developmental interventions.103-157 Early intensive behavioral and developmental interventions are the most commonly recommended approaches for young children. These approaches can either be “manualized,” in that a specific manual is developed and published and followed carefully, or more general, in which developmental approaches are applied in different ways. These interventions are based on the principles of ABA. ABA is an umbrella term describing principles and techniques used in the assessment, treatment, and prevention of challenging behaviors and the promotion of new desired behaviors. The goal of ABA is to teach new skills, promote generalization of these skills, and reduce challenging behaviors with systematic reinforcement. The principles and techniques of ABA existed for decades prior to specific application and study within ASD, and ABA provides the basis for many early intensive behavioral and developmental approaches.

The principles of ABA may be applied in models of care in which the provider works directly with the child, including, for example, the Early Start Denver Model (ESDM); University of California, Los Angeles (UCLA)/Lovaas-based interventions; preschool-delivered general ABA-based early intervention approaches, and the Learning Experiences and Alternative Program for Preschoolers and their Parents (LEAP) model. A total of 17 studies (Table 7) fall into this category (two good- and two fair-quality RCTs, one good- and four fair-quality nonrandomized trials, seven fair-quality prospective cohort studies, and one fair-quality retrospective cohort study).

Another model of care is early intensive interventions with parent-training components (Table 8), and these include parent-led ESDM, general home- or clinic-based early intensive intervention, Pivotal Response Training (PRT), the Assessment Evaluation and Programming System for Infants and Children (AEPS), the Developmental, Individual Difference, Relationship-based (DIR)/Floortime model, parent training in communication responsiveness, and More than Words. Thirteen studies addressed these interventions (four good- and six fair- quality RCTs and two good- and one fair-quality prospective cohort studies).

Finally, 12 studies took an approach that was play-based and focused on interaction between child and parent or child and provider.

These interventions are generally focused on improving cognitive and language outcomes, and the results are presented below by target outcome. Measures of adaptive behavior and ASD severity are also available for these interventions and are provided in Appendix F.

#### Studies of Direct Provision to Child Approaches: Cognitive Outcomes

Fifteen of 17 studies of ABA-based interventions provided data on cognitive outcomes associated with treatment, of which four were RCTs and 11 were nonrandomized trials or cohort studies. In 11 of the 15 studies, the comparator was “eclectic treatment,” which means that parents were obtaining treatment in the community for their children, but the investigators did not control what that treatment was. Seven of these 11 studies with eclectic comparison groups evaluated cognitive outcomes, and outcomes were improved in the early intervention group compared to eclectic in seven studies. Across all comparison groups (eclectic or other comparison group), the ABA-based intensive intervention resulted in statistically significantly greater cognitive improvements than did the comparator in 10 of 15 studies evaluating cognitive changes.

##### UCLA/Lovaas Approaches

The UCLA/Lovaas approach is a well-known treatment that is most commonly associated with the ABA method. UCLA/Lovaas-based approaches draw on ABA-derived principles and typically include high-intensity (>20 hours per week) one-on-one instruction with primary emphasis on discrete trial techniques. Discrete trial training introduces a stimulus (instruction/cue) to which a child may respond. Responses may be reinforced/rewarded, and the trial of stimulus-potential response-reward is repeated to develop mastery. These approaches also emphasize incidental teaching and generalization of skills to the home or other settings. Approaches that are considered UCLA/Lovaas may have some variation but all base their treatment on the UCLA/Lovaas manual.

Eight studies assessing UCLA/Lovaas-based models provide data to assess cognitive outcomes. Four of these eight studies compared UCLA/Lovaas models to eclectic or community-based treatments, two compared clinic-directed interventions to parent-managed interventions (parents identifying and directing ABA therapists), one compared a therapist-led to a parent-led approach, and one compared a high-intensity to a low-intensity intervention.

Overall, children in the treatment arms were more likely to improve significantly than children in the comparators. In three of the four studies that compared the treatment to eclectic treatment, cognitive measures were significantly improved in the UCLA/Lovaas groups compared to eclectic controls. In the fourth, there was no difference. The two studies comparing clinic-directed UCLA/Lovaas to parent-managed interventions demonstrated no significant difference in cognitive outcomes. The one study comparing a therapist-led UCLA/Lovaas model with parent-led reported significantly improved outcomes for the therapist-led arm. The study comparing high to low intensity found greater effects associated with the higher intensity intervention. Specific treatment effects varied and are described below.

UCLA/Lovaas vs. eclectic approaches. Three of the studies comparing the UCLA/Lovaas approach to eclectic approaches were nonrandomized trials, and the fourth was a prospective cohort study. Overall, cognitive outcomes were significantly improved in the UCLA/Lovaas groups compared to the control in three studies and not significantly different between groups in the fourth.

In one fair-quality nonrandomized trial (Peters-Scheffer 2011) comparing a UCLA/Lovaas model implemented in a specialized ASD preschool to specialized ASD preschool alone,114 cognitive outcomes measured on the Bayley Scales of Infant Development were significantly improved (p<0.01) in the UCLA/Lovaas group compared to control (treatment group baseline, 47.00 ± 10.33, followup, 55.83 ± 14.94; control group baseline, 45.73 ± 15.99; followup, 43.73 ± 16.74). All children in this study had concomitant intellectual disability in addition to an ASD diagnosis.

A second fair-quality nonrandomized trial (Eikeseth 2007) compared an intensive, school-based UCLA/Lovaas program with school-based eclectic treatment that included elements of multiple interventions, including the Treatment and Education of Autistic and Related Communication-Handicapped Children (TEACCH) model and occupational therapy.117, 118 Followup scores for individual cognitive outcomes (measured on the Bayley Scales, Wechsler Preschool and Primary Scale of Intelligence-Revised [WPPSI-R], or Wechsler Intelligence Scales for Children-Revised [WISC-R]) did not differ significantly between groups; however, gains from baseline to followup were significantly greater in the UCLA/Lovaas group compared to the eclectic group (mean cognitive score change, 17.15 ± 10.97 vs. 4.33 ± 7.55; p<0.01). Children in the treatment group were significantly more likely to have cognitive scores in the average range at followup than the eclectic group (7/13 children vs. 2/12; p<0.05). At followup of all participants roughly 31 months after treatment onset, cognitive gains continued to be significantly greater (p<0.05) in the UCLA/Lovaas group compared to the eclectic arm (mean gain, 25 vs. 7 points). Children in both groups continued with either UCLA/Lovaas or eclectic therapy, both at reduced intensity, during the followup interval.

One fair-quality prospective cohort study (Cohen 2006) compared intensive UCLA/Lovaas-based intervention delivered in the school and home to eclectic therapies available in the community and delivered primarily in the school.119 Cognitive skills measured on the Bayley Scales or WPPSI increased significantly in the UCLA/Lovaas group compared to the eclectic comparators (p<0.05), though mean cognitive scores increased in both groups (gain of 25 points in treatment group and 14 points in control). Twelve of the 21 children in the intervention group and seven of the 21 in the comparison group had IQs in the average range at followup (p=not significant).

Finally, one good-quality nonrandomized trial (Peters-Scheffer 2013) compared low-intensity (4 to 10 hours per week) UCLA/Lovaas-based intervention added to preschool programming for children with ASD and intellectual disability with eclectic, community-based intervention, including specialized preschool.121 Cognitive outcomes measured on the Mullen Scales of Early Learning improved in the treatment group at the 12-month but not 24-month assessment (effect size, 0.40) and did not improve at either time in the control group. Between-group differences were not significant.

Clinic-directed vs. parent-managed UCLA/Lovaas approaches. Two studies compared clinic-directed approaches to parent-managed care. In both studies, all children improved their scores on cognitive outcomes, but whether the treatment was directed by the clinic or managed by the parents was not associated with a difference.

The first, a good-quality RCT (Sallows 2005), compared intensive (mean of approximately 37 to 39 hours per week) clinic-directed UCLA/Lovaas therapy to UCLA/Lovaas-based therapy (approximately 31 to 32 hours/week) with therapists managed by parents, who set the number of therapy hours.122 Cognitive outcomes as measured on various age-appropriate tools (Bayley Scales of Infant Development-II, WPPSI-R, WISC-III) did not differ significantly between groups at baseline or followup. In analyses combining groups, mean full-scale IQ increased from a mean of 51 to 76 points, and children improved significantly on full-scale IQ, verbal IQ, and performance IQ from baseline in both groups (all p values <0.01).

An additional fair-quality nonrandomized trial compared a clinic-directed, home-based intensive UCLA/Lovaas-based model to a parent-managed model in which parents identified and managed tutors.115, 116 These tutors also received supervision from the same consultants involved in the clinic-directed model. Cognitive outcomes as measured on the Bayley Scales of Infant Development (for younger children) or the WPPSI-R improved from baseline to followup in both groups, with no significant group differences. In analyses combining groups, mean scores increased 16 points from baseline, with half of children gaining 15 or more points (range, 15 to 52 points), 39 percent gaining 1 to 14 points, 2 percent maintaining the baseline cognitive scores, and 9 percent losing 4 to 18 points.

Clinic- vs. parent-conducted UCLA/Lovaas approaches. One fair-quality RCT (Smith 2000) compared intensive, therapist-led UCLA/Lovaas-based intervention with intensive parent-led UCLA/Lovaas-based intervention to assess the ability of parents to provide the intensive approach relative to professional therapists. Cognitive outcomes on the Stanford-Binet Intelligence Scale or Bayley Scales of Infant Development were significantly improved in the therapist-led group compared to parent-led (therapist-led group intake IQ, 50.53 ± 11.18; followup IQ, 66.49 ± 24.08; parent-led group intake IQ, 50.69 ± 13.88; followup IQ, 49.67 ± 19.74; p<0.05).120

High- vs. low-intensity UCLA/Lovaas approaches. Finally, one fair-quality nonrandomized trial (Reed 2007) compared three models of high-intensity (>20 hours per week) ABA-based interventions to generic, low-intensity (<20 hours per week) early intervention.123 The high-intensity interventions included UCLA/Lovaas-based intervention; a verbal behavior model that used discrete trial training to target verbal responding and the ability to use language to request and name objects/events; and the Complete Application of Behavior Analysis to Schools (CABAS) approach. CABAS focuses on training teachers in multiple ABA techniques, including incidental teaching and reinforcement, and involves maximizing child-targeted “learn units” or opportunities to learn. The study assessed cognitive outcomes using the Psycho-Educational Profile-Revised and British Ability Scale. In comparisons of all high- versus low-intensity interventions, children in high-intensity programs improved significantly more in intellectual and educational functioning (p values <0.01) than did children in low-intensity programs. In comparisons among high-intensity interventions, children in the UCLA/Lovaas and CABAS groups had the greatest gains in intellectual functioning (p<0.05). Change scores for educational functioning were significantly higher for the CABAS group (effect size, 3.74; p<0.01) than the other high-intensity groups.

##### ESDM

ESDM is an approach directed to young children that integrates ABA-based early intervention approaches with developmental and relationship-based care, with specific activities involving interpersonal communication, engagement with real-life materials and activities, and parental use of the strategies in the home. ESDM is typically provided for approximately 30 hours per week and may be delivered in a child's home or clinic- or school-based settings by trained therapists and parents.

The ESDM approach has been assessed in one good-quality RCT and a followup study, with changes in cognitive scores a primary outcome.103, 104 Cognitive skills measured on the Mullen Scales of Early Learning's Early Learning Composite improved significantly in children in the ESDM group compared to children receiving eclectic, community-based interventions (mean gain of 15.4 vs. 4.4 points, respectively; p=0.018). At a 2-year followup, cognitive scores for children in the ESDM group had improved a mean of 17.6 points from baseline compared to a 7-point gain in the control group (p=0.044). The average starting cognitive score was 61.0 ± 9.2 for children in the intervention group and 59.4 ± 8.6 for children in the comparison group. The standard score on the Mullen Early Learning composite is 100 ± 15.

##### LEAP

Another ABA-based approach is the LEAP model, which integrates multiple interventions for children with ASD with modeling and social skills development mediated by typically developing peers in a preschool setting. The model incorporates elements of PRT; the Picture Exchange Communication System (PECS); positive behavior support; and naturalistic, incidental teaching, in which teachers use classroom interactions and a child's interest to guide teaching.

One fair-quality RCT (Strain 2011) evaluated the LEAP model and reported cognitive outcomes.112 Compared to children in preschools with teachers who received LEAP manuals and no specific instruction, children in preschools with teachers who received LEAP coaching and training gained significantly on cognitive measures (mean gain of 8.9 vs. loss of 1.8 points on the Mullen Early Learning Composite; p<0.01).

##### Preschool-Delivered Models

Preschool-delivered general ABA-based models combine elements of ABA techniques, such as one-on-one instruction using discrete trial techniques and incidental teaching, and typically deliver more than 20 hours per week of intervention. Approaches may draw from numerous ASD treatment types but focus primarily on ABA-based techniques.

Five of six studies assessing these approaches in preschools reported cognitive outcomes, and all five of these compared ABA-based intervention delivered in a preschool environment to eclectic therapies, some of which were school based. In four of the five studies, cognitive outcomes were significantly improved for the ABA groups versus the control arms; group differences were not significant in one study. We briefly summarize these studies below. Four of the five were fair- quality prospective cohort studies, and one was a fair-quality retrospective cohort.

The first prospective cohort study (Eldevik 2012) compared outcomes in children receiving ABA-based intervention in mainstream preschools to treatment as usual and measured cognitive outcomes with the Bayley Scales of Infant Development-II or III, Stanford-Binet-IV or V, or WPPSI-R.107 The ABA group had significantly improved intellectual functioning (p=0.004) compared to the control group (mean change in score, 15.1 ± 14.9 vs. 0.5 ± 9.5; effect size, 1.03 [95% CI, 0.34 to 1.72]). A second fair-quality prospective cohort study (Howard 2005) compared preschool-based ABA intervention to eclectic treatments received in public school classrooms and nonintensive early intervention classrooms.111 Cognitive outcomes as measured primarily on the WPPSI-R were significantly better in the ABA group compared to the other groups (difference in mean followup score for ABA group and mean of other groups combined, 24.42; p<0.01). Average scores for the ABA group were 58.54 at baseline and 89.88 at followup, compared to a comparison group mean of 68.81 at followup. On the WPPSI-R, children who score at 68 are in the bottom 5 percent of same-aged test takers. In contrast, children who score at 89 do as well or better than 27 percent of same-aged test takers, reflecting children's significantly improved ability to engage in testing and display their skills.

A third fair-quality prospective cohort study (Zachor 2007) comparing ABA-based preschool intervention to eclectic developmental intervention reported cognitive outcomes measured on the Bayley Scale of Infant Development-II and Stanford-Binet-IV scales for both groups combined.110 Cognitive outcomes were significantly improved in the ABA group compared to the eclectic group at followup.

A fair-quality retrospective cohort study (Flanagan 2012) compared outcomes for children enrolled in ABA-based intervention in preschool to outcomes in children on the program waiting list who were receiving eclectic therapies, including speech therapy, specialized or regular daycare, and low-intensity early intervention.109, 141 Cognitive skills were assessed using either the Mullen Scales of Early Learning, the Stanford-Binet-IV, or the WPPSI-III. Cognitive scores were higher in the ABA group compared to the control group at followup (mean, 55.80 ± 26.97 vs. 39.50 ± 18.93; p=0.002; effect size, 0.83). At followup, 18 percent of the 61 children in the ABA group versus 3.3 percent of the 61 children in the waitlist group had IQ scores in the average range (p=0.008).

Finally, a fourth fair-quality prospective cohort study (Itzchak 2011) comparing ABA-based intervention and eclectic-developmental interventions reported no significant group differences in followup cognitive outcomes measured on the Mullen Scales of Early Learning.105, 106

#### Studies of Direct Provision to Child Approaches: Language Outcomes

The other most commonly assessed outcome is language skills. ASD has a significant communication component, and children may present with difficulties in both expressive and receptive language. The ability to communicate with their children is often a parent-centered outcome. Several of the studies described above that reported on cognitive outcomes also reported on shifts in language. Ten additional studies provided data on language outcomes but not cognitive outcomes. Overall, 16 studies of ABA-based early intervention reported language outcomes, with more significant improvements in the ABA arms compared to control arms in 10 studies, and no significant between-group differences in six studies.

##### UCLA/Lovaas-Based Approaches

Seven of the eight studies also described above assessing UCLA/Lovaas-based models reported language outcomes. Two of the four studies that compared UCLA/Lovaas models to eclectic or community-based treatments reported significantly greater improvements in the treatment group, while no differences were observed in the other two. Two studies compared clinic-directed UCLA/Lovaas to parent-managed interventions, in which parents identified and managed ABA therapists. Language outcomes were not significantly different between groups in either of these studies. One study compared therapist- and parent-led UCLA/Lovaas models and reported significantly improved language outcomes in the therapist-led arm.

UCLA/Lovaas vs. eclectic approaches. In one fair-quality nonrandomized trial (Peters-Scheffer 2010) comparing a UCLA/Lovaas model implemented in a specialized ASD preschool to a specialized ASD preschool alone,114 language outcomes measured on the VABS-II Communication domain improved in both groups over time, with significantly greater gains (p=0.02) in the UCLA/Lovaas group compared to control (baseline communication score in treatment group, 26.92 ± 12.12; followup, 39.42 ± 15.39; baseline score in control group, 25.00 ± 10.00; followup, 29.95 ± 13.39).

One fair-quality nonrandomized trial (Eikeseth 2007) compared an intensive, school-based UCLA/Lovaas program to school-based eclectic treatment that included elements of multiple interventions, including TEACCH and occupational therapy.117, 118 Followup scores for individual language outcomes (measured on the Reynell Developmental Language Scales and VABS-II Communication domain) did not differ significantly between groups; however, gains from baseline to followup were significantly greater in the UCLA/Lovaas group compared to the eclectic group (change in Reynell Developmental Language Scales total score, 27.00 ± 20.41 vs. 1.08 ± 17.07; p<0.01; change in VABS-II Communication, 15.69 ± 16.89 vs. -1.58 ± 7.81; p<0.01). At followup of all participants roughly 31 months after treatment onset, VABS-II communication scores (Reynell Developmental Language Scales not measured at long-term followup) were significantly higher in the UCLA/Lovaas arm versus the control (mean, 78.5 ± 22.3 vs. 56.0 ± 16.3; p<0.01). Children in both groups continued with either UCLA/Lovaas therapy or eclectic therapy, both at reduced intensity, during the followup interval.

One fair-quality prospective cohort study (Cohen 2006) compared intensive UCLA/Lovaas-based intervention delivered in the school and home to eclectic therapies available in the community and delivered primarily in the school.119 Language outcomes measured on the Reynell Developmental Language Scales were not significantly different between groups at followup. Eight of the 21 children in the intervention group and four of the 21 children in the comparison group had language comprehension scores in the average range at followup (p=not significant). Nine children in the intervention group and six in the comparison arms also had expressive language scores in the average range (p=not significant).

One good-quality nonrandomized trial (Peters-Scheffer 2013) compared low-intensity (4 to 10 hours per week) UCLA/Lovaas-based intervention added to preschool programming for children with ASD and intellectual disability to eclectic, community-based intervention, including specialized preschool.121 Language outcomes were measured using the Early Social Communication Scales, Peabody Picture Vocabulary Test (which measured expressive language), VABS-II Communication domain, and Schlichting Test for Language Production. Receptive, but not expressive, language improved significantly in the UCLA/Lovaas group compared to control (p=0.04; effect size, 1.22), and group differences were not significant for any subscale of the early social communication measure. The UCLA/Lovaas group also improved significantly on the VABS-II Communication domain compared to the control group (p<0.004; effect size, 1.41).

Clinic-directed vs. parent-managed UCLA/Lovaas approaches. One fair-quality nonrandomized trial (Hayward 2009) compared a clinic-directed, home-based intensive UCLA/Lovaas model to a parent-managed model in which parents identified and managed tutors.115, 116 These tutors also received supervision from the same consultants involved in the clinic-directed model. Language outcomes as measured on the Reynell Developmental Language Scales improved from baseline to followup in both groups, with no significant between-group differences. In analyses combining groups, mean language comprehension age increased to 27.5 months and mean expressive language age increased to 26.95 months from means of roughly 21 months in each group at baseline.

A good-quality RCT (Sallows 2005) compared intensive (mean of approximately 37 to 39 hours per week) clinic-directed UCLA/Lovaas therapy to UCLA/Lovaas-based therapy (approximately 31 to 32 hours per week) with therapists managed by parents, who set the number of therapy hours.122 Language outcomes as measured on various tools, as age appropriate (Reynell Developmental Language Scales, Clinical Evaluation of Language Fundamentals, VABS Communication domain), did not differ significantly between groups at baseline or followup. In analyses combining groups, children improved significantly on receptive language and the VABS Communication domain from baseline (all p values <0.01).

Clinic- vs. parent-conducted UCLA/Lovaas approaches. In a fair-quality RCT (Smith 2000) comparing intensive, therapist-led UCLA/Lovaas-based intervention with intensive, parent-led UCLA/Lovaas-based intervention, overall language outcomes on the Reynell Developmental Language Scales were significantly improved (p<0.05) in the therapist-led group compared to parent-led (therapist-led group total Reynell score at intake, 28.60 ± 4.07; followup, 87.40 ± 46.21; parent-led group intake, 30.00 ± 6.34; followup, 61.33 ± 31.88).120 Scores on the Reynell Developmental Language Scales Expressive Language and Language Comprehension subscales did not differ significantly between groups, nor did scores on the VABS Communication domain.

##### ESDM

The ESDM RCT described above also reported language outcomes.103, 104 Receptive and expressive language measured on the Mullen Scales of Early Learning improved significantly in the ESDM group compared to the comparison arm (ESDM mean gains of 18.9 and 12.1 points vs. 10.2 and 4.0 points in comparison arm) at 2 years post-treatment (p values <0.05). In the ESDM group, children at an average of age of 23.9 months had an Early Learning Composite score (standard score [SS] mean, 100 [SD, 15]) of 59.4 (1st percentile). This corresponded to domain scores (T score mean, 50 [SD, 10]) of 21.1 (1st percentile) for language understanding (Receptive Language), 24.5 (1st percentile) for language use (Expressive Language), 33.2 (4th percentile) for nonverbal problem solving (Visual Reception), and 33.9 (4th percentile) for fine motor skills (Fine Motor). At 52.4 months, the ESDM group evidenced an Early Learning Composite score (SS mean, 100 [SD, 15]) of 78.6 (7th to 8th percentile). This corresponded to domain scores (T score mean, 50 [SD, 10]) of 40.1 (16th percentile) for language understanding (Receptive Language), 38.6 (12th percentile) for language use (Expressive Language), 41 (18th percentile) for nonverbal problem solving (Visual Reception), and 33.5 (4th percentile) for fine motor skills (Fine Motor). Children in the other treatment arm (community treatment) did not exhibit a statistically significant difference on their cognitive profile.

At an average age of 52.4 months at outcome assessment (e.g., 28.5 months later), children in the ESDM (treatment) group had new developmental age equivalents of approximately 44 months for Receptive Language; 43 months for Expressive Language; 46 months for Visual Reception; and 42 months for Fine Motor. The community treatment group, at an average age of 52.1 months at outcome (e.g., 29.1 months later), had new developmental age equivalents of approximately 37 months for Receptive Language; 36 months for Expressive Language; 41 months for Visual Reception; and 40 months for Fine Motor. Both groups improved, with the active treatment groups improving significantly more. A description of the potential impact of this level of change is provided in the Discussion.

##### LEAP

Two studies of LEAP assessed language outcomes with mixed results (improved outcomes in the full LEAP training arm compared to control in one study and no significant differences among groups in another study). One of these studies is also described above and included cognitive outcomes.

The fair-quality RCT described above (Strain 2011)112 reported that compared to children in preschools with teachers who received LEAP manuals and no specific instruction, children in preschools with teachers who received LEAP coaching and training gained significantly on language as measured by the Preschool Language Scales, 4th edition (mean gain of 18.5 vs. 9.4 points; p<0.01).

In addition, another fair-quality prospective cohort study (Boyd 2013) assessed language outcomes using a composite score derived from the Preschool Language Scales, 4th edition; Mullen Scales of Early Learning Expressive and Receptive language scales; and VABS-II Expressive and Receptive Communication scales.113 The study compared outcomes in children with ASD enrolled in three types of preschools: 1) those using the LEAP model; 2) those using the TEACCH model, which uses elements such as visual schedules and structured learning environments to promote children's engagement and learning; and 3) those not using any specific model. Communication composite scores improved significantly in all three groups from baseline (all p values ≤0.05), but between-group differences were not significant.

##### Preschool-Delivered Models

All six studies that assessed ABA models in preschools reported language outcomes, and all of these compared ABA-based intervention delivered in a preschool environment to eclectic intervention. In five of the six studies, language outcomes were significantly improved for the ABA group, while group differences were not significant in one study. We briefly summarize these studies below.

Four studies measured outcomes on the VABS Communication domain.105-109 All four were cohort studies comparing ABA-based intervention to eclectic comparators. In three of the four studies, the treatment group demonstrated more improvement in language than the comparison. In one study, the mean change score for children receiving the treatment was 8.6 ± 14.6 compared to 0 ± 12.6 in the comparison group. The study reported p-value for difference was 0.034.^107^ In the second study, the difference was statistically significant at p<0.05, and an effect size on the communication subscale was 1.08.^108^ A third study compared outcomes for children enrolled in ABA-based intervention in preschool to children on the program waiting list, who were receiving eclectic therapies including speech therapy, specialized or regular daycare, and low-intensity early intervention.109 Language skills were significantly improved in the ABA group versus control group (mean, 46.60 ± 29.92 vs. 30.33 ± 16.98; p=0.006; effect size, 0.56) at followup. Nonetheless, another similar study demonstrated no difference.105, 106

One fair-quality prospective cohort study (Howard 2005) compared preschool-based ABA intervention to eclectic treatments received in public school classrooms and nonintensive early intervention classrooms.111 Language outcomes in this study were measured primarily on the Reynell Developmental Language Scales. Language outcomes were significantly improved for the ABA group versus the other groups (receptive language difference in mean followup score for ABA group and mean of other groups combined, 21.73; P<0.01; expressive language difference in mean followup score for ABA group and mean of other groups combined, 23.21; p<0.01). These significant improvements in receptive and expressive language reflect an improved ability for children to follow instructions, identify objects, and use words and gestures to functionally communicate. This in turn allows therapists to build even more broadly on children's language abilities to teach more complex communication skills.

Finally, an additional fair-quality prospective cohort (Zachor 2007) comparing ABA-based preschool intervention to eclectic developmental intervention reported language outcomes measured on the ADOS language and communication subscale.110 Outcomes were significantly improved for the ABA group compared to the control (mean, 7.2 ± 4.1 vs. 9.7 ± 3.0; p<0.01).

#### Studies of Parent Training Approaches: Cognitive Outcomes

Another group of studies (n=13) focused on the application of ABA-based methods via the parents. In these interventions, the parents are trained in an ABA approach and implement it at home. Five of these 13 studies addressed cognitive outcomes. Outcomes did not differ significantly between groups in four studies, and cognitive outcomes were significantly improved in the treatment group compared to the eclectic control group in one study.

##### Parent-Delivered ESDM

As described above, ESDM integrates ABA-based early intervention approaches with developmental and relationship-based approaches that involve interpersonal communication, engagement with real-life materials and activities, and parental use of strategies in the home. ESDM may be delivered in a child's home by trained therapists or parents. One fair-quality RCT (Rogers 2012) compared a parent-delivered ESDM model, in which parents received therapist-led training and coaching in using ESDM techniques with their children, to community-based treatments.129, 130 At followup, cognitive outcomes as measured on the Mullen Scales of Early Learning's Early Learning Composite did not differ significantly between groups, though both groups improved from baseline (effect size in ESDM group, 0.44; effect size in control group, 0.37).

##### AEPS

AEPS is a developmental curriculum that sets targeted goals for children based on their developmental profile. It promotes engaging and sharing attention and imitation of skills and actions. This approach was studied in one good-quality RCT (Landa 2011) that compared an intervention combining AEPS, parent training sessions, and additional therapist-led intervention to promote joint attention, imitation of social actions, and sharing positive affect to AEPS plus parent-training sessions alone.124, 125 Nonverbal IQ as rated on the Mullen Scales of Early Learning did not differ significantly between groups at followup. At a followup of the enhanced intervention group at roughly 72 months of age (mean age at baseline, 27 months), overall IQ was significantly improved from baseline (mean change, 21.4 ± 22.9; effect size, 1.02; p<0.001).

##### Clinic- and/or Home-Based Early Intervention

These models incorporate elements of ABA, discrete trial training, one-on-one training, and naturalistic or incidental teaching in comprehensive programs based in specialized centers and/or offered in the home. Programs train parents in techniques to use in the child's natural environments (such as the home), and intervention is provided in centers and the home by therapists and parents for 20 to 40 hours per week.

Two studies that used clinic- and/or home-based models compared to different comparison groups provided data on cognitive outcomes. In one good-quality prospective cohort study (Strauss 2012), children in the parent-training arm showed a greater increase in mental development compared to children receiving eclectic therapies (change on the Griffiths Mental Development Scales for Ages 2 to 8, 4.639 in the parent training group vs. 0.332 in eclectic group; p=not reported).126, 127 In addition, a fair-quality prospective cohort study (Reed 2012) compared four early intervention models: home-based early intervention using ABA principles, specialized daycare, a low-intensity special education one-on-one teaching program, and home-based therapist-delivered intervention plus parent training.132 Groups did not differ on measures of intellectual functioning (measured on the Psycho-Educational Profile-Revised) at followup. The ABA group did have significantly better scores on measures of educational functioning (measured on the British Ability Scale) compared to the other groups (p<0.05).

##### Parent Training in Communication Responsiveness

Intervention models focusing on parental responsivity target parent behaviors and responses in order to promote the development of language and social skills. Such models emphasize shared engagement with the child and parental sensitivity to the child's communication attempts. Models typically promote development of early language skills, such as joint attention, and build upon skills as the child's social communication abilities increase. A fair-quality RCT (Drew 2002) assessed a parent-training intervention to promote early communication skills compared to services available in the community and reported no significant differences between groups at followup on nonverbal IQ (Griffiths Scale of Infant Development).136

#### Studies of Parent Training Approaches: Language Outcomes

Twelve of 13 studies with parent training components reported language outcomes. In three studies, language outcomes were significantly improved in the treatment arms compared to control, and groups did not differ significantly in nine studies. In two of these nine studies, language outcomes as rated by external assessors did not differ between groups, but parent-rated language outcomes were significantly improved in the treatment group compared to the control group.

##### Parent-Delivered ESDM

The fair-quality RCT described above also provided outcomes data on language acquisition.129, 130 Language outcomes measured on the MacArthur-Bates Communicative Development Inventory and VABS Communication domain did not differ significantly between groups at followup.

##### AEPS

The AEPS study described above also provided data on communication outcomes.124, 125 Socially engaged imitation (imitation paired with eye contact with examiner) measured by coding videotapes of child and therapist interaction was significantly higher in the enhanced intervention group compared to control, but initiation of joint attention and shared positive affect did not differ significantly between groups. Expressive language outcomes measured on the Mullen Scale did not differ significantly between groups at followup. At followup of only the enhanced intervention group at roughly 72 months of age (mean age at baseline, 27 months), VABS Communication domain scores were significantly improved from baseline (mean change, 12.7 ± 19.4; effect size, 0.81; p<0.001).

##### Clinic- and/or Home-Based Early Intervention

Three studies used clinic- and/or home-based models compared to different comparison groups, and two of these reported language outcomes. One study compared a clinic- and home-based program to eclectic therapies and reported improved language outcomes in the center/home-based arm compared to control. One study compared a home-based program that incorporated parent training to a center-based variant of the program and to a waitlist control group and reported significantly higher scores in the center-based group compared to home-based for one language measure.

One good--quality RCT (Roberts 2011) compared a home-based program that incorporated parent training to a center-based variant of the program incorporating small-group intervention and parent training and to a waitlist control group.131 Children in the waitlist group were receiving community-based interventions (interventions not specified). Children in the center-based group improved significantly on Reynell Developmental Language Scale comprehension standard scores compared to the home-based arm (mean difference, 7.3 [95% CI, 0.7 to 13.9]; p=0.03), but scores in the expressive language subscale did not differ among groups, nor did scores on the VABS Communication domain. Scores on the Pragmatics Profile of Everyday Communication also did not differ significantly among groups.

In one good-quality prospective cohort study (Strauss 2012), children in the parent-training arm showed a greater increase in language comprehension measured on the MacArthur Communication Development Inventories (change, 6.460 vs. 3.885; p-value not reported) and in language production (change, 3.410 vs. 1.69; p-value not reported) compared to children receiving eclectic therapies.126, 127

##### Parent Training in Communication Responsiveness

Intervention models focusing on parental responsivity target parent behaviors and responses in order to promote the development of language and social skills. Such models emphasize shared engagement with the child and parental sensitivity to the child's communication attempts. Models typically promote development of early language skills such as joint attention and build upon skills as the child's social communication abilities increase.

Five studies assessed parent training in communication responsiveness and reported language outcomes. Four of these studies compared the parent training arm to eclectic/community-based interventions or treatment as usual and one compared a parent training arm with instruction provided by a therapist to parent training with instruction provided via a video. Language outcomes at followup were significantly improved in the active parent training arm compared to control in two studies and did not differ significantly between groups in two studies. In one study, language outcomes evaluated by assessors were not significantly different between groups, but parent ratings favored the treatment group versus control. We summarize the studies briefly below.

One good-quality RCT (Aldred 2011) compared a parent training intervention focusing on social communication and parental responses to communication with routine, community-based care.137, 138 Expressive language measured on the MacArthur-Bates Communicative Development Inventory was significantly improved in the treatment arm compared to control (mean scores at followup, 199.4 vs. 33.1; p<0.001). Language comprehension and VABS Communication domain scores did not differ significantly between groups.

One fair-quality RCT (Green 2010) comparing a parent responsivity-focused intervention to eclectic treatment as usual reported no group differences on blinded assessor-rated language measures (Preschool Language Scale, coded parent-child interactions), but in parent-rated measures, the treatment group showed significant improvement on MacArthur-Bates Communicative Development Inventory Receptive and Expressive language scales and the CSBS.135 Teacher-rated measures (VABS Communication domain) did not differ significantly between groups.

A good-quality prospective cohort (Keen 2010) compared a professionally supported parent training intervention to a self-directed video-led program.139 Both programs focused on parental responsivity to child communication and integrating intervention into family routines. Followup scores on CSBS-Developmental Profile social communication measures were significantly more improved in the professionally supported arm compared to the self-directed arm on parent-rated measures but not observer-rated measures.

A fair-quality RCT (Drew 2002) assessed a parent training intervention to promote early communication skills compared to services available in the community and reported no significant differences between groups at followup on language measures (MacArthur Inventory), though more children in the parent training group compared to control moved from being nonverbal to having single-word or phrase speech (n=7 vs. 3; p<0.05).136 A fair-quality RCT (Oosterling 2010) replicated this intervention model in an ASD preschool setting, comparing parent training plus ASD preschool to ASD preschool alone.133 No language outcomes (measured on the MacArthur-Bates Communicative Development Inventory) differed significantly between groups at followup.

##### DIR/Floortime-Based Interventions

The DIR/Floortime model focuses on understanding a child's challenges, strengths, and level of development to target relationship building, social and communication skills, and problem solving appropriate for a given child. DIR/Floortime programs typically include a variety of therapies, including speech and language therapy, occupational therapy, and incidental and naturalistic teaching that follows a child's interests.

One fair-quality RCT (Casenhiser 2013) evaluating an intervention based on the DIR/Floortime model and integrating parent training compared to community-based treatments reported no significant between-group differences for language outcomes assessed using the Preschool Language Scale-4 or Comprehensive Assessment of Spoken Language.128 Initiation of joint attention was significantly improved in the DIR/Floortime group compared to control at followup (p<0.001; effect size, 1.02).

##### More Than Words

The More than Words model emphasizes building parents' skills in interacting with the child and engaging the child in communication opportunities arising in activities or events occurring in the child's natural environment. The program focuses on teaching parental sensitivity to a child's developmental level and creating opportunities to promote communication. It targets two-way interaction, social communication skills, and improving understanding of language.

One fair-quality RCT (Carter 2011) compared language outcomes measured on both the Early Social Communication Scales and through coding of parent-child play for children receiving More than Words and children receiving treatment as usual.134 Language outcomes were not significantly different between groups at followup.

##### PRT

PRT focuses on “pivotal areas” of language and communication skill development, including responsiveness, initiating communication, motivation to communicate, and self-regulation to attempt to produce wider improvements in language and other skills. PRT uses ABA techniques such as incidental teaching in natural environments, reinforcement, and motivation to promote communication.

One good-quality RCT (Schreibman 2013) evaluated PRT compared to the PECS, which uses picture cards to promote communication in children with limited spoken language.140 Both interventions targeted language use, either verbally or using picture cards. Language outcomes measured on the Mullen Scales of Early Learning, Expressive One-Word Picture Vocabulary Test, VABS Communication domain, and MacArthur-Bates Communicative Development Inventory did not differ significantly between groups, though both groups improved from baseline to followup. At followup, 78 percent of children in both groups had acquired at least 10 spoken words.

#### Studies of Play-Based Interventions

Among the 12 studies addressing play-based approaches, we considered three studies to be of good quality154-157 and 10 of fair quality.142-153 Studies were conducted in the United States143, 145, 147-157 and Europe144, 146 and included a total of 483 participants between the ages of 21 and 82 months. Intervention duration ranged from 6 to 16 weeks; three studies reported long-term (≥12 months postintervention) followup of participants.147, 149-152, 154 While all studies used approaches incorporating focused interactions directed by teachers, interventionists, or parents/caregivers, studies typically addressed outcomes related to joint attention, play, imitation, or child/parent communication (Table 9). Participants in play/interaction studies often received other early intervention services in addition to the targeted intervention, making disentangling effects of the intervention difficult, but studies reported positive effects for preschool children with ASD, particularly when targeting joint attention skills themselves as well as related social communication and language skills.

Ten of 12 studies reported outcomes related to joint attention, and outcomes were significantly improved in the treatment group compared to the control group in nine studies; outcomes did not differ between groups in one study. Data are more limited about the ability of play-based studies to improve broad developmental skills (such as cognition, adaptive behavior, and ASD symptom severity) beyond communication and language gains over time. In one study, training regarding imitation skills showed positive results in improving not only imitation skills, but potentially other social communication skills such as joint attention as well. Studies focused on changing parental responses to child behavior and communication reported limited effects on language.

### KQ 4a What Is the Effect of Intervention Timing (by Age and in Relation to the Establishment of a Definitive Diagnosis) on Treatment Outcomes?

In some early intervention studies, younger age has been associated with greater improvement. For example, greater language gains were seen in children who were younger with lower functioning levels at baseline in one RCT of an approach incorporating parent training.138 In a retrospective cohort study of a community-based early intervention program, outcomes were related to age at enrollment, treatment duration, and higher baseline adaptive scores. A significant interaction emerged between age at enrollment and group membership, with younger starting age influencing outcomes for the treatment group but not the waitlist control.109 Findings are not entirely consistent across age groups. Such differences may reflect variations in subgroups of participants responding differentially to treatment due to factors that are not fully understood or described in the research. Further, as children develop, the specific targets of intervention often shift (e.g., studies later emphasizing adaptive/social outcomes over IQ/language targets) or samples participating in treatment may reflect differential symptom profiles.

Additional analyses of some children in this earlier Canadian study109 (overlap not clear) assessed the effects of baseline age and IQ on cognitive and adaptive outcomes in 207 children, and, in a separate analysis of matched older and younger children, effects of baseline age on the same outcomes.141 In the initial retrospective analysis of 207 children, participant ages at intake ranged from 2 to 14.5 years, IQ from 10 to 104, and mental age from 3 months to roughly 7.5 years. Higher baseline IQ and younger age were significantly associated with greater cognitive rate (pre-post change in mental age/time in intervention) and with higher IQ at followup (all p<0.001), but change in IQ was not significantly associated with higher initial IQ. Higher baseline IQ was also associated with higher adaptive behavior scores at followup (p<0.001), but age was not a significant predictor. Longer duration of intervention was associated with slower rate of IQ and adaptive behavior development (p values ≤0.01); however, as this analysis was not prospective, the children who received more intervention could have been making slower progress. In the analysis of older (n=60; age at baseline, 6 to 13.58 years) and younger (n=60; age at baseline, 2.08 to 5.92 years) children matched on developmental trajectory (i.e., number of intervention hours, baseline IQ, and adaptive behavior), younger children had significantly better followup IQ outcomes compared to the older group. Younger children gained an average of roughly 17 IQ points (effect size, 0.80) while older children gained an average of 2 points. Cognitive rate improved significantly for younger (effect size, 3.19) but not older children. Both groups improved over time in adaptive behavior, but differences between groups were not significant (improvement of 4 points in younger children and 5 points in older children).

### KQ 4b What Is the Effect of Severity of ASD (as Measured in Each Study) on Treatment Outcomes?

#### ASD Severity and Diagnoses

In some studies, children with lower symptom severity or less severe diagnoses improved more than participants with greater impairments. In an RCT assessing ABA-based early intervention, lower baseline ASD severity was associated with parent-reported cognitive and adaptive growth for children who received eclectic versus ABA intervention, but not with standardized test scores.105, 106 A prospective cohort study of preschool-based early intensive intervention reported that children in the early intervention group with PDD-NOS or Asperger diagnoses (but not ASD) had greater gains in overall adaptive behavior, communication, and daily living skills.107

#### Adaptive Behavior

Studies reported mixed findings related to outcomes associated with baseline adaptive behavior. In one retrospective cohort, positive outcomes in both the early intervention and the waitlist control groups were related to higher baseline adaptive scores.109

#### Language/Communication

The impact of language skills and attention to objects (vs. people) were assessed in two studies. In one RCT of the More Than Words program, the treatment group showed differential effects on child communication depending on children's baseline object interest; children with lower levels of baseline object interest had greater growth in communication skills, whereas children with higher levels of object interest showed attenuated growth.134 In another study of play-focused intervention, children with baseline expressive language abilities below 14.7 months showed greater gains in language in the intervention group versus control (effect size, 0.25 for 24 children with low language skills).147

### KQ 5 What Are the Harms of Treatment of ASD in Young Children?

No studies of behavioral interventions reported harms.