# Methods

## Scope and Purpose

In this review, we systematically reviewed the evidence on screening test accuracy and early treatment effectiveness for ASD in young children, focusing on both benefits and harms of potentially implementing screening for ASD in primary care. The research plan for the review was posted for public comment for 4 weeks and revised based on this input; the final research plan was posted on the USPSTF Web site. We explicitly focused on studies that investigated nonselective screening of young (<36 months of age), low-risk populations (e.g., universal screening, not specific research paradigms such as infant sibling work). We therefore excluded studies of measures primarily used and studied in populations that have been preidentified as having ASD, or identified as having some sort of developmental delay either by parents or clinicians, although this is a large body of literature. We included studies of treatments relevant for very young children with ASD (ages 0 to 4 years) and required that studies include a comparison group and at least 10 total children with ASD. We also reviewed contextual issues from a broader health systems perspective to describe the major issues regarding implementation of screening. Box 1 outlines screening tools used in included studies. Although additional ASD screeners are published and in use, for this review we only considered tools for which there was available research regarding use in, or use in a close analogue of, unselected primary care screening.

Box 1 ASD Screening Tools Used in Studies Included in the Review

Screening Tool | Format | Administration Time | Key Characteristics
Checklist for Autism in Toddlers (CHAT; 1992) | Parent-rated scale + Professional observation | 5 minutes | - Targets children at 18 months old; - Assesses communication, joint attention, pretend play using yes/no questions; - First screener systematically assessing early ASD identification; - No longer in common use
Modified Checklist for Autism in Toddlers (M-CHAT) with and without M-CHAT Follow-up interview (M-CHAT/F; 2001) | Parent-rated scale + Follow-up interview | 5-10 minutes | - Targets children 16-30 months old; - Assesses communication, joint attention, pretend play; - Includes follow-up interview that was used in most but not all studies.
Modified Checklist for Autism in Toddlers, Revised with Follow-up (M-CHAT-R/F; 2014) Revision of M-CHAT/F | Parent-rated scale + Follow-up interview procedure | 5 minutes | - Targets young children 16-30 months of age; - Assesses communication, joint attention, pretend play; - Offers explicit follow-up procedures based on scores from both instrument and follow-up interview
Infant Toddler Checklist (ITC; 2002) | Parent-rated scale+ parent follow-up interview | 5-10 minutes | - Targets children 9-24 months old; - Screener has available norms across developmental ages for risk
Early Screening of Autistic Traits (ESAT; 2006) | Parent-rated scale + clinician observation | 5-10 minutes | - Measure originally developed in Dutch and used primarily in European studies; - Targets children 14-15 months old; - Requires pre-screening in clinical setting followed by in-home parent-completed questionnaire
First Year Inventory/First Year Inventory-Lite (FYI – L; 2003) | Parent rated scale | 5-10 minutes | - Targets children at 12 months of age; - Assesses skills regarding communication, joint attention, socialization, and sensory regulation
Social Attention and Communication Study Checklist (SACS; 2010) | Clinician rated scale | Unknown | - Designed for repeated assessment of children at ages 8, 12, 18, and 24 months old; - Trained nursing providers conduct behavioral observations during informal interactions; - Measures markers of social interaction, play skills, and verbal and nonverbal communication
Young Autism and other developmental disorders Checkup Tool (YACHT; 2009) | Parent-rated scale, + Professional observation + Child Performance | 5-20 Minutes | - Japanese measure targeting 18 month old children; - Assesses early social communication markers via parent-report, clinician observation, and brief testing.

ASD=autism spectrum disorder.

This review will be used to inform USPSTF recommendations on ASD screening in primary care settings.

## Key Questions and Analytic Framework

We determined initial key questions (KQs) in consultation with clinical experts and USPSTF members. KQs were also posted to the USPSTF Web site for public comment and revised as needed. We addressed the following final key questions:

1. Is screening for ASD conducted in children 12 to 36 months old associated with improved short- and long-term outcomes?
2. What are the performance characteristics (e.g., sensitivity, specificity, PPV, and negative predictive value [NPV]) of ASD screening tests in children 12 to 36 months old?
  a. Do certain risk factors (e.g., prematurity or having a sibling diagnosed with ASD) modify the performance characteristics of ASD screening tests?
  b. Does the age at which ASD screening is performed modify the performance characteristics of ASD screening tests?
  c. Do other characteristics of the child or family (e.g., intellectual disability, socioeconomic status [SES], literacy level, insurance status, race/ethnicity, sex, primary language spoken in home, limited English proficiency) modify the performance characteristics of ASD screening tests?
3. What are the harms (e.g., distress, potential misclassification) of ASD screening for the child and family?
4. What is the effect of interventions targeting young children (in preschool and elementary school) on the following outcomes: core ASD symptoms, cognitive and intellectual functioning, language and communication skill development, challenging behavior, adaptive behavior, educational placement/achievement, and quality of life for the child and family?
  a. What is the effect of intervention timing (by age and in relation to the establishment of a definitive diagnosis) on treatment outcomes?
  b. What is the effect of severity of ASD (as reported in each study) on treatment outcomes?
5. What are the harms of treatment for ASD in young children?

The analytic framework (Figure 1) outlines clinical logic through which children being screened for ASD would proceed in order for there to be positive health outcomes as a result. In short, unselected young children would be accurately screened for ASD and, through appropriate diagnostic evaluation and early treatment, would experience improved developmental and other health-related outcomes, with few or minimal harms as a result of the entire process. Numbers in circles on the diagram illustrate KQs in the process.

Figure 1 Analytic Framework

ASD=autism spectrum disorder.

Note: Numbers in circles on the diagram refer to key questions.

This figure is the analytic framework that depicts the five Key Questions (KQs) to be addressed by the systematic review. The figure illustrates how screening in unselected children ages 12 to 36 months may improve health outcomes (KQ 1) and result in the identification of individuals with ASD (KQ 2) who may receive interventions. Interventions may result in changes in health outcomes as well (KQ 4). The analytic framework also depicts the possible adverse events occurring after screening (KQ 3) or treatment (KQ 5).

## Data Sources and Searches

### Search Strategy

#### Databases

A librarian employed search strategies provided in Appendix A to retrieve research on screening for ASD in young children and interventions for young children with ASD. All strategies were peer reviewed by a second librarian. Our primary literature search for screening-related studies employed four databases: MEDLINE® via the PubMed interface, PsycINFO (psychology and psychiatry literature), the Educational Resources Information Clearinghouse, and the Cumulative Index of Nursing and Allied Health Literature (CINAHL) database. Our search for intervention studies used the same databases with the exception of CINAHL. In our tests of the strategies, searching CINAHL did not retrieve any unique treatment studies, thus we did not use it for the treatment search.

Our search strategies used a combination of subject heading terms appropriate for each database and key words relevant screening or intervention for ASD. We limited searches to literature published since 2000 to ensure that screening methods and interventions used currently would be represented. We also manually searched the reference lists of included studies and of recent narrative and systematic reviews and meta-analyses addressing ASD screening or intervention in young children with ASD.

#### Prior Systematic Reviews and Meta-Analyses

We identified systematic reviews and meta-analyses retrieved by the searches for primary literature as well as through scanning the reference lists of included studies. We included summaries of reviews and meta-analyses we rated as good quality (see Quality Assessment below).

#### Search Terms and Dates

Controlled vocabulary terms served as the foundation of our search for screening-related literature in each database (e.g., MEDLINE vocabulary terms including mass screening, early diagnosis), complemented by additional keyword phrases (e.g., screening, identification). To locate intervention-related studies, we used the search strategy employed in our prior review of therapies for children with ASD.55 The search used both controlled vocabulary and keyword terms (Appendix A). We also limited searches for screening and intervention studies to items published in English and from 2000 to the present. Our searches were done between January and December 2013 for screening literature and December 2013 for intervention studies. We updated the MEDLINE search for screening and intervention studies in August 2014. We imported all citations into an electronic database.

## Study Selection

### Inclusion and Exclusion Criteria

We developed criteria for inclusion and exclusion in consultation with our Medical Officer and USPSTF members (Table 1).

Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Definition of Disease | Clinical diagnosis of autism spectrum disorder (ASD)
Populations
KQ1-3 | Young children ages 12 to 36 months undergoing [underlined: screening] for ASD | Studies that exclusively focus on infants or older children or adults or that assess general developmental screening
KQ 4-5 | Young children ages 0-12 years undergoing [underlined: intervention] for ASD | Studies of treatments for adolescents or adults
Interventions
KQ 1 | Tools and approaches used specifically to screen for ASD | Studies of screening for other conditions, general developmental screening or genetic or biomarker screening
KQ 2 | Tools and approaches used specifically to screen for ASD | Studies of screening for other conditions, general developmental screening or genetic or biomarker screening
KQ 3 | Tools and approaches used specifically to screen for ASD | Studies of screening for other conditions, general developmental screening or genetic or biomarker screening
KQs 4-5 | Interventions for ASD directed to children 0-5 years | Studies of interventions directed to older children, adolescents or adults as these would not follow from screening; medication interventions not relevant to young children
Comparators
KQs 1, 2, 3 | No screening or alternate screening approaches when comparing two or more approaches
KQs 4,5 | Placebo, other intervention, no intervention | Noncomparative studies
Outcomes
KQ 1 | Timing of referral/evaluation, diagnosis, access to intervention; core ASD symptoms; cognitive and intellectual functioning; language/communication skill development; challenging behavior; adaptive behavior; educational placement/achievement; quality of life for child and family assessed in preschool and elementary school age groups | Short term outcomes such as changes in joint attention
KQ 2 | Performance characteristics of ASD screening approaches | Studies that do not allow calculation of performance characteristics
KQ 3 | Harms from ASD screening (e.g., labeling, family distress)
KQ 4 | Core ASD symptoms, cognitive and intellectual functioning, language and communication skill development, challenging behavior, adaptive behavior, educational placement/achievement, and quality of life for the child and family | Short term outcomes such as changes in joint attention
KQ 5 | Harms of ASD treatment (e.g., worsening of behavior, other unintended consequences)
Setting
KQ 1-3 | Primary care settings and primary care referable settings, early intervention and education settings | Studies not conducted in one of the following countries, rated as “very high human development” on the United Nations Development Program's International Human Development Index (HDI): Andorra, Argentina, Australia, Austria, Bahrain, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong (China), Hungary, Iceland, Ireland, Israel, Italy, Japan, Republic of Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States
KQ 4-5 | Clinical, educational, early intervention, or home settings
Study Designs
KQ 1-3 (benefits or harms of screening, screening performance) | Any study design except single case reports | Single case reports
KQ 4-5 (benefits or harms of intervention) | Any comparative study design targeting young children with ASD, including at least 10 children with ASD; Good quality systematic reviews | Single case reports Studies with <10 children with ASD Studies included in prior comprehensive systematic review

ASD=autism spectrum disorder; KQ=key question

#### Criteria for Screening Studies

Screening-related studies needed to include at least two individuals (i.e., excluding single case reports) screened for ASD between the ages of 12 and 36 months. We required that studies include undiagnosed populations or populations without suspected developmental delay (i.e., we excluded studies in which the majority of children had an already identified concern about potential developmental delay by parents or clinicians underlying referral for screening/evaluation) or who were already diagnosed with ASD. There is an additional body of research on assessing the ability of ASD screening tests to accurately identify children with ASD in groups of children suspected as having some sort of delay, and as expected, the test performance characteristics are better in these studies than those seen in a general screening population. There is also a body of evidence in which samples are selected that include children with known diagnoses of ASD; these are intended to assess the ability of the screeners to discriminate, but we do not consider that the performance characteristics would apply to the primary care population. None of these scenarios reflects screening in the absence of any concern in the primary care office, in which many children are unrecognized as having symptoms of delay.

We assessed both intermediate and health-related outcomes. Intermediate outcomes included timing of referral and diagnosis and timing of access to intervention. Health-related outcomes included effects on core ASD symptoms, language and communication skill development, and quality of life for the child and caregiver. Screening studies had to take place in primary care or primary care relevant settings.

#### Criteria for Treatment Studies

To complete the clinical logic of screening to achieve earlier diagnosis and treatment in order to achieve improved health outcomes, we updated a previously published review of treatment for children with ASD55 by supplementing it with newer literature meeting the following criteria: 1) treatment studies needed to include at least 10 individuals with ASD; 2) report on an intervention aimed at young children with ASD (between the ages of 0 and 5 years) and include a comparison group; and 3) studies had to evaluate outcomes related to core ASD symptoms, cognitive and intellectual functioning, language and communication skill development, challenging behavior, adaptive behavior, educational placement/achievement, harms of intervention, or quality of life for the child and family. We included studies with any length of followup and in any setting (clinic, home). We briefly summarize findings of studies addressing interventions under KQ 4; detailed results can be found in the full systematic review.

### Screening of Studies

Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it for full text assessment.

Two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. The group of abstract and full text reviewers included expert clinicians and health services researchers.

## Quality Assessment and Data Extraction

### Data Extraction and Data Management

The staff members and clinical experts who conducted this review jointly developed the evidence table, which was used to summarize data from the studies. We modeled the table on USPSTF methods guidelines and designed the table to include issues of study design, descriptions of the study populations, description of the screening process or intervention, and baseline and outcome data on constructs of interest.

One team member initially entered information into the evidence table. Another member of the team also independently reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The full research team met during the article extraction period and discussed issues related to data extraction (e.g., optimal level of detail in the description of the screening technique or intervention, determining key population characteristic to include). In addition to outcomes related to screening performance and intervention effectiveness, we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events. The final evidence table is presented in Appendix C. Studies are presented in the evidence table alphabetically by the last name of the first author within each year.

### Quality (Risk of Bias) Assessment of Individual Studies

#### Screening Studies

We assessed the quality of screening studies using design-specific quality criteria based on the USPSTF methods.

#### Intervention Studies

We assessed the quality of intervention studies using methods previously developed for systematic reviews of interventions for children with ASD.55 We evaluated the quality of studies in the domains below using specific questions to evaluate a study's conduct. We rated each domain individually and combined them for an overall quality level. Three levels were possible: good, fair, and poor.

##### Study Design

1. Did the study employ a group design (have a comparison group)?
2. Were the groups randomly assigned?
3. If no, was there an appropriate comparison group?
4. If yes, was randomization done correctly?

##### Diagnostic Approach

1. Was a valid diagnostic approach for ASD used within the study, or were referred participants diagnosed using a valid approach?
  a. A clinical diagnosis based on the DSM, in addition to the Autism Diagnostic Interview-Revised (ADI-R) and/or ADOS assessments.
  b. A combination of a DSM clinical diagnosis with one other assessment tool; or the ADOS assessment in combination with one other assessment tool.
  c. Either a clinical DSM-based diagnosis alone or the ADOS assessment alone.
  d. Neither a clinical DSM-based diagnosis nor the ADOS assessment.

##### Participant Ascertainment

1. Was the sample clearly characterized (e.g., information provided to characterize participants in terms of impairments associated with their ASD, such as cognitive or developmental level)?
2. Were inclusion and exclusion criteria clearly stated?
3. Do the authors report attrition?
4. Were characteristics of the dropout group evaluated for differences with the participant group as a whole?

##### Intervention Characteristics

1. Was the intervention fully described?
2. Was treatment fidelity monitored in a systematic way? (for nonmedical interventions)
3. Did the authors measure and report adherence to the intended treatment process? (for medical interventions)
4. Did the authors report differences in or hold steady all concomitant interventions?

##### Outcomes Measurement

1. Did outcome measures demonstrate adequate reliability and validity (including interobserver reliability for behavior observation coding)?
2. Were outcomes coded and assessed by individuals blinded to the intervention status of the participants?

##### Statistical Analysis

1. For RCTs, was there an intent-to-treat analysis?
2. For negative studies, was a power calculation provided?
3. For observational studies, were potential confounders and effect measure modifiers captured?
4. For observational studies, were potential confounders and effect measure modifiers handled appropriately?

Finally, we assessed the quality of systematic reviews and meta-analyses using the AMSTAR tool.56 For all types of studies, two reviewers independently assessed quality, with final decisions made via discussion to reach consensus or by third-party adjudication by a senior methodologist as needed. We report individual quality assessments for each study in Appendix D.

### Determining Quality Levels

#### Screening Studies

We determined quality ratings for screening studies based on USPSTF methods and criteria for ratings for diagnostic accuracy studies.57 Our criteria were as follows:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (>1000) patients with and without disease, includes participants drawn from the general population and follows at least a random sample of screen-negative participants.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size.

Poor: Has fatal flaw such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size.

An important consideration in assessing quality of the screening accuracy studies was the methodology employed for handling screen-negative participants. Given the prevalence rate of 1 in 68, as well as the resource-intensive nature of conducting the gold standard evaluations (i.e., in-person, time-intensive diagnostic assessments by skilled behavioral professionals sometimes lasting a full day or more) in screen-negative children, almost no study has followed a large enough sample to truly assess false negatives on a population level. Given the pervasive and ongoing nature of developmental disorders, however, false negatives are primarily a concern among borderline cases, such as those that fail one portion of the screening process. Rather than follow up with all screen negatives, some studies followed up with borderline cases that failed a portion of the screening process (e.g., failed the screener but not the interview). As such, we allowed varying methodologies for attempting to assess false negatives among those who partially failed screening to qualify in determination of a “good” study if they met other criteria as a good study.

#### Intervention Studies

We assessed each domain described above individually and considered the individual ratings to determine an overall quality assessment of good, fair, or poor. We required that studies receive positive scores questions related to study design and diagnostic approach to be considered good quality. Scores were calculated first by domain and then summed and weighted as described in Table 2 to determine overall study quality. Studies could receive up to two points on the domains of study design, diagnostic approach, participant ascertainment, and intervention, and up to one point on the domains of outcome measurement and statistical analysis.

Table 2 Quality Scoring Algorithm for Intervention Studies

Definition and Scoring Algorithm | Rating
Score algorithm for internal validity quality rating
- ≥8/10 points, including a ++ on study design and ++ on diagnostic approach | Good quality
- ≥6/10 points, including at least a + on intervention | Fair quality
- ≤5/10 points | Poor quality

## Data Synthesis and Analysis

We determined that a meta-analysis of screening studies would be inappropriate and unnecessary. We assessed attrition at each step in the process and assumed nondifferential loss to followup to impute diagnostic yield and other outcomes if there had been complete followup for key studies. We analyzed results of studies qualitatively, summarizing them in tables and in text. We summarized only those systematic reviews rated as good quality.

## Expert Review and Public Comment

The draft report was reviewed by content experts, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) project officers and revised prior to final publication.

## USPSTF Involvement

We worked with USPSTF liaisons at key points in the review process to develop the analytic framework and KQs, to address methodological decisions on applicable evidence, and to resolve issues of scope for the review. The review was funded by AHRQ under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted with external review of the draft report.