# Introduction

The Centers for Disease Control and Prevention (CDC) estimates that one in every 68 children has an autism spectrum disorder (ASD). Most are diagnosed at or after age 4.^1^ Some children are identified early for evaluation and diagnosis, either because of parental concern or through general developmental surveillance by primary care providers. In addition to this subgroup, the screening population for primary care includes other children whose families and providers do not yet have concerns. An estimated 42 to 55 percent of pediatricians regularly screen for ASD in toddlers,2 with providers less likely to screen toddlers from under-represented ethnic and language groups (e.g., 29% of primary care pediatricians report offering Spanish ASD screening in populations of children whose parents are native Spanish speakers).3 Current approaches that include pediatric surveillance, general developmental screening, and a reliance on parents to raise concerns do not identify most children with ASD prior to age 4. The question of whether it is beneficial to do so is a component of this review.

## Autism Spectrum Disorder

ASD is defined in terms of persistent, significant impairments in social interaction and communication as well as restrictive, repetitive behaviors and activities.4 Social communication and social interaction features include deficits in social-emotional reciprocity (e.g., deficits in joint attention, atypical social approach and response, conversational challenges, reduced sharing of interest, emotions, and affect), deficits in nonverbal communication (e.g., atypical eye contact, reduced gesture use, limited use of facial expressions in social interactions, challenges understanding nonverbal communication), and deficits in forming and maintaining relationships (e.g., diminished peer interest, challenges joining in play, difficulties adjusting behavior to social context). ASD features of restricted, repetitive patterns of behavior, interests, or activities may include stereotyped motor mannerisms, use of objects, or speech (e.g., simple motor stereotypies, repetitive play, echolalia, and formal or idiosyncratic speech); insistence on sameness, inflexible adherence to routines, or ritualized patterns of behavior (e.g., distress at small changes, rigid patterns of thought and behavior, performance of everyday activities in ritualistic manner); intense preoccupation with specific interests (e.g., strong attachment to objects, circumscribed or perseverative topics of interest); and sensory sensitivities or interests (e.g., hyper- or hypo- reactivity to pain and sensory input, sensitivity to noise, visual fascination with objects or movement).5-7 These symptoms cause impairment across many areas of functioning and are present early in life. However, impairments may not be fully evident until environmental demands exceed children's capacity. They also may be masked by learned compensatory strategies later in life. Many children with ASD also have intellectual impairment or language impairment, and the disorder has been associated with known medical, genetic, or environmental factors.

Previously, disorders considered a part of the autism spectrum were divided into discrete categories including: Autistic Disorder, Asperger's Disorder, and Pervasive Developmental Disorder, Not Otherwise Specified (PDD-NOS), as defined by the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV).4 The DSM-5, published in May 2013, combined the previous categorical disorders into a single category of “Autism Spectrum Disorder,” with varying degrees of severity depending on the amount of support required by an individual.8 Because no medical or biological marker exists for ASD, the diagnosis is behaviorally based. Diagnosis is established with a combination of history, observation, and/or formal testing, which may include ASD-specific screening and assessment instruments.9, 10

### Burden of Disease/Illness

The prevalence of ASD in the United States is estimated at 14.7 cases per 1,000 children, or 1 in 68, with estimates varying widely by region of the country, sex, and race/ethnicity.1 More males (1 in 42) than females (1 in 189) are affected. For many individuals, core symptoms of ASD improve with intervention and maturation;11-13 however, early core deficits typically translate into varying developmental effects that remain throughout the lifespan, with differing impact on long-term functional outcomes.14 Many adults with ASD do not obtain traditional markers of adaptive independence, including jobs, independent living, and educational attainment.15-19

### Etiology and Risk Factors

ASD has a strong genetic component, with heritability estimated to be between 40 and 90 percent.20-22 A range of genes is implicated in susceptibility to ASD;22-24 however, environmental exposures and context also play a role in ASD development and neurogenetic expression.24, 25 Identification of specific genetic risk variants has been challenging, and many researchers suggest that there are be multiple pathways involved, including prenatal and postnatal insult in some cases.23 Current research26, 27 suggests that certain metabolic and other maternal conditions (such as diabetes, hypertension, obesity, and influenza infection) during pregnancy may be associated with increased risk of ASD in offspring. Other studies have investigated the role of advanced maternal and paternal age,28-30 intrapregnancy interval,31, 32 pesticide exposure,33 and exposure to mercury and other heavy metals,34 among other potential risk factors.

In addition to the potential causative genetic and environmental factors described above, being the sibling of another child diagnosed with ASD triples the risk of receiving an ASD diagnosis from 6.7 to 18.7 percent.35, 36 This risk varies by gender and increases twofold when two or more older siblings have ASD. Increasingly, researchers are attempting to follow infant siblings from very early ages in order to better understand the earliest potential actionable features of the disorder.5

### Rationale for Screening and Clinical Practice Parameters

A recent CDC report found that most children with ASD in the United States are diagnosed at a median age of 4 years, 5 months.1 On average, median age of diagnosis is somewhat earlier for children with autistic disorder (4 years) than for children with the more broadly defined autism spectrum diagnoses, such as PDD-NOS (4 years, 2 months) and Asperger Syndrome (6 years, 2 months). Substantial racial/ethnic differences in the age of ASD diagnosis also have been documented. For example, one study reported that African American children received ASD diagnoses an average of 1.4 years later than white children,37 and CDC figures suggest that at 8 years of age far fewer Hispanic and African American children have been identified with ASD.

Supporters of universal screening say that delays in accurate diagnosis may contribute to familial distress38 and limit access to intervention services,39, 40 which many experts consider to be important for improving children's short-term and longer-term outcomes. Although some children can access treatments through early intervention and medical systems while waiting for diagnostic confirmation, the number of intervention hours received without an ASD diagnosis is usually substantially less than many experts recommend.40-44

Over the past decade several professional groups, including the American Academy of Neurology,43 the American Academy of Child and Adolescent Psychiatry,44 and the American Academy of Pediatrics (AAP)45, 46 have issued guidance on the early detection of ASD. The most recent AAP guidance recommends universal screening of all children at 18 and 24 months of age in addition to developmental surveillance and monitoring. Other agencies have not supported ASD screening; 2011 guidance from the U.K. National Screening Committee does not recommend systematic population screening,47 nor does 2007 guidance from the Scottish Intercollegiate Guidelines Network (SIGN).48 These organizations cited a lack of data on positive predictive value (PPV) in a population setting. However, these recommendations do not reflect all currently available screening research, and the SIGN guidelines are currently under revision but not completed at the time of this report.

After screening positive, some families access diagnostic and treatment services quickly, while other families report significant time (e.g., waitlists) and financial barriers in accessing evaluation resources.38, 49 Some research reports high levels of parental stress associated with the ASD diagnostic process and advocates additional work to understand the impact of the process on parent functioning.50 Both delays and demands associated with the ASD diagnostic process may place a burden on the families of children who falsely screen positive, and this is one reason that the screening process in ASD has evolved from the use of single questionnaires with very high false-positive rates to two-stage screening approaches that include parent questionnaires and followup interviews. It is possible that concerns about long waiting lists and/or over-referral of children who meet screening criteria for reasons other than ASD are contributing to low practice of ASD screening in pediatric practice.51-54 Increasingly, researchers are attempting to identify mechanisms to train additional community providers (e.g., primary care providers, behavioral providers, educational professionals) to provide timely and accurate diagnosis of ASD and reduce diagnostic wait times. However, variability still exists in families' abilities to access specialized diagnostic assessment resources.

A number of U.S. professional groups and affiliated organizations, including the AAP, CDC, and Autism Speaks, have developed materials to help clinicians care for individuals with ASD and related developmental disabilities, including screening and providing followup care. This includes information and training on available screeners, coding/billing guidance, and practice support, as well as referrals and resources.

### Treatment of ASD

From a health care perspective, the purpose of screening is to identify children for whom effective treatments exist and could make a difference compared to treatments initiated at a later point. Commonly pursued treatments for ASD include behavioral, medical/pharmacotherapy, educational, allied health, and complementary and alternative medicine approaches. Our review of the treatment literature is presented below.

## Previous U.S. Preventive Services Task Force Recommendation

The U.S. Preventive Services Task Force (USPSTF) has not made any prior recommendations on ASD screening.