# Excluded Studies

Key to Exclusion Reasons

X-1: | Did not address screening
X-2: | Not original research
X-3: | Ineligible population
X-4: | Did not address outcomes of interest
X-5: | Not conducted in eligible country
X-6: | Article not obtainable

1 Baron-Cohen S, Wheelwright S, Cox A, et al. Early identification of autism by the CHecklist for Autism in Toddlers (CHAT). J R Soc Med. Oct. 2000;93(10):521-5. X-2. [pmid: 11064690].
2 Eaves RC, Campbell HA, Chambers D. Criterion-related and construct validity of the Pervasive Developmental Disorders Rating Scale and the Autism Behavior Checklist. Psychology in the Schools. 2000;37(4):311-21. X-3.
3 Fenson L, Pethick S, Renda C, et al. Short-Form Versions of the MacArthur Communicative Development Inventories. Applied Psycholinguistics. 2000;21(1):95-115. X-1, X-3, X-4.
4 Stone WL, Coonrod EE, Ousley OY. Brief report: screening tool for autism in two-year-olds (STAT): development and preliminary data. J Autism Dev Disord. Dec. 2000;30(6):607-12. X-4. [pmid: 11261472].
5 Adrien JL, Rossignol-Deletang N, Martineau J, et al. Regulation of cognitive activity and early communication development in young autistic, mentally retarded, and young normal children. Dev Psychobiol. Sep. 2001;39(2):124-36. X-3, X-4. [pmid: 11568882].
6 Baird G, Charman T, Cox A, et al. Current topic: Screening and surveillance for autism and pervasive developmental disorders. Arch Dis Child. Jun. 2001;84(6):468-75. X-2, X-3, X-4, X-5. [pmid: 11369559].
7 Baird G, Charman T, Santosh PJ. Clinical considerations in the diagnosis of autism spectrum disorders. Indian J Pediatr. May. 2001;68(5):439-49. X-1, X-2, X-3, X-4, X-5. [pmid: 11407161].
8 Blackwell J. Clinical practice guideline: screening and diagnosing autism. J Am Acad Nurse Pract. Dec. 2001;13(12):534-6. X-2, X-3, X-4, X-5. [pmid: 11836828].
9 Chakrabarti S, Fombonne E. Pervasive developmental disorders in preschool children. JAMA. Jun. 27. 2001;285(24):3093-9. X-1, X-4. [pmid: 11427137].
10 Charman T, Baron-Cohen S, Baird G, et al. Commentary: The Modified Checklist for Autism in Toddlers. Journal of Autism and Developmental Disorders. 2001;31(2):145-8. X-2, X-3, X-4, X-5. [pmid: 11450813].
11 Robins DL, Fein D, Barton ML, et al. Reply to Charman et al.'s Commentary on the Modified Checklist for Autism in Toddlers. Journal of Autism and Developmental Disorders. 2001;31(2):149-51. X-2, X-3, X-4.
12 Scambler D, Rogers SJ, Wehner EA. Can the checklist for autism in toddlers differentiate young children with autism from those with developmental delays?. J Am Acad Child Adolesc Psychiatry. Dec. 2001;40(12):1457-63. X-4. [pmid: 11765292].
13 Willemsen-Swinkels SH, Buitelaar JK, van Engeland H. Is 18 months too early for the CHAT?. J Am Acad Child Adolesc Psychiatry. Jul. 2001;40(7):737-8. X-2, X-4. [pmid: 11437006].
14 Zwaigenbaum L. Autistic spectrum disorders in preschool children. Can Fam Physician. Oct. 2001;47:2037-42. X-2, X-3, X-4, X-5. [pmid: 11723598].
15 Brereton AV, Tonge BJ, Mackinnon AJ, et al. Screening young people for autism with the developmental behavior checklist. J Am Acad Child Adolesc Psychiatry. Nov. 2002;41(11):1369-75. X-3, X-4. [pmid: 12410080].
16 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. Dec. 2002;11(6):266-72. X-1, X-4. [pmid: 12541005].
17 Honda H, Shimizu Y. Early Intervention System for Preschool Children with Autism in the Community: The DISCOVERY Approach in Yokohama, Japan. Autism: The International Journal of Research and Practice. 2002;6(3):239-57. X-4. [pmid: 12212916].
18 Jensen VK, Sinclair LV. Treatment of Autism in Young Children: Behavioral Intervention and Applied Behavior Analysis. Infants and Young Children. 2002;14(4):42-52. X-1, X-2, X-3, X-4.
19 Plotts C, Webber J. The Role of Developmental Histories in the Screening and Diagnosis of Autism Spectrum Disorders. Assessment for Effective Intervention. 2002;27(1-2):19-26. X-1, X-2, X-3, X-4.
20 South M, Williams BJ, McMahon WM, et al. Utility of the Gilliam Autism Rating Scale in Research and Clinical Populations. Journal of Autism and Developmental Disorders. 2002;32(6):593-9. X-3, X-4. [pmid: 12553595].
21 Sprafkin J, Volpe RJ, Gadow KD, et al. A DSM-IV-referenced screening instrument for preschool children: the Early Childhood Inventory-4. J Am Acad Child Adolesc Psychiatry. May. 2002;41(5):604-12. X-1, X-3, X-4. [pmid: 12014793].
22 Vrancic D, Nanclares V, Soares D, et al. Sensitivity and specificity of the autism diagnostic inventory-telephone screening in Spanish. J Autism Dev Disord. Aug. 2002;32(4):313-20. X-3, X-4. [pmid: 12199136].
23 Williams TO, Eaves RC. The reliability of test scores for the Pervasive Developmental Disorders Rating Scale. Psychology in the Schools. 2002;39(6):605-11. X-4.
24 Blackwell J, Niederhauser C. Diagnose and manage autistic children. Nurse Pract. Jun. 2003;28(6):36-43. quiz 4-5. X-2, X-3, X-4, X-5. [pmid: 12796622].
25 Manning-Courtney P, Brown J, Molloy CA, et al. Diagnosis and treatment of autism spectrum disorders. Curr Probl Pediatr Adolesc Health Care. Oct. 2003;33(9):283-304. X-2, X-3, X-4, X-5. [pmid: 14534514].
26 Nash PL, Coury DL. Screening tools assist with diagnosis of autistic spectrum disorders. Pediatr Ann. Oct. 2003;32(10):664-70. X-2, X-3, X-4, X-5. [pmid: 14606216].
27 Saemundsen E, Magnusson P, Smari J, et al. Autism Diagnostic Interview-Revised and the Childhood Autism Rating Scale: Convergence and Discrepancy in Diagnosing Autism. Journal of Autism and Developmental Disorders. 2003;33(3):319-28. X-4. [pmid: 12908834].
28 Stone WL, Coonrod EE, Pozdol SL, et al. The Parent Interview for Autism-Clinical Version (PIA-CV): A Measure of Behavioral Change for Young Children with Autism. Autism: The International Journal of Research and Practice. 2003;7(1):9-30. X-1, X-3,X-4. [pmid: 12638762].
29 Sturmey P, Lee R, Reyer H, et al. Assessing preferences for staff: Some pilot data. Behavioural and Cognitive Psychotherapy. 2003;31(1):103-7. X-1, X-3, X-4.
30 Tachimori H, Osada H, Kurita H. Childhood autism rating scale--Tokyo version for screening pervasive developmental disorders. Psychiatry Clin Neurosci. Feb. 2003;57(1):113-8. X-1. [pmid: 12519463].
31 Webb E, Morey J, Thompsen W, et al. Prevalence of autistic spectrum disorder in children attending mainstream schools in a Welsh education authority. Dev Med Child Neurol. Jun. 2003;45(6):377-84. X-3, X-4. [pmid: 12785438].
32 Addington AM, Gornick M, Sporn AL, et al. Polymorphisms in the 13q33.2 gene G72/G30 are associated with childhood-onset schizophrenia and psychosis not otherwise specified. Biol Psychiatry. May. 15. 2004;55(10):976-80. X-1, X-3, X-4. [pmid: 15121480].
33 Briggs-Gowan MJ, Carter AS, Irwin JR, et al. The Brief Infant-Toddler Social and Emotional Assessment: screening for social-emotional problems and delays in competence. J Pediatr Psychol. Mar. 2004;29(2):143-55. X-1, X-3, X-4. [pmid: 15096535].
34 Eaves LC, Ho HH. The very early identification of autism: outcome to age 4 1/2-5. J Autism Dev Disord. Aug. 2004;34(4):367-78. [pmid: 15449513].
35 Geurts HM, Verte S, Oosterlaan J, et al. Can the Children's Communication Checklist differentiate between children with autism, children with ADHD, and normal controls?. J Child Psychol Psychiatry. Nov. 2004;45(8):1437-53. X-1, X-3, X-4. [pmid: 15482504].
36 Goin PR, Myers JB. Characteristics of Infantile Autism: Moving Toward Earlier Detection. Focus on Autism and Other Developmental Disabilities. 2004;19(1):5-12. X-2, X-3, X-4, X-5.
37 Howlin P, Karpf J. Using the social communication questionnaire to identify ‘autistic spectrum’ disorders associated with other genetic conditions: findings from a study of individuals with Cohen syndrome. Autism. Jun. 2004;8(2):175-82. X-3, X-4. [pmid: 15165433].
38 Munson BL. Myths and facts…about autism. Nursing. Oct. 2004;34(10):75. X-1, X-2, X-3, X-4, X-5. [pmid: 15489628].
39 Noland RM, Gabriels RL. Screening and identifying children with autism spectrum disorders in the public school system: the development of a model process. J Autism Dev Disord. Jun. 2004;34(3):265-77. X-2, X-3, X-4. [pmid: 15264495].
40 Norbury CF, Nash M, Baird G, et al. Using a parental checklist to identify diagnostic groups in children with communication impairment: a validation of the Children's Communication Checklist--2. Int J Lang Commun Disord. Jul-Sep. 2004;39(3):345-64. X-1, X-3,X-4. [pmid: 15204445].
41 Rellini E, Tortolani D, Trillo S, et al. Childhood Autism Rating Scale (CARS) and Autism Behavior Checklist (ABC) correspondence and conflicts with DSM-IV criteria in diagnosis of autism. J Autism Dev Disord. Dec. 2004;34(6):703-8. x-4. [pmid: 15679189].
42 Skovgaard AM, Houmann T, Landorph SL, et al. Assessment and classification of psychopathology in epidemiological research of children 0-3 years of age: a review of the literature. Eur Child Adolesc Psychiatry. Dec. 2004;13(6):337-46. X-2, X-3, X-4, X-5. [pmid: 15619045].
43 Spence SJ, Sharifi P, Wiznitzer M. Autism spectrum disorder: screening, diagnosis, and medical evaluation. Semin Pediatr Neurol. Sep. 2004;11(3):186-95. X-1, X-2, X-3, X-4, X-5. [pmid: 15575413].
44 Steinhausen HC, Metzke CW. Differentiating the behavioural profile in autism and mental retardation and testing of a screener. Eur Child Adolesc Psychiatry. Aug. 2004;13(4):214-20. X-3, X-4. [pmid: 15365891].
45 Stone WL, Coonrod EE, Turner LM, et al. Psychometric properties of the STAT for early autism screening. J Autism Dev Disord. Dec. 2004;34(6):691-701. X-4. [pmid: 15679188].
46 Tebruegge M, Nandini V, Ritchie J. Does routine child health surveillance contribute to the early detection of children with pervasive developmental disorders? An epidemiological study in Kent, U.K. BMC Pediatr. Mar. 3. 2004;4:4. X-4. [pmid: 15053835].
47 Wetherby AM, Woods J, Allen L, et al. Early indicators of autism spectrum disorders in the second year of life. J Autism Dev Disord. Oct. 2004;34(5):473-93. X-4. [pmid: 15628603].
48 Wong V, Hui LH, Lee WC, et al. A modified screening tool for autism (Checklist for Autism in Toddlers [CHAT-23]) for Chinese children. Pediatrics. Aug. 2004;114(2):e166-76. X-3. [pmid: 15286253].
49 Bennett HE, Wood CL, Hare DJ. Providing Care for adults with Autistic Spectrum Disorders in Learning Disability Services: Needs-based or Diagnosis-driven?. Journal of Applied Research in Intellectual Disabilities. 2005;18(1):57-64. X-3, X-4.
50 Campbell JM. Diagnostic assessment of Asperger's disorder: a review of five third-party rating scales. J Autism Dev Disord. Feb. 2005;35(1):25-35. X-2, X-3, X-4, X-5. [pmid: 15796119].
51 Clarke DF, Roberts W, Daraksan M, et al. The prevalence of autistic spectrum disorder in children surveyed in a tertiary care epilepsy clinic. Epilepsia. Dec. 2005;46(12):1970-7. X-1, X-3, X-4. [pmid: 16393164].
52 Dame Stephanie S. Challenges to autism research. J R Soc Med. Nov. 2005;98(11):523-5. X-1, X-2, X-3, X-4, X-5. [pmid: 16260809].
53 de Bildt A, Sytema S, Kraijer D, et al. Prevalence of pervasive developmental disorders in children and adolescents with mental retardation. Journal of Child Psychology and Psychiatry. 2005;46(3):275-86. X-1, X-3, X-4. [pmid: 15755304].
54 Gargus RA, Yatchmink Y. Early identification and assessment of young children with autism. Med Health R I. May. 2005;88(5):147-51. X-2, X-3, X-4, X-5. [pmid: 16052956].
55 Glascoe FP. Screening for developmental and behavioral problems. Ment Retard Dev Disabil Res Rev. 2005;11(3):173-9. X-2, X-3, X-4. [pmid: 16161092].
56 Gray KM, Tonge BJ. Screening for autism in infants and preschool children with developmental delay. Australian and New Zealand Journal of Psychiatry. 2005;39(5):378-86. X-4. [pmid: 15860026].
57 Hansson SL, Svanstrom Rojvall A, Rastam M, et al. Psychiatric telephone interview with parents for screening of childhood autism - tics, attention-deficit hyperactivity disorder and other comorbidities (A-TAC): preliminary reliability and validity. Br J Psychiatry. Sep. 2005;187:262-7. X-3, X-4. [pmid: 16135864].
58 Honda H, Shimizu Y, Imai M, et al. Cumulative incidence of childhood autism: a total population study of better accuracy and precision. Dev Med Child Neurol. Jan. 2005;47(1):10-8. x-4. [pmid: 15686284].
59 Jeffries AR, Curran S, Elmslie F, et al. Molecular and phenotypic characterization of ring chromosome 22. Am J Med Genet A. Aug. 30. 2005;137(2):139-47. X-1, X-3, X-4. [pmid: 16059935].
60 Juneja M, Mukherjee SB, Sharma S. A descriptive hospital based study of children with autism. Indian Pediatr. May. 2005;42(5):453-8. X-4, X-5. [pmid: 15923691].
61 Ke JY, Chen CL, Chen YJ, et al. Features of developmental functions and autistic profiles in children with fragile X syndrome. Chang Gung Med J. Aug. 2005;28(8):551-8. X-1, X-4, X-5. [pmid: 16265845].
62 Koegel LK, Koegel RL, Nefdt N, et al. First S.T.E.P: A Model for the Early Identification of Children With Autism Spectrum Disorders. Journal of Positive Behavior Interventions. 2005;7(4):247-52. X-2, X-3, X-4.
63 Kraijer D, de Bildt A. The PDD-MRS: an instrument for identification of autism spectrum disorders in persons with mental retardation. J Autism Dev Disord. Aug. 2005;35(4):499-513. X-4. [pmid: 16134035].
64 Kurita H, Koyama T, Osada H. Autism-Spectrum Quotient-Japanese version and its short forms for screening normally intelligent persons with pervasive developmental disorders. Psychiatry Clin Neurosci. Aug. 2005;59(4):490-6. X-3, X-4. [pmid: 16048456].
65 Lecavalier L. An evaluation of the Gilliam Autism Rating Scale. J Autism Dev Disord. Dec. 2005;35(6):795-805. X-3, X-4. [pmid: 16283084].
66 Namerow LB, Mangini LM. Targeting symptom domains: a strategy for pharmacotherapy in childhood pervasive developmental disorders. Conn Med. Oct. 2005;69(9):525-33. X-1, X-2, X-3, X-4, X-5. [pmid: 16270789].
67 Pinto-Martin JA, Dunkle M, Earls M, et al. Developmental stages of developmental screening: steps to implementation of a successful program. Am J Public Health. Nov. 2005;95(11):1928-32. X-2, X-3, X-4. [pmid: 16195523].
68 Pinto-Martin JA, Souders MC, Giarelli E, et al. The role of nurses in screening for autistic spectrum disorder in pediatric primary care. J Pediatr Nurs. Jun. 2005;20(3):163-9. X-2, X-3, X-4, X-5. [pmid: 15933650].
69 Skuse DH, Mandy WP, Scourfield J. Measuring autistic traits: heritability, reliability and validity of the Social and Communication Disorders Checklist. Br J Psychiatry. Dec. 2005;187:568-72. X-3, X-4. [pmid: 16319410].
70 Stehouwer JD. Test Review: Rick, J.R. (2003).Krug Asperger's Disorder Index (KADI). Austin, TX: PRO-ED. Assessment for Effective Intervention. 2005;31(1):85-8. X-2, X-3, X-4, X-5.
71 Towbin KE, Pradella A, Gorrindo T, et al. Autism spectrum traits in children with mood and anxiety disorders. J Child Adolesc Psychopharmacol. Jun. 2005;15(3):452-64. X-3, X-4. [pmid: 16092910].
72 Williams TO Jr., Eaves RC. Pervasive developmental disorders rating scale: development and construct validity. Psychol Rep. Aug. 2005;97(1):245-57. X-3, X-4. [pmid: 16279331].
73 Williams TO, Eaves RC. Factor Analysis of the Pervasive Developmental Disorders Rating Scale With Teacher Ratings of Students With Autistic Disorder. Psychology in the Schools. 2005;42(2):207-16. X-4.
74 Wray J, Silove N, Knott H. 7. Language disorders and autism. Med J Aust. Apr. 4. 2005;182(7):354-60. X-1, X-2, X-3, X-4, X-5. [pmid: 15804229].
75 Zhang X, Ji CY. Autism and mental retardation of young children in China. Biomed Environ Sci. Oct. 2005;18(5):334-40. X-1, X-4, X-5. [pmid: 16370317].
76 Carpenter LA, Macias MM. Screening and diagnosis of autism spectrum disorders (ASD). J S C Med Assoc. Oct. 2006;102(8):271-3. X-10. [pmid: 17319241].
77 Crais ER, Watson LR, Baranek GT, et al. Early identification of autism: how early can we go?. Semin Speech Lang. Aug. 2006;27(3):143-60. X-2, X-3, X-4, X-5. [pmid: 16941286].
78 Descheemaeker MJ, Govers V, Vermeulen P, et al. Pervasive developmental disorders in Prader-Willi syndrome: the Leuven experience in 59 subjects and controls. Am J Med Genet A. Jun. 1. 2006;140(11):1136-42. X-1, X-3 ,X4. [pmid: 16646032].
79 Dosreis S, Weiner CL, Johnson L, et al. Autism spectrum disorder screening and management practices among general pediatric providers. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S88-94. X-3, X-4. [pmid: 16685190].
80 Earls MF, Hay SS. Setting the stage for success: implementation of developmental and behavioral screening and surveillance in primary care practice--the North Carolina Assuring Better Child Health and Development (ABCD) Project. Pediatrics. Jul. 2006;118(1):e183-8. X-1, X-2, X-4. [pmid: 16818532].
81 Eaves LC, Wingert H, Ho HH. Screening for autism: agreement with diagnosis. Autism. May. 2006;10(3):229-42. [pmid: 16682396].
82 Eaves LC, Wingert HD, Ho HH, et al. Screening for autism spectrum disorders with the social communication questionnaire. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S95-S103. X-3, X-4. [pmid: 16685191].
83 Eaves RC, Williams TO Jr. Exploratory and confirmatory factor analyses of the pervasive developmental disorders rating scale for young children with autistic disorder. J Genet Psychol. Mar. 2006;167(1):65-92. X-1, X-4. [pmid: 16629404].
84 Eaves RC, Williams TO. The reliability and construct validity of ratings for the autism behavior checklist. Psychology in the Schools. 2006;43(2):129-42. X-3,X-4.
85 Eaves RC, Woods-Groves S, Williams TO, et al. Reliability and Validity of the Pervasive Developmental Disorders Rating Scale and the Gilliam Autism Rating Scale. Education and Training in Developmental Disabilities. 2006;41(3):300-9. X-3, X-4.
86 Hartman CA, Luteijn E, Serra M, et al. Refinement of the Children's Social Behavior Questionnaire (CSBQ): an instrument that describes the diverse problems seen in milder forms of PDD. J Autism Dev Disord. Apr. 2006;36(3):325-42. X-1, X-3, X-4. [pmid: 16617405].
87 Hattori J, Ogino T, Abiru K, et al. Are pervasive developmental disorders and attention-deficit/hyperactivity disorder distinct disorders?. Brain Dev. Jul. 2006;28(6):371-4. X-1, X-3 ,X-4. [pmid: 16504439].
88 Jane MC, Canals J, Ballespi S, et al. Parents and teachers reports of DSM-IV psychopathological symptoms in preschool children: differences between urban-rural Spanish areas. Soc Psychiatry Psychiatr Epidemiol. May. 2006;41(5):386-93. X-1, X-3 ,X-4. [pmid: 16520884].
89 Krol NP, De Bruyn EE, Coolen JC, et al. From CBCL to DSM: a comparison of two methods to screen for DSM-IV diagnoses using CBCL data. J Clin Child Adolesc Psychol. Feb. 2006;35(1):127-35. X-1, X-3, X-4. [pmid: 16390308].
90 Lord C, Risi S, DiLavore PS, et al. Autism from 2 to 9 years of age. Arch Gen Psychiatry. Jun. 2006;63(6):694-701. X-1, X-4. [pmid: 16754843].
91 Mawle E, Griffiths P. Screening for autism in pre-school children in primary care: systematic review of English Language tools. Int J Nurs Stud. Jul. 2006;43(5):623-36. X-SR. [pmid: 16387303].
92 Mazefsky CA, Oswald DP. The Discriminative Ability and Diagnostic Utility of the ADOS-G, ADI-R, and GARS for Children in a Clinical Setting. Autism: The International Journal of Research & Practice. 2006;10(6):533-49. X-4. [pmid: 17088271].
93 Mitchell S, Brian J, Zwaigenbaum L, et al. Early language and communication development of infants later diagnosed with autism spectrum disorder. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S69-78. X-1, X-4. [pmid: 16685188].
94 Persson B, Nordstrom B, Petersson K, et al. Screening for infants with developmental deficits and/or autism: a Swedish pilot study. J Pediatr Nurs. Aug. 2006;21(4):313-24. X-4. [pmid: 16843217].
95 Pine E, Luby J, Abbacchi A, et al. Quantitative assessment of autistic symptomatology in preschoolers. Autism. Jul. 2006;10(4):344-52. X-1, X-3, X-4. [pmid: 16908478].
96 Risi S, Lord C, Gotham K, et al. Combining Information from Multiple Sources in the Diagnosis of Autism Spectrum Disorders. Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45(9):1094-103. X-1, X-3,X-4. [pmid: 16926617].
97 Robins DL, Dumont-Mathieu TM. Early screening for autism spectrum disorders: update on the modified checklist for autism in toddlers and other measures. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S111-9. X-2, X-3, X-4, X-5. [pmid: 16685177].
98 Scambler DJ, Hepburn SL, Rogers SJ. A two-year follow-up on risk status identified by the checklist for autism in toddlers. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S104-10. X-4. [pmid: 16685176].
99 Swinkels SH, Dietz C, van Daalen E, et al. Screening for autistic spectrum in children aged 14 to 15 months. I: the development of the Early Screening of Autistic Traits Questionnaire (ESAT). J Autism Dev Disord. Aug. 2006;36(6):723-32. X-4. [pmid: 16614790].
100 Tryon PA, Mayes SD, Rhodes RL, et al. Can Asperger's Disorder Be Differentiated from Autism Using “DSM-IV” Criteria?. Focus on Autism and Other Developmental Disabilities. 2006;21(1):2-6. X-1, X-2, X-3, X-4.
101 Williams J, Brayne C. Screening for autism spectrum disorders.What is the evidence?. Autism. 2006;10(1):11-35. X-2, X-3, X-4. [pmid: 16522708].
102 Allen CW, Silove N, Williams K, et al. Validity of the social communication questionnaire in assessing risk of autism in preschool children with developmental problems. J Autism Dev Disord. Aug. 2007;37(7):1272-8. [pmid: 17080270].
103 Allison C, Williams J, Scott F, et al. The Childhood Asperger Syndrome Test (CAST): test-retest reliability in a high scoring sample. Autism. Mar. 2007;11(2):173-85. X-3, X-4. [pmid: 17353217].
104 Almon-Morris H, Diakite A. Teaching Emotions to Children with Autism: Identification, Demonstration, and Explanation of Occasioning Stimuli. Journal of Precision Teaching and Celeration. 2007;23:19-22. X-1, X-3, X-4.
105 Angley M, Young R, Ellis D, et al. Children and autism--Part 1--recognition and pharmacological management. Aust Fam Physician. Sep. 2007;36(9):741-4. X-1, X-2, X-3, X-4. [pmid: 17915375].
106 Ben-Sasson A, Cermak SA, Orsmond GI, et al. Extreme sensory modulation behaviors in toddlers with autism spectrum disorders. Am J Occup Ther. Sep-Oct. 2007;61(5):584-92. X-1, X-4. [pmid: 17944296].
107 Bruckner C, Yoder P, Stone W, et al. Construct validity of the MCDI-I Receptive Vocabulary scale can be improved: differential item functioning between toddlers with autism spectrum disorders and typically developing infants. J Speech Lang Hear Res. Dec. 2007;50(6):1631-8. X-1, X-4. [pmid: 18055777].
108 Bryson SE, Zwaigenbaum L, Brian J, et al. A prospective case series of high-risk infants who developed autism. J Autism Dev Disord. Jan. 2007;37(1):12-24. X-1, X-3, X-4. [pmid: 17211728].
109 Chawarska K, Klin A, Paul R, et al. Autism spectrum disorder in the second year: stability and change in syndrome expression. J Child Psychol Psychiatry. Feb. 2007;48(2):128-38. X-1, X-4. [pmid: 17300551].
110 Clifford S, Young R, Williamson P. Assessing the early characteristics of autistic disorder using video analysis. J Autism Dev Disord. Feb. 2007;37(2):301-13. X-1, X-2, X-4. [pmid: 17031450].
111 Corsello C, Hus V, Pickles A, et al. Between a ROC and a hard place: decision making and making decisions about using the SCQ. J Child Psychol Psychiatry. Sep. 2007;48(9):932-40. [pmid: 17714378].
112 Eapen V, Mabrouk AA, Zoubeidi T, et al. Prevalence of pervasive developmental disorders in preschool children in the UAE. J Trop Pediatr. Jun. 2007;53(3):202-5. X-3. [pmid: 17244665].
113 Ellefsen A, Kampmann H, Billstedt E, et al. Autism in the Faroe Islands: an epidemiological study. J Autism Dev Disord. Mar. 2007;37(3):437-44. X-1, X-3, X-4, X-5. [pmid: 17029020].
114 Glascoe FP, Macias MM, Wegner LM, et al. Can a broadband developmental-behavioral screening test identify children likely to have autism spectrum disorder?. Clin Pediatr (Phila). Nov. 2007;46(9):801-5. X-4. [pmid: 17641122]. RETAIN FOR CQ
115 Gotham K, Risi S, Pickles A, et al. The Autism Diagnostic Observation Schedule: revised algorithms for improved diagnostic validity. J Autism Dev Disord. Apr. 2007;37(4):613-27. X-1, X-4. [pmid: 17180459].
116 Groen WB, Swinkels SH, van der Gaag RJ, et al. Finding effective screening instruments for autism using bayes theorem. Arch Pediatr Adolesc Med. Apr. 2007;161(4):415-6. X-4. [pmid: 17404143].
117 Lee L-C, David AB, Rusyniak J, et al. Performance of the Social Communication Questionnaire in children receiving preschool special education services. Research in Autism Spectrum Disorders. 2007;1(2):126-38. X-4.
118 Limperopoulos C, Bassan H, Gauvreau K, et al. Does cerebellar injury in premature infants contribute to the high prevalence of long-term cognitive, learning, and behavioral disability in survivors?. Pediatrics. Sep. 2007;120(3):584-93. X-4. [pmid: 17766532].
119 Magyar CI, Pandolfi V. Factor structure evaluation of the childhood autism rating scale. J Autism Dev Disord. Oct. 2007;37(9):1787-94. X-1, X-4. [pmid: 17437070].
120 Mattila ML, Kielinen M, Jussila K, et al. An epidemiological and diagnostic study of Asperger syndrome according to four sets of diagnostic criteria. J Am Acad Child Adolesc Psychiatry. May. 2007;46(5):636-46. X-1, X-2, X-3, X-4. [pmid: 17450055].
121 McClure I, Melville CA. Early identification key in autism spectrum disorders. Practitioner. Aug. 3. 2007;251(1697):31-5. X-1, X-2, X-3, X-4. [pmid: 17882895].
122 Nadel S, Poss JE. Early detection of autism spectrum disorders: screening between 12 and 24 months of age. J Am Acad Nurse Pract. Aug. 2007;19(8):408-17. X-1, X-2, X-3, X-4. [pmid: 17655570].
123 Nadig AS, Ozonoff S, Young GS, et al. A prospective study of response to name in infants at risk for autism. Arch Pediatr Adolesc Med. Apr. 2007;161(4):378-83. [pmid: 17404135].
124 Reznick JS, Baranek GT, Reavis S, et al. A parent-report instrument for identifying one-year-olds at risk for an eventual diagnosis of autism: The First Year Inventory. Journal of Autism and Developmental Disorders. 2007;37(9):1691-710. X-4. [pmid: 17180716].
125 Richler J, Bishop SL, Kleinke JR, et al. Restricted and repetitive behaviors in young children with autism spectrum disorders. J Autism Dev Disord. Jan. 2007;37(1):73-85. X-1, X-4. [pmid: 17195920].
126 Saemundsen E, Ludvigsson P, Hilmarsdottir I, et al. Autism spectrum disorders in children with seizures in the first year of life - a population-based study. Epilepsia. Sep. 2007;48(9):1724-30. X-3, X-4. [pmid: 17555525].
127 Scambler DJ, Hepburn S, Rutherford MD, et al. Emotional responsivity in children with autism, children with other developmental disabilities, and children with typical development. J Autism Dev Disord. Mar. 2007;37(3):553-63. X-1, X-4. [pmid: 16933089].
128 Scambler DJ, Hepburn SL, Hagerman RJ, et al. A preliminary study of screening for risk of autism in children with fragile X syndrome: testing two risk cut-offs for the Checklist for Autism in Toddlers. J Intellect Disabil Res. Apr. 2007;51(Pt 4):269-76. X-4. [pmid: 17326808].
129 Stone WL, McMahon CR, Yoder PJ, et al. Early social-communicative and cognitive development of younger siblings of children with autism spectrum disorders. Arch Pediatr Adolesc Med. Apr. 2007;161(4):384-90. X-4. [pmid: 17404136].
130 Ventola P, Kleinman J, Pandey J, et al. Differentiating between autism spectrum disorders and other developmental disabilities in children who failed a screening instrument for ASD. J Autism Dev Disord. Mar. 2007;37(3):425-36. X-4. [pmid: 16897377].
131 Watson LR, Baranek GT, Crais ER, et al. The first year inventory: retrospective parent responses to a questionnaire designed to identify one-year-olds at risk for autism. J Autism Dev Disord. Jan. 2007;37(1):49-61. X-4. [pmid: 17219058].
132 Wiggins LD, Bakeman R, Adamson LB, et al. The utility of the Social Communication Questionnaire in screening for autism in children referred for early intervention. Focus on Autism and Other Developmental Disabilities. 2007;22(1):33-8. X-4.
133 Witwer AN, Lecavalier L. Autism screening tools: an evaluation of the Social Communication Questionnaire and the Developmental Behaviour Checklist-Autism Screening Algorithm. J Intellect Dev Disabil. Sep. 2007;32(3):179-87. X-3, X-4. [pmid: 17885895].
134 Allen RA, Robins DL, Decker SL. Autism spectrum disorders: Neurobiology and current assessment practices. Psychology in the Schools. 2008;45(10):905-17. X-2, X-3, X-4, X-5.
135 Allison C, Baron-Cohen S, Wheelwright S, et al. The Q-CHAT (Quantitative CHecklist for Autism in Toddlers): a normally distributed quantitative measure of autistic traits at 18-24 months of age: preliminary report. J Autism Dev Disord. Sep. 2008;38(8):1414-25. X-4. [pmid: 18240013].
136 Bolte S, Holtmann M, Poustka F. The Social Communication Questionnaire (SCQ) as a screener for autism spectrum disorders: additional evidence and cross-cultural validity. J Am Acad Child Adolesc Psychiatry. Jun. 2008;47(6):719-20. author reply 20-1. X-3, X-4. [pmid: 18496329].
137 Boomsma A, Van Lang ND, De Jonge MV, et al. A new symptom model for autism cross-validated in an independent sample. J Child Psychol Psychiatry. Aug. 2008;49(8):809-16. X-1, X-3, X-4. [pmid: 18492042].
138 Brian J, Bryson SE, Garon N, et al. Clinical assessment of autism in high-risk 18-month-olds. Autism. Sep. 2008;12(5):433-56. X-1, X-3, X-4. [pmid: 18805941].
139 Bryson SE, Zwaigenbaum L, McDermott C, et al. The Autism Observation Scale for Infants: scale development and reliability data. J Autism Dev Disord. Apr. 2008;38(4):731-8. X-4. [pmid: 17874180].
140 Chiang CH, Soong WT, Lin TL, et al. Nonverbal communication skills in young children with autism. J Autism Dev Disord. Nov. 2008;38(10):1898-906. X-1, X-4,X-5. [pmid: 18491223].
141 DeVincent C, Gadow KD, Strong G, et al. Screening for autism spectrum disorder with the Early Childhood Inventory-4. J Dev Behav Pediatr. Feb. 2008;29(1):1-10. X-3, X-4. [pmid: 18300725].
142 Elder LM, Dawson G, Toth K, et al. Head circumference as an early predictor of autism symptoms in younger siblings of children with autism spectrum disorder. J Autism Dev Disord. Jul. 2008;38(6):1104-11. X-4. [pmid: 18058011].
143 Farmer JE, Clark MJ. Identification and evaluation of Missouri's children with autism spectrum disorders: promoting a rapid response. Mo Med. Sep-Oct. 2008;105(5):384-9. X-2, X-3, X-4, X-5. [pmid: 18807359].
144 Garcia-Primo P, Martin-Arribas MC, Ferrari-Arroyo MJ, et al. Autism, the big unkown. Georgian Med News. Mar. 2008;(156):9-14. X-2, X-3,X-4. [pmid: 18403803].
145 Ghanizadeh A. A preliminary study on screening prevalence of pervasive developmental disorder in schoolchildren in Iran. J Autism Dev Disord. Apr. 2008;38(4):759-63. X-3, X-4, X-5. [pmid: 17879153].
146 Goin-Kochel RP, Cohen R. Screening cases within a statewide autism registry: A comparison of parental reports using DSM-IV-TR criteria versus the SCQ. Focus on Autism and Other Developmental Disabilities. 2008;23(3):148-54. X-3,X-4.
147 Gray KM, Tonge BJ, Sweeney DJ, et al. Screening for autism in young children with developmental delay: an evaluation of the developmental behaviour checklist: early screen. J Autism Dev Disord. Jul. 2008;38(6):1003-10. [pmid: 17972169].
148 Greenspan SI, Brazelton TB, Cordero J, et al. Guidelines for early identification, screening, and clinical management of children with autism spectrum disorders. Pediatrics. Apr. 2008;121(4):828-30. X-2, X-3, X-4, X-5. [pmid: 18381546].
149 Herba CM, de Bruin E, Althaus M, et al. Face and emotion recognition in MCDD versus PDD-NOS. J Autism Dev Disord. Apr. 2008;38(4):706-18. X-1, X-3, X-4. [pmid: 17721812].
150 Hess KL, Morrier MJ, Heflin LJ, et al. Autism treatment survey: services received by children with autism spectrum disorders in public school classrooms. J Autism Dev Disord. May. 2008;38(5):961-71. X-1, X-3, X-4. [pmid: 17929155].
151 Hoekstra RA, Bartels M, Cath DC, et al. Factor structure, reliability and criterion validity of the Autism-Spectrum Quotient (AQ): a study in Dutch population and patient groups. J Autism Dev Disord. Sep. 2008;38(8):1555-66. X-1, X-3,X-4. [pmid: 18302013].
152 Johnson CP. Recognition of autism before age 2 years. Pediatr Rev. Mar. 2008;29(3):86-96. X-2, X-3, X-4, X-5. [pmid: 18310467].
153 Kawamura Y, Takahashi O, Ishii T. Reevaluating the incidence of pervasive developmental disorders: Impact of elevated rates of detection through implementation of an integrated system of screening in Toyota, Japan. Psychiatry and Clinical Neurosciences. 2008;62(2):152-9. X-4. [pmid: 18412836].
154 Kleinman JM, Ventola PE, Pandey J, et al. Diagnostic stability in very young children with autism spectrum disorders. J Autism Dev Disord. Apr. 2008;38(4):606-15. X-4. [pmid: 17924183].
155 Kurita H, Koyama T, Inoue K. Reliability and validity of the Pervasive Developmental Disorders Assessment System. Psychiatry Clin Neurosci. Apr. 2008;62(2):226-33. X-1, X-4. [pmid: 18412847].
156 Lejarraga H, Menendez AM, Menzano E, et al. Screening for developmental problems at primary care level: a field programme in San Isidro, Argentina. Paediatr Perinat Epidemiol. Mar. 2008;22(2):180-7. X-1, X-3. [pmid: 18298693].
157 Limperopoulos C, Bassan H, Sullivan NR, et al. Positive screening for autism in ex-preterm infants: prevalence and risk factors. Pediatrics. Apr. 2008;121(4):758-65. X-4. [pmid: 18381541]. RETAIN FOR CONTEXT
158 Luyster RJ, Kadlec MB, Carter A, et al. Language assessment and development in toddlers with autism spectrum disorders. J Autism Dev Disord. Sep. 2008;38(8):1426-38. X-1, X-4. [pmid: 18188685].
159 Matson JL, Dempsey T, Rivet T. A comparison of Asperger symptom rating scales with children and adolescents. Research in Autism Spectrum Disorders. 2008;2(4):643-50. X-3.
160 Matson JL, Gonzalez ML, Rivet TT. Reliability of the Autism Spectrum Disorder-Behavior Problems for Children (ASD-BPC). Research in Autism Spectrum Disorders. 2008;2(4):696-706. X-1, X-4.
161 Ozonoff S, Heung K, Byrd R, et al. The onset of autism: patterns of symptom emergence in the first years of life. Autism Res. Dec. 2008;1(6):320-8. X-1, X-2, X-3, X-4. [pmid: 19360687].
162 Ozonoff S, Macari S, Young GS, et al. Atypical object exploration at 12 months of age is associated with autism in a prospective sample. Autism. Sep. 2008;12(5):457-72. X-1, X-3, X-4. [pmid: 18805942].
163 Pine DS, Guyer AE, Goldwin M, et al. Autism spectrum disorder scale scores in pediatric mood and anxiety disorders. J Am Acad Child Adolesc Psychiatry. Jun. 2008;47(6):652-61. X-1, X-3,X-4. [pmid: 18434923].
164 Pinto-Martin JA, Young LM, Mandell DS, et al. Screening strategies for autism spectrum disorders in pediatric primary care. J Dev Behav Pediatr. Oct. 2008;29(5):345-50. X-4. [pmid: 18852608].
165 Rapin I, Tuchman RF. Autism: definition, neurobiology, screening, diagnosis. Pediatr Clin North Am. Oct. 2008;55(5):1129-46. viii. X-2, X-3, X-4, X-5. [pmid: 18929056].
166 Ronald A, Happe F, Plomin R. A twin study investigating the genetic and environmental aetiologies of parent, teacher and child ratings of autistic-like traits and their overlap. Eur Child Adolesc Psychiatry. Dec. 2008;17(8):473-83. X-1, X-3,X-4. [pmid: 18427861].
167 Santaella ML, Varela Y, Linares N, et al. Prevalence of autism spectrum disorders in relatives of patients with selective immunoglobulin A deficiency. P R Health Sci J. Sep. 2008;27(3):204-8. X-1, X-3, X-4, X-5. [pmid: 18782963].
168 Scholte EM, Van Berckelaer-Onnes I, Van der Ploeg JD. Rating scale to screen symptoms of psychiatric disorders in children. European Journal of Special Needs Education. 2008;23(1):47-62. X-3,X-4.
169 Seif Eldin A, Habib D, Noufal A, et al. Use of M-CHAT for a multinational screening of young children with autism in the Arab countries. Int Rev Psychiatry. Jun. 2008;20(3):281-9. X-5. [pmid: 18569180].
170 Sikora DM, Hall TA, Hartley SL, et al. Does parent report of behavior differ across ADOS-G classifications: analysis of scores from the CBCL and GARS. J Autism Dev Disord. Mar. 2008;38(3):440-8. X-3, X-4. [pmid: 17619131].
171 Snow AV, Lecavalier L. Sensitivity and specificity of the Modified Checklist for Autism in Toddlers and the Social Communication Questionnaire in preschoolers suspected of having pervasive developmental disorders. Autism. Nov. 2008;12(6):627-44. [pmid: 19005032].
172 Steyaert JG, De la Marche W. What's new in autism?. Eur J Pediatr. Oct. 2008;167(10):1091-101. X-1, X-2, X-3, X-4, X-5. [pmid: 18597114].
173 Stone WL, McMahon CR, Henderson LM. Use of the Screening Tool for Autism in Two-Year-Olds (STAT) for children under 24 months: an exploratory study. Autism. Sep. 2008;12(5):557-73. X-4. [pmid: 18805947].
174 Suhail K, Zafar F. Prevalence of autism in special education schools of Lahore. Pakistan Journal of Psychological Research. 2008;23(3-4):45-64. X-1, X-4, X-5.
175 Taniai H, Nishiyama T, Miyachi T, et al. Genetic influences on the broad spectrum of autism: study of proband-ascertained twins. Am J Med Genet B Neuropsychiatr Genet. Sep. 5. 2008;147B(6):844-9. X-1, X-3, X-4. [pmid: 18361421].
176 Wallis KE, Pinto-Martin J. The challenge of screening for autism spectrum disorder in a culturally diverse society. Acta Paediatr. May. 2008;97(5):539-40. X-2, X-3,X-4. [pmid: 18373717].
177 Wallis KE, Smith SM. School health developmental screening in pediatric primary care: the role of nurses. J Spec Pediatr Nurs. Apr. 2008;13(2):130-4. X-2, X-3, X-4, X-5. [pmid: 18366381].
178 Wiggins LD, Robins DL. Brief report: excluding the ADI-R behavioral domain improves diagnostic agreement in toddlers. J Autism Dev Disord. May. 2008;38(5):972-6. X-4. [pmid: 17879150].
179 Anderson GM. Conceptualizing Autism: The Role for Emergence. Journal of the American Academy of Child & Adolescent Psychiatry. 2009;48(7):688. X-1, X-2, X-3, X-4. [pmid: 19542823].
180 Bauer SC, Smith PJ, Chien AT, et al. Educating Pediatric Residents about Developmental and Social-Emotional Health. Infants and Young Children. 2009;22(4):309-20. X-1, X-3, X-4, X-5.
181 Bhattacharyya R, Sanyal D, Roy K, et al. A study of cluster behavioral abnormalities in Down syndrome. Indian J Med Sci. Feb. 2009;63(2):58-65. X-1, X-3, X-4. [pmid: 19359768].
182 Chakrabarti S. Early identification of autism. Indian Pediatr. May. 2009;46(5):412-4. X-1, X-3, X-4, X-5. [pmid: 19179745].
183 de Bildt A, Mulder EJ, Hoekstra PJ, et al. Validity of the Children's Social Behavior Questionnaire (CSBQ) in children with intellectual disability: comparing the CSBQ with ADI-R, ADOS, and clinical DSM-IV-TR classification. J Autism Dev Disord. Oct. 2009;39(10):1464-70. X-1, X-2, X-3, X-4. [pmid: 19495951].
184 Deb S, Dhaliwal A-J, Roy M. The usefulness of the DBC-ASA as a screening instrument for autism in children with intellectual disabilities: A pilot study. Journal of Applied Research in Intellectual Disabilities. 2009;22(5):498-501. X-3.
185 Duby JC, Johnson CP. Universal screening for autism spectrum disorders: a snapshot within the big picture. Pediatr Ann. Jan. 2009;38(1):36-41. X-2, X-3 ,X-4. [pmid: 19213292].
186 Earls MF, Andrews JE, Hay SS. A longitudinal study of developmental and behavioral screening and referral in North Carolina's Assuring Better Child Health and Development participating practices. Clin Pediatr (Phila). Oct. 2009;48(8):824-33. X-1. [pmid: 19571336].
187 Fodstad JC, Matson JL, Hess J, et al. Social and communication behaviours in infants and toddlers with autism and pervasive developmental disorder-not otherwise specified. Dev Neurorehabil. Jun. 2009;12(3):152-7. X-4. [pmid: 19466623].
188 Gillis JM. Screening practices of family physicians and pediatricians in 2 southern states. Infants & Young Children. 2009;22(4):321-31. X-3, X-4.
189 Goldson E. Autism: an update. Adv Pediatr. 2009;56:187-201. X-2, X-3, X-4, X-5. [pmid: 19968949].
190 Goldwater- Adler S, MacLeod CG, Smith IM. DSMD in triage of youth seen at a specialty autism clinic. Journal on Developmental Disabilities. 2009;15(2):63-71. X-1, X-3, X-4.
191 Hack M, Taylor HG, Schluchter M, et al. Behavioral outcomes of extremely low birth weight children at age 8 years. J Dev Behav Pediatr. Apr. 2009;30(2):122-30. X-1, X-3 ,X-4. [pmid: 19322106].
192 Hepburn SL, Maclean WE. Maladaptive and repetitive behaviors in children with Down syndrome and autism spectrum disorders: Implications for screening. Journal of Mental Health Research in Intellectual Disabilities. 2009;2(2):67-88. X-1, X-3 ,X-4.
193 Inglese MD. Caring for children with autism spectrum disorder. Part II: screening, diagnosis, and management. J Pediatr Nurs. Feb. 2009;24(1):49-59. X-2, X-3, X-4, X-5. [pmid: 19159835].
194 Karabekiroglu K, Aman MG. Validity of the aberrant behavior checklist in a clinical sample of toddlers. Child Psychiatry Hum Dev. Mar. 2009;40(1):99-110. X-1, X-4 ,X-5. [pmid: 18600444].
195 Kiser K. The power of books. Minn Med. Mar. 2009;92(3):9-11. X-1, X-2, X-3, X-4. [pmid: 19400377].
196 Kuban KC, O'Shea TM, Allred EN, et al. Positive screening on the Modified Checklist for Autism in Toddlers (M-CHAT) in extremely low gestational age newborns. J Pediatr. Apr. 2009;154(4):535-40 e1. X-4. [pmid: 19185317].
197 Levy SE, Mandell DS, Schultz RT. Autism. Lancet. Nov. 7. 2009;374(9701):1627-38. X-2, X-3, X-4, X-5. [pmid: 19819542].
198 Limperopoulos C. Autism spectrum disorders in survivors of extreme prematurity. Clin Perinatol. Dec. 2009;36(4):791-805. vi. X-2, X-3, X-4, X-5. [pmid: 19944836].
199 Matson JL, Boisjoli J, Rojahn J, et al. A factor analysis of challenging behaviors assessed with the baby and infant screen for children with autism traits (Biscuit-Part 3). Research in Autism Spectrum Disorders. 2009;3(3):714-22. X-1, X-4.
200 Matson JL, Dempsey T, Fodstad JC. Stereotypies and repetitive/restrictive behaviours in infants with autism and pervasive developmental disorder. Dev Neurorehabil. Jun. 2009;12(3):122-7. X-4. [pmid: 19466619].
201 Matson JL, Fodstad JC, Dempsey T. What symptoms predict the diagnosis of autism or PDD-NOS in infants and toddlers with developmental delays using the Baby and Infant Screen for aUtIsm Traits. Dev Neurorehabil. 2009;12(6):381-8. [pmid: 20205546].
202 Matson JL, Fodstad JC, Mahan S. Cutoffs, norms, and patterns of comorbid difficulties in children with developmental disabilities on the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Part 2). Res Dev Disabil. Nov-Dec. 2009;30(6):1221-8. X-1, X-3, X-4. [pmid: 19450951].
203 Matson JL, Wilkins J, Sevin JA, et al. Reliability and item content of the baby and infant screen for children with aUtIsm traits (BISCUIT): Parts 1–3. Research in Autism Spectrum Disorders. 2009;3(2):336-44. X-4.
204 Matson JL, Wilkins J, Sharp B, et al. Sensitivity and specificity of the Baby and Infant Screen for Children with Autism Traits (BISCUIT): Validity and cutoff scores for autism and PDD-NOS in toddlers. Research in Autism Spectrum Disorders. 2009;3(4):924-30.
205 Niklasson L, Rasmussen P, Óskarsdóttir S, et al. Autism, ADHD, mental retardation and behavior problems in 100 individuals with 22q11 deletion syndrome. Research in Developmental Disabilities. 2009;30(4):763-73. X-1. [pmid: 19070990].
206 Oosterling IJ, Swinkels SH, van der Gaag RJ, et al. Comparative analysis of three screening instruments for autism spectrum disorder in toddlers at high risk. J Autism Dev Disord. Jun. 2009;39(6):897-909. [pmid: 19205862].
207 Pandolfi V, Magyar CI, Dill CA. Confirmatory factor analysis of the child behavior checklist 1.5-5 in a sample of children with autism spectrum disorders. J Autism Dev Disord. Jul. 2009;39(7):986-95. X-1, X-4. [pmid: 19263208].
208 Perera H, Wijewardena K, Aluthwelage R. Screening of 18-24-month-old children for autism in a semi-urban community in Sri Lanka. J Trop Pediatr. Dec. 2009;55(6):402-5. X-5. [pmid: 19401407].
209 Rojahn J, Matson JL, Mahan S, et al. Cutoffs, norms, and patterns of problem behaviors in children with an ASD on the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Part 3). Research in Autism Spectrum Disorders. 2009;3(4):989-98. X-1, X-4.
210 Roscoe EM, Rooker GW, Pence ST, et al. Assessing the utility of a demand assessment for functional analysis. J Appl Behav Anal. Winter. 2009;42(4):819-25. X-1, X-3, X-4. [pmid: 20514188].
211 Santosh PJ, Mandy WP, Puura K, et al. The construction and validation of a short form of the developmental, diagnostic and dimensional interview. Eur Child Adolesc Psychiatry. Aug. 2009;18(8):521-4. X-1, X-3, X-4. [pmid: 19263189].
212 Sato FP, Paula CS, Lowenthal R, et al. Instrument to screen cases of pervasive developmental disorder: a preliminary indication of validity. Rev Bras Psiquiatr. Mar. 2009;31(1):30-3. X-3, X-4, X-5. [pmid: 19506772].
213 Shattuck PT, Durkin M, Maenner M, et al. Timing of identification among children with an autism spectrum disorder: findings from a population-based surveillance study. J Am Acad Child Adolesc Psychiatry. May. 2009;48(5):474-83. X-1, X-3, X-4. [pmid: 19318992].
214 van Daalen E, Kemner C, Dietz C, et al. Inter-rater reliability and stability of diagnoses of autism spectrum disorder in children identified through screening at a very young age. Eur Child Adolesc Psychiatry. Nov. 2009;18(11):663-74. X-4. [pmid: 19421728].
215 Van Dyke EM. Autistic disorder: early interventions can improve outcomes. JAAPA. Jul. 2009;22(7):18-9. X-1, X-2, X-3, X-4. [pmid: 19697566].
216 Warren Z, Stone W, Humberd Q. A training model for the diagnosis of autism in community pediatric practice. J Dev Behav Pediatr. Oct. 2009;30(5):442-6. X-4. [pmid: 19823138].
217 Wiggins LD, Robins DL, Bakeman R, et al. Brief report: sensory abnormalities as distinguishing symptoms of autism spectrum disorders in young children. J Autism Dev Disord. Jul. 2009;39(7):1087-91. X-1, X-4. [pmid: 19283461].
218 Xu D, Gilkerson J, Richards J, et al. Child vocalization composition as discriminant information for automatic autism detection. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:2518-22. X-1, X-3, X-4. [pmid: 19964971].
219 Zwaigenbaum L, Bryson S, Lord C, et al. Clinical assessment and management of toddlers with suspected autism spectrum disorder: insights from studies of high-risk infants. Pediatrics. May. 2009;123(5):1383-91. X-2, X-3, X-4, X-5. [pmid: 19403506].
220 Allen SG, Berry AD, Brewster JA, et al. Enhancing developmentally oriented primary care: an Illinois initiative to increase developmental screening in medical homes. Pediatrics. Dec. Suppl 3. 2010;126:S160-4. X-1,X-3,X-4. [pmid: 21123480].
221 Biederman J, Petty CR, Fried R, et al. Child behavior checklist clinical scales discriminate referred youth with autism spectrum disorder: a preliminary study. J Dev Behav Pediatr. Jul-Aug. 2010;31(6):485-90. X-3, X-4. [pmid: 20585266].
222 Charman T. Developmental approaches to understanding and treating autism. Folia Phoniatr Logop. 2010;62(4):166-77. X-1, X-2, X-3, X-4. [pmid: 20460929].
223 Chlebowski C, Green JA, Barton ML, et al. Using the Childhood Autism Rating Scale to Diagnose Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2010;40(7):787-99. X-4. [pmid: 20054630].
224 Dereu M, Warreyn P, Raymaekers R, et al. Screening for autism spectrum disorders in Flemish day-care centres with the checklist for early signs of developmental disorders. J Autism Dev Disord. Oct. 2010;40(10):1247-58. X-1. [pmid: 20198413].
225 DiGuiseppi C, Hepburn S, Davis JM, et al. Screening for autism spectrum disorders in children with Down syndrome: population prevalence and screening test characteristics. J Dev Behav Pediatr. Apr. 2010;31(3):181-91. X-4. [pmid: 20375732].
226 Fujibayashi H, Kitayama S, Matsuo M. Score of inattention subscale of ADHD rating scale-IV is significantly higher for AD/HD than PDD. Kobe J Med Sci. 2010;56(1):E12-7. X-3, X-4. [pmid: 21063141].
227 Ghaziuddin M, Welch K, Mohiuddin S, et al. Utility of the Social and Communication Questionnaire in the differentiation of autism from ADHD. Journal of Developmental and Physical Disabilities. 2010;22(4):359-66. X-3, X-4, X-5.
228 Gillberg C. The ESSENCE in child psychiatry: Early Symptomatic Syndromes Eliciting Neurodevelopmental Clinical Examinations. Res Dev Disabil. Nov-Dec. 2010;31(6):1543-51. X-1, X-2, X-3, X-4. [pmid: 20634041].
229 Granader YE, Bender HA, Zemon V, et al. The clinical utility of the Social Responsiveness Scale and Social Communication Questionnaire in tuberous sclerosis complex. Epilepsy Behav. Jul. 2010;18(3):262-6. X-3, X-4. [pmid: 20554253].
230 Gunnar MR. A Commentary on “Deprivation-Specific Psychological Patterns: Effects of Institutional Deprivation”. Monographs of the Society for Research in Child Development. 2010;75(1):232-47. X-1, X-2, X-3, X-4. [pmid: 20500642].
231 Hedley D, Young R, Angelica M, et al. Cross-cultural evaluation of the Autism Detection in Early Childhood (ADEC) in Mexico. Autism. Mar. 2010;14(2):93-112. X-5. [pmid: 20395280].
232 Hoglund Carlsson L, Gillberg C, Lannero E, et al. Autism: screening toddlers with CHAT in a child health care programme did not improve early identification. Acta Paediatr. Dec. 2010;99(12):1897-9. X-4. [pmid: 20670307].
233 Horovitz M, Matson JL. Communication deficits in babies and infants with autism and pervasive developmental disorder-not otherwise specified (PDD-NOS). Dev Neurorehabil. 2010;13(6):390-8. X-1, X-4. [pmid: 20887201].
234 Hutman T, Rozga A, DeLaurentis AD, et al. Response to distress in infants at risk for autism: a prospective longitudinal study. J Child Psychol Psychiatry. Sep. 2010;51(9):1010-20. X-1. [pmid: 20546081].
235 Inada N, Kamio Y, Koyama T. Developmental chronology of preverbal social behaviors in infancy using the M-CHAT: Baseline for early detection of atypical social development. Research in Autism Spectrum Disorders. 2010;4(4):605-11. X-3, X-4.
236 Juneja M, Sharma S, Mukherjee SB. Sensitivity of the Autism Behavior Checklist in Indian autistic children. Journal of Developmental and Behavioral Pediatrics. 2010;31(1):48-9. X-1, X-3, X-4, X-5. [pmid: 20081436].
237 Karabekiroglu K, Briggs-Gowan MJ, Carter AS, et al. The clinical validity and reliability of the Brief Infant-Toddler Social and Emotional Assessment (BITSEA). Infant Behav Dev. Dec. 2010;33(4):503-9. X-5. [pmid: 20800285].
238 Karmel BZ, Gardner JM, Meade LS, et al. Early medical and behavioral characteristics of NICU infants later classified with ASD. Pediatrics. Sep. 2010;126(3):457-67. X-1, X-3, X-4. [pmid: 20679296].
239 Koyama T, Inokuchi E, Inada N, et al. Utility of the Japanese version of the Checklist for Autism in Toddlers for predicting pervasive developmental disorders at age 2. Psychiatry Clin Neurosci. Jun. 2010;64(3):330-2. [pmid: 20602732].
240 Larson T, Anckarsater H, Gillberg C, et al. The autism--tics, AD/HD and other comorbidities inventory (A-TAC): further validation of a telephone interview for epidemiological research. BMC Psychiatry. 2010;10:1. X-3, X-4. [pmid: 20055988].
241 Lowenthal R, Mercadante MT, Filho JFB, et al. Autism spectrum disorder in Down syndrome: Definition of the cutoff point for the Autism Screening Questionnaire screening instrument. Journal of Developmental and Behavioral Pediatrics. 2010;31(8):684. X-2, X-3, X-4, X-5. [pmid: 20924246].
242 Lung FW, Shu BC, Chiang TL, et al. Parental concerns based general developmental screening tool and autism risk: the Taiwan National Birth cohort study. Pediatr Res. Feb. 2010;67(2):226-31. X-1, X-3, X-4, X-5. [pmid: 20091940].
243 Matson JL, Boisjoli JA, Hess JA, et al. Factor structure and diagnostic fidelity of the Baby and Infant Screen for Children with aUtIsm Traits-Part 1 (BISCUIT-part 1). Dev Neurorehabil. 2010;13(2):72-9. X-4. [pmid: 20222767].
244 Matson JL, Fodstad JC, Mahan S, et al. Cut-offs, norms and patterns of problem behaviours in children with developmental disabilities on the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Part 3). Dev Neurorehabil. Feb. 2010;13(1):3-9. X-1, X-3, X-4. [pmid: 20067340].
245 McClure I, MacKay T, Mamdani H, et al. A Comparison of a Specialist Autism Spectrum Disorder Assessment Team with Local Assessment Teams. Autism: The International Journal of Research and Practice. 2010;14(6):589-603. X-1, X-3, X-4. [pmid: 20923893].
246 Moricke E, Swinkels SH, Beuker KT, et al. Predictive value of subclinical autistic traits at age 14-15 months for behavioural and cognitive problems at age 3-5 years. Eur Child Adolesc Psychiatry. Aug. 2010;19(8):659-68. X-4. [pmid: 20390313].
247 Oosterling I, Rommelse N, de Jonge M, et al. How useful is the Social Communication Questionnaire in toddlers at risk of autism spectrum disorder?. J Child Psychol Psychiatry. Nov. 2010;51(11):1260-8. [pmid: 20626528].
248 Oosterling IJ, Wensing M, Swinkels SH, et al. Advancing early detection of autism spectrum disorder by applying an integrated two-stage screening approach. J Child Psychol Psychiatry. Mar. 2010;51(3):250-8. [pmid: 19843319].
249 Ozonoff S, Iosif AM, Baguio F, et al. A prospective study of the emergence of early behavioral signs of autism. J Am Acad Child Adolesc Psychiatry. Mar. 2010;49(3):256-66 e1-2. X-1, X-3, X-4. [pmid: 20410715].
250 Pandolfi V, Magyar CI, Dill CA. Constructs assessed by the GARS-2: factor analysis of data from the standardization sample. J Autism Dev Disord. Sep. 2010;40(9):1118-30. X-3, X-4. [pmid: 20151186].
251 Rao S, Salmon G. Autism spectrum disorders. Br J Hosp Med (Lond). Dec. 2010;71(12):699-703. X-1, X-2, X-3, X-4, X-5. [pmid: 21135768].
252 Rodman JL, Gilbert KA, Grove AB, et al. Efficacy of brief quantitative measures of play for screening for autism spectrum disorders. J Autism Dev Disord. Mar. 2010;40(3):325-33. X-1, X-4. [pmid: 19798562].
253 Staines R. School nurses can help identify children with undiagnosed autism. Paediatr Nurs. Mar. 2010;22(2):7. X-1, X-2, X-3, X-4. [pmid: 20373658].
254 Stilp RL, Gernsbacher MA, Schweigert EK, et al. Genetic variance for autism screening items in an unselected sample of toddler-age twins. J Am Acad Child Adolesc Psychiatry. Mar. 2010;49(3):267-76. X-4. [pmid: 20410716].
255 Stoltenberg C, Schjolberg S, Bresnahan M, et al. The Autism Birth Cohort: a paradigm for gene-environment-timing research. Mol Psychiatry. Jul. 2010;15(7):676-80. X-1, X-4. [pmid: 20571529].
256 Volker MA, Lopata C, Smerbeck AM, et al. BASC-2 PRS profiles for students with high-functioning autism spectrum disorders. J Autism Dev Disord. Feb. 2010;40(2):188-99. X-1, X-3, X-4. [pmid: 19705267].
257 Ward SL, Gilmore L. The autistic behavioural indicators instrument (ABII): Development and instrument utility in discriminating autistic disorder from speech and language impairment and typical development. Research in Autism Spectrum Disorders. 2010;4(1):28-42. X-4.
258 Absoud M, Parr JR, Salt A, et al. Developing a schedule to identify social communication difficulties and autism spectrum disorder in young children with visual impairment. Dev Med Child Neurol. Mar. 2011;53(3):285-8. X-3. [pmid: 21166670].
259 Allely CS, Wilson P. Diagnosing autism spectrum disorders in primary care. Practitioner. Nov. 2011;255(1745):27-30. 3. X-1, X-2, X-3, X-4. [pmid: 22235552].
260 Allen-Brady K, Cai G, Cannon D, et al. No evidence for IL1RAPL1 involvement in selected high-risk autism pedigrees from the AGRE data set. Autism Res. Aug. 2011;4(4):293-6. X-1, X-3 ,X-4. [pmid: 21491612].
261 Al-Qabandi M, Gorter JW, Rosenbaum P. Early autism detection: are we ready for routine screening?. Pediatrics. Jul. 2011;128(1):e211-7. X-2, X-3, X-4, X-5. [pmid: 21669896].
262 Bethell CD, Kogan MD, Strickland BB, et al. A national and state profile of leading health problems and health care quality for US children: key insurance disparities and across-state variations. Acad Pediatr. May-Jun. 2011;11(3 Suppl):S22-33. X-1, X-4. [pmid: 21570014].
263 Bolduc ME, Du Plessis AJ, Sullivan N, et al. Spectrum of neurodevelopmental disabilities in children with cerebellar malformations. Dev Med Child Neurol. May. 2011;53(5):409-16. X-4. [pmid: 21418200].
264 Bolte S, Westerwald E, Holtmann M, et al. Autistic traits and autism spectrum disorders: the clinical validity of two measures presuming a continuum of social communication skills. J Autism Dev Disord. Jan. 2011;41(1):66-72. X-1, X-3 ,X-4. [pmid: 20422277].
265 Duquette C, Orders S, Fullarton S, et al. Fighting for Their Rights: Advocacy Experiences of Parents of Children Identified with Intellectual Giftedness. Journal for the Education of the Gifted. 2011;34(3):488-512. X-1, X-3,X-4.
266 Esposito G, Venuti P, Bornstein MH. Assessment of distress in young children: A comparison of autistic disorder, developmental delay, and typical development. Research in Autism Spectrum Disorders. 2011;5(4):1510-6. X-1, X-3,X-4. [pmid: 21647245].
267 Gau SS-F, Lee C-M, Lai M-C, et al. Psychometric properties of the Chinese version of the Social Communication Questionnaire. Research in Autism Spectrum Disorders. 2011;5(2):809-18. X-4, X-5.
268 Ghuman JK, Leone SL, Lecavalier L, et al. The screen for social interaction (SSI): a screening measure for autism spectrum disorders in preschoolers. Res Dev Disabil. Nov-Dec. 2011;32(6):2519-29. X-3, X-4. [pmid: 21821391].
269 Gillis JM, Callahan EH, Romanczyk RG. Assessment of Social Behavior in Children with Autism: The Development of the Behavioral Assessment of Social Interactions in Young Children. Research in Autism Spectrum Disorders. 2011;5(1):351-60. X-3, X-4.
270 Guo YQ, Tang Y, Rice C, et al. Validation of the Autism Spectrum Screening Questionnaire, Mandarin Chinese Version (CH-ASSQ) in Beijing, China. Autism. Nov. 2011;15(6):713-27. X-3, X-4, X-5. [pmid: 21690211].
271 Gura GF, Champagne MT, Blood-Siegfried JE. Autism spectrum disorder screening in primary care. Journal of Developmental and Behavioral Pediatrics. 2011;32(1):48-51. X-4. [pmid: 21160437].
272 Horovitz M, Matson JL, Rieske RD, et al. The relationship between race and challenging behaviours in infants and toddlers with autistic disorder and pervasive developmental disorder-not otherwise specified. Dev Neurorehabil. 2011;14(4):208-14. X-1, X-4. [pmid: 21732805].
273 Karabekiroğlu K, Akbaş S. Identifying and differentiating PDD-NOS: A comparison with autism and ADHD. Yeni Symposium: psikiyatri, nöroloji ve davraniş bilimleri dergisi. 2011;49(3):141-52. X-1, X-4, X-5.
274 Kopp S, Gillberg C. The Autism Spectrum Screening Questionnaire (ASSQ)-Revised Extended Version (ASSQ-REV): an instrument for better capturing the autism phenotype in girls? A preliminary study involving 191 clinical cases and community controls. Res Dev Disabil. Nov-Dec. 2011;32(6):2875-88. X-3, X-4. [pmid: 21664105].
275 Lung F-W, Chiang T-L, Lin S-J, et al. Autism-risk screening in the first 3 years of life in Taiwan birth cohort pilot study. Research in Autism Spectrum Disorders. 2011;5(4):1385-9. X-4, X-5.
276 Luyster RJ, Kuban KC, O'Shea TM, et al. The Modified Checklist for Autism in Toddlers in extremely low gestational age newborns: individual items associated with motor, cognitive, vision and hearing limitations. Paediatr Perinat Epidemiol. Jul. 2011;25(4):366-76. X-4. [pmid: 21649679].
277 Manning SE, Davin CA, Barfield WD, et al. Early diagnoses of autism spectrum disorders in Massachusetts birth cohorts, 2001-2005. Pediatrics. Jun. 2011;127(6):1043-51. X-1, X-4. [pmid: 21576313].
278 Matson JL, Boisjoli JA, Hess JA, et al. Comorbid psychopathology factor structure on the Baby and Infant Screen for Children with aUtIsm Traits-Part 2 (BISCUIT-Part 2). Research in Autism Spectrum Disorders. 2011;5(1):426-32. X-1, X-4.
279 Matson JL, Kozlowski AM, Neal D, et al. Cutoffs for the Matson Evaluation of Social Skills with Youngsters-II (MESSY-II) for typically developing children and for children diagnosed with autism spectrum disorders. Research in Autism Spectrum Disorders. 2011;5(2):798-802. X-1, X-4.
280 Matson JL, Mahan S, Fodstad JC, et al. Effects of symptoms of co-morbid psychopathology on challenging behaviours among infants and toddlers with Autistic Disorder and PDD-NOS as assessed with the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT). Dev Neurorehabil. 2011;14(3):129-39. X-4. [pmid: 21548853].
281 Matson JL, Wilkins J, Fodstad JC. The validity of the Baby and Infant Screen for Children with aUtIsm Traits: Part 1 (BISCUIT: Part 1). J Autism Dev Disord. Sep. 2011;41(9):1139-46. X-4. [pmid: 20177764].
282 Mazefsky CA, Anderson R, Conner CM, et al. Child Behavior Checklist scores for school-aged children with autism: Preliminary evidence of patterns suggesting the need for referral. Journal of Psychopathology and Behavioral Assessment. 2011;33(1):31-7. X-3,X-4. [pmid: 22661827].
283 McLaughlin MR. Speech and language delay in children. Am Fam Physician. May. 15. 2011;83(10):1183-8. X-1, X-2, X-3, X-4. [pmid: 21568252].
284 Mouridsen SE, Hauschild KM. Autism spectrum disorders in siblings of children with a developmental language disorder. Logoped Phoniatr Vocol. Dec. 2011;36(4):145-9. X-1, X-3, X-4. [pmid: 21446849].
285 Muratori F, Narzisi A, Tancredi R, et al. The CBCL 1.5-5 and the identification of preschoolers with autism in Italy. Epidemiol Psychiatr Sci. Dec. 2011;20(4):329-38. X-4. [pmid: 22201210].
286 Murray MJ, Mayes SD, Smith LA. Brief Report: Excellent Agreement between Two Brief Autism Scales (Checklist for Autism Spectrum Disorder and Social Responsiveness Scale) Completed Independently by Parents and the Autism Diagnostic Interview-Revised. Journal of Autism and Developmental Disorders. 2011;41(11):1586-90. X-2, X-3, X-4. [pmid: 21301946].
287 Ooi YP, Rescorla L, Ang RP, et al. Identification of autism spectrum disorders using the Child Behavior Checklist in Singapore. J Autism Dev Disord. Sep. 2011;41(9):1147-56. X-3, X-4. [pmid: 20405192].
288 Palmer E, Ketteridge C, Parr JR, et al. Autism spectrum disorder diagnostic assessments: improvements since publication of the National Autism Plan for Children. Arch Dis Child. May. 2011;96(5):473-5. X-3, X-4. [pmid: 20522453].
289 Paula CS, Ribeiro SH, Fombonne E, et al. Brief report: prevalence of pervasive developmental disorder in Brazil: a pilot study. J Autism Dev Disord. Dec. 2011;41(12):1738-42. X-3, X-4 ,X-5. [pmid: 21337063].
290 Pierce K, Conant D, Hazin R, et al. Preference for geometric patterns early in life as a risk factor for autism. Arch Gen Psychiatry. Jan. 2011;68(1):101-9. X-1. [pmid: 20819977].
291 Pinto-Martin JA, Levy SE, Feldman JF, et al. Prevalence of autism spectrum disorder in adolescents born weighing <2000 grams. Pediatrics. Nov. 2011;128(5):883-91. X-3, X-4. [pmid: 22007018].
292 Pool JL, Hourcade JJ. Developmental Screening: A Review of Contemporary Practice. Education and Training in Autism and Developmental Disabilities. 2011;46(2):267-75. X-2, X-3, X-4.
293 Rowland C. Using the Communication Matrix to Assess Expressive Skills in Early Communicators. Communication Disorders Quarterly. 2011;32(3):190-201. X-1, X-3, X-4.
294 Sipes M, Matson JL, Horovitz M. Autism spectrum disorders and motor skills: the effect on socialization as measured by the Baby And Infant Screen For Children with aUtIsm Traits (BISCUIT). Dev Neurorehabil. 2011;14(5):290-6. X-1, X-4. [pmid: 21870953].
295 Sipes M, Matson JL, Turygin N. The use of the Battelle Developmental Inventory-Second Edition (BDI-2) as an early screener for autism spectrum disorders. Dev Neurorehabil. 2011;14(5):310-4. X-3. [pmid: 21870955].
296 Suzuki M, Tachimori H, Saito M, et al. Development of a screening scale for high-functioning pervasive developmental disorders using the Tokyo Child Development Schedule and Tokyo Autistic Behavior Scale. Research in Autism Spectrum Disorders. 2011;5(2):843-54. X-3, X-4.
297 Tonge B, Brereton A. Autism spectrum disorders. Aust Fam Physician. Sep. 2011;40(9):672-7. X-2, X-3 ,X-4. [pmid: 21894273].
298 van Daalen E, Kemner C, Verbeek NE, et al. Social Responsiveness Scale-aided analysis of the clinical impact of copy number variations in autism. Neurogenetics. Nov. 2011;12(4):315-23. X-3, X-4. [pmid: 21837366].
299 Vanvuchelen M, Roeyers H, De Weerdt W. Imitation Assessment and Its Utility to the Diagnosis of Autism: Evidence from Consecutive Clinical Preschool Referrals for Suspected Autism. Journal of Autism and Developmental Disorders. 2011;41(4):484-96. X-1, X-4. [pmid: 20683767].
300 Webb PL. Screening for Autism Spectrum Disorders During Well-Child Visits in a Primary Care Setting. Journal for Nurse Practitioners. 2011;7(3):229-35. X-4.
301 Worley JA, Matson JL, Kozlowski AM. The effects of hearing impairment on symptoms of autism in toddlers. Dev Neurorehabil. 2011;14(3):171-6. X-4. [pmid: 21548858].
302 Worley JA, Matson JL, Mahan S, et al. Stability of symptoms of autism spectrum disorders in toddlers: an examination using the Baby and Infant Screen for Children with aUtIsm Traits-Part 1 (BISCUIT). Dev Neurorehabil. 2011;14(1):36-40. X-4. [pmid: 21241177].
303 Worley JA, Matson JL, Sipes M, et al. Prevalence of autism spectrum disorders in toddlers receiving early intervention services. Research in Autism Spectrum Disorders. 2011;5(2):920-5. X-4.
304 Yamada Y, Yoshida F, Hemmi H, et al. Atypical social development in neonatal intensive care unit survivors at 12 months. Pediatr Int. Dec. 2011;53(6):858-66. X-4. [pmid: 21429057].
305 Young GS, Rogers SJ, Hutman T, et al. Imitation from 12 to 24 months in autism and typical development: A longitudinal Rasch analysis. Developmental Psychology. 2011;47(6):1565-78. X-1, X-4. [pmid: 21910524].
306 Allison C, Auyeung B, Baron-Cohen S. Toward brief “Red Flags” for autism screening: The Short Autism Spectrum Quotient and the Short Quantitative Checklist for Autism in toddlers in 1,000 cases and 3,000 controls [corrected]. J Am Acad Child Adolesc Psychiatry. Feb. 2012;51(2):202-12 e7. X-4. [pmid: 22265366].
307 Arunyanart W, Fenick A, Ukritchon S, et al. Developmental and Autism Screening: A Survey Across Six States. Infants & Young Children: An Interdisciplinary Journal of Special Care Practices. 2012;25(3):175-87. X-3, X-4.
308 Aydin A. Turkish Adaptation of Test of Pretended Play. Educational Sciences: Theory and Practice. 2012;12(2):916-25. X-1, X-3, X-4, X-5.
309 Baghdadli A, Assouline B, Sonie S, et al. Developmental trajectories of adaptive behaviors from early childhood to adolescence in a cohort of 152 children with autism spectrum disorders. J Autism Dev Disord. Jul. 2012;42(7):1314-25. X-1, X-3 ,X-4. [pmid: 21928042].
310 Barton ML, Dumont-Mathieu T, Fein D. Screening Young Children for Autism Spectrum Disorders in Primary Practice. Journal of Autism and Developmental Disorders. 2012;42(6):1165-74. X-2, X-3, X-4. [pmid: 21842325].
311 Ben-Sasson A, Carter AS. The application of the First Year Inventory for ASD screening in Israel. Journal of Autism and Developmental Disorders. 2012;42(9):1906-16. X-4. [pmid: 22234796].
312 Bolton PF, Golding J, Emond A, et al. Autism spectrum disorder and autistic traits in the Avon Longitudinal Study of Parents and Children: precursors and early signs. J Am Acad Child Adolesc Psychiatry. Mar. 2012;51(3):249-60 e25. X-1, X-4. [pmid: 22365461].
313 Coo H, Ouellette-Kuntz H, Lam M, et al. Correlates of age at diagnosis of autism spectrum disorders in six Canadian regions. Chronic Dis Inj Can. Mar. 2012;32(2):90-100. X-1, X-3, X-4. [pmid: 22414306].
314 Dereu M, Raymaekers R, Warreyn P, et al. Can child care workers contribute to the early detection of autism spectrum disorders? A comparison between screening instruments with child care workers versus parents as informants. J Autism Dev Disord. May. 2012;42(5):781-96. X-1. [pmid: 21691866].
315 Dereu M, Roeyers H, Raymaekers R, et al. How useful are screening instruments for toddlers to predict outcome at age 4? General development, language skills, and symptom severity in children with a false positive screen for autism spectrum disorder. Eur Child Adolesc Psychiatry. Oct. 2012;21(10):541-51. X-1. [pmid: 22580987].
316 DeWeerdt S. Culture: Diverse diagnostics. Nature. Nov. 1. 2012;491(7422):S18-9. X-1, X-2, X-3, X-4, X-5. [pmid: 23136656].
317 Feldman MA, Ward RA, Savona D, et al. Development and initial validation of a parent report measure of the behavioral development of infants at risk for autism spectrum disorders. J Autism Dev Disord. Jan. 2012;42(1):13-22. [pmid: 21387111].
318 Fisher B, Dezort C, Nordli DR, et al. Routine developmental and autism screening in an epilepsy care setting. Epilepsy Behav. Aug. 2012;24(4):488-92. X-4. [pmid: 22789633].
319 Fombonne E, Marcin C, Bruno R, et al. Screening for autism in Mexico. Autism Res. Jun. 2012;5(3):180-9. X-3, X-4 ,X-5. [pmid: 22581514].
320 Frazier TW, Youngstrom EA, Speer L, et al. Validation of proposed DSM-5 criteria for autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. Jan. 2012;51(1):28-40 e3. X-3, X-4. [pmid: 22176937].
321 Grinker RR, Chambers N, Njongwe N, et al. “Communities” in community engagement: lessons learned from autism research in South Korea and South Africa. Autism Res. Jun. 2012;5(3):201-10. X-4, X-5. [pmid: 22566396].
322 Hattier MA, Matson JL. An examination of the relationship between communication and socialization deficits in children with autism and PDD-NOS. Research in Autism Spectrum Disorders. 2012;6(2):871-80. X-1, X-4.
323 Hattier MA, Matson JL, Kozlowski AM. Communication skills in children with cerebral palsy and autism spectrum disorder. Journal of Developmental and Physical Disabilities. 2012;24(1):85-93. X-1, X-3, X-4.
324 Hattier MA, Matson JL, May AC, et al. Repetitive/restricted behaviours and interests in children with cerebral palsy and autism spectrum disorder. Dev Neurorehabil. 2012;15(3):178-84. X-1, X-3, X-4. [pmid: 22582848].
325 Honigfeld L, Chandhok L, Spiegelman K. Engaging pediatricians in developmental screening: the effectiveness of academic detailing. J Autism Dev Disord. Jun. 2012;42(6):1175-82. X-4. [pmid: 21826585].
326 Hutman T, Chela MK, Gillespie-Lynch K, et al. Selective visual attention at twelve months: signs of autism in early social interactions. J Autism Dev Disord. Apr. 2012;42(4):487-98. X-4. [pmid: 21519953].
327 Hyman SL, Johnson JK. Autism and Pediatric Practice: Toward a Medical Home. Journal of Autism and Developmental Disorders. 2012;42(6):1156-64. X-2, X-3 ,X-4. [pmid: 22411200].
328 Ito H, Tani I, Yukihiro R, et al. Validation of an interview-based rating scale developed in Japan for pervasive developmental disorders. Research in Autism Spectrum Disorders. 2012;6(4):1265-72. X-1, X-3 ,X-4.
329 Kim SH, Lord C. New Autism Diagnostic Interview-Revised Algorithms for Toddlers and Young Preschoolers from 12 to 47 Months of Age. Journal of Autism and Developmental Disorders. 2012;42(1):82-93. X-1, X-4. [pmid: 21384244].
330 Kozlowski AM, Matson JL, Worley JA, et al. Defining characteristics for young children meeting cutoff on the Modified Checklist for Autism in Toddlers. Research in Autism Spectrum Disorders. 2012;6(1):472-9.
331 Lakic A. Screening, identification and evaluation of autism spectrum disorders in primary health care. Vojnosanit Pregl. May. 2012;69(5):437-43. X-2, X-3, X-4, X-5. [pmid: 22764548].
332 Lialiou P, Zikos D, Mantas J. Development and evaluation of an expert system for the diagnosis of child autism. Stud Health Technol Inform. 2012;180:1185-7. X-3, X-4. [pmid: 22874395].
333 Lord C, Luyster R, Guthrie W, et al. Patterns of developmental trajectories in toddlers with autism spectrum disorder. J Consult Clin Psychol. Jun. 2012;80(3):477-89. X-1, X-3, X-4. [pmid: 22506796].
334 Losh M, Esserman D, Anckarsater H, et al. Lower birth weight indicates higher risk of autistic traits in discordant twin pairs. Psychol Med. May. 2012;42(5):1091-102. X-1, X-3, X-4. [pmid: 22132806].
335 LoVullo SV, Matson JL. Development of a critical item algorithm for the Baby and Infant Screen for Children with aUtIsm Traits. Research in Autism Spectrum Disorders. 2012;6(1):378-84.
336 Magyar CI, Pandolfi V, Dill CA. An initial evaluation of the Social Communication Questionnaire for the assessment of autism spectrum disorders in children with Down syndrome. J Dev Behav Pediatr. Feb. 2012;33(2):134-45. X-3, X-4. [pmid: 22267105].
337 Mandell DS, Lawer LJ, Branch K, et al. Prevalence and Correlates of Autism in a State Psychiatric Hospital. Autism: The International Journal of Research and Practice. 2012;16(6):557-67. X-3,X-4, X-5. [pmid: 21846667].
338 Matson JL, Kozlowski AM, Hattier MA, et al. DSM-IV vs DSM-5 diagnostic criteria for toddlers with autism. Dev Neurorehabil. 2012;15(3):185-90. X-4. [pmid: 22582849].
339 Matson JL, Tureck K. Early Diagnosis of Autism: Current Status of the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Parts 1, 2, and 3). Research in Autism Spectrum Disorders. 2012;6(3):1135-41. X-1, X-2, X-3, X-4, X-5.
340 Medeiros K, Kozlowski AM, Beighley JS, et al. The effects of developmental quotient and diagnostic criteria on challenging behaviors in toddlers with developmental disabilities. Res Dev Disabil. Jul-Aug. 2012;33(4):1110-6. X-1, X-3 ,X-4. [pmid: 22502836].
341 Moore T, Johnson S, Hennessy E, et al. Screening for autism in extremely preterm infants: problems in interpretation. Dev Med Child Neurol. Jun. 2012;54(6):514-20. X-4. [pmid: 22458327].
342 Nakanishi M, Deardorff MA, Clark D, et al. Investigation of autistic features among individuals with mild to moderate Cornelia de Lange syndrome. Am J Med Genet A. Aug. 2012;158A(8):1841-7. X-3, X-4. [pmid: 22740374].
343 Nath S, Roy R, Mukherjee S. Perinatal complications associated with autism--a case control study in a neurodevelopment and early intervention clinic. J Indian Med Assoc. Aug. 2012;110(8):526-9. X-4, X-5. [pmid: 23741815].
344 Neal D, Matson JL, Belva BC. Discriminant analysis of the autism spectrum disorder observation for children. Developmental Neurorehabilitation. 2012;15(4):267-73. X-3, X-4. [pmid: 22632093].
345 Nygren G, Cederlund M, Sandberg E, et al. The prevalence of autism spectrum disorders in toddlers: a population study of 2-year-old Swedish children. J Autism Dev Disord. Jul. 2012;42(7):1491-7. X-4. [pmid: 22048962].
346 Peacock G, Lin SC. Enhancing early identification and coordination of intervention services for young children with autism spectrum disorders: report from the Act Early Regional Summit Project. Disabil Health J. Jan. 2012;5(1):55-9. X-1, X-2, X-3, X-4. [pmid: 22226299].
347 Quek LH, Sofronoff K, Sheffield J, et al. Co-occurring anger in young people with Asperger's syndrome. Journal of Clinical Psychology. 2012;68(10):1142-8. X-1, X-3, X-4. [pmid: 22806337].
348 Reel KH, Lecavalier L, Butter E, et al. Diagnostic utility of the Pervasive Developmental Disorder Behavior Inventory. Research in Autism Spectrum Disorders. 2012;6(1):458-65. X-3, X-4.
349 Ross JL, Roeltgen DP, Kushner H, et al. Behavioral and social phenotypes in boys with 47,XYY syndrome or 47,XXY Klinefelter syndrome. Pediatrics. Apr. 2012;129(4):769-78. X-3, X-4. [pmid: 22412026].
350 Roux AM, Herrera P, Wold CM, et al. Developmental and autism screening through 2-1-1: reaching underserved families. Am J Prev Med. Dec. 2012;43(6 Suppl 5):S457-63. X-1, X-3, X-4. [pmid: 23157765].
351 Sasson NJ, Elison JT. Eye tracking young children with autism. J Vis Exp. 2012;(61). X-1, X-2 , X-3, X-4. [pmid: 22491039].
352 Schieve LA, Boulet SL, Blumberg SJ, et al. Association between parental nativity and autism spectrum disorder among US-born non-Hispanic white and Hispanic children, 2007 National Survey of Children's Health. Disabil Health J. Jan. 2012;5(1):18-25. X-1, X-3, X-4. [pmid: 22226294].
353 Soares NS, Patel DR. Office screening and early identification of children with autism. Pediatr Clin North Am. Feb. 2012;59(1):89-102. x. xi. X-2, X-3, X-4, X-5. [pmid: 22284795].
354 Stephens BE, Bann CM, Watson VE, et al. Screening for autism spectrum disorders in extremely preterm infants. J Dev Behav Pediatr. Sep. 2012;33(7):535-41. X-4. [pmid: 22926660].
355 Tsai WC, Soong WT, Shyu YI. Toddler autism screening questionnaire: development and potential clinical validity. Autism. Jul. 2012;16(4):340-9. X-5. [pmid: 22399452].
356 Valicenti-McDermott M, Hottinger K, Seijo R, et al. Age at diagnosis of autism spectrum disorders. J Pediatr. Sep. 2012;161(3):554-6. X-1, X-4. [pmid: 22683037].
357 Veness C, Prior M, Bavin E, et al. Early indicators of autism spectrum disorders at 12 and 24 months of age: a prospective, longitudinal comparative study. Autism. Mar. 2012;16(2):163-77. X-4. [pmid: 21733958].
358 Wall DP, Dally R, Luyster R, et al. Use of artificial intelligence to shorten the behavioral diagnosis of autism. PLoS ONE. 2012;7(8). X-1, X-3, X-4.
359 Wang J, Lee L-C, Chen Y-S, et al. Assessing autistic traits in a Taiwan preschool population: Cross-cultural validation of the Social Responsiveness Scale (SRS). Journal of Autism and Developmental Disorders. 2012;42(11):2450-9. X-3, X-4, X-5. [pmid: 22407579].
360 Warren Z, Vehorn A, Dohrmann E, et al. Accuracy of phenotyping children with autism based on parent report: what specifically do we gain phenotyping “rapidly”?. Autism Res. Feb. 2012;5(1):31-8. X-3, X-4. [pmid: 21972233].
361 Wegiel J, Schanen NC, Cook EH, et al. Differences between the pattern of developmental abnormalities in autism associated with duplications 15q11.2-q13 and idiopathic autism. J Neuropathol Exp Neurol. May. 2012;71(5):382-97. X-1 ,X-3 ,X-4. [pmid: 22487857].
362 Wiggins LD, Robins DL, Adamson LB, et al. Support for a dimensional view of autism spectrum disorders in toddlers. J Autism Dev Disord. Feb. 2012;42(2):191-200. X-1, X-4. [pmid: 21448751].
363 Wright K, Poulin-Dubois D. Modified Checklist for Autism in Toddlers (M-CHAT) Screening at 18 Months of Age Predicts Concurrent Understanding of Desires, Word Learning and Expressive Vocabulary. Research in Autism Spectrum Disorders. 2012;6(1):184-92. X-4.
364 Yama B, Freeman T, Graves E, et al. Examination of the properties of the Modified Checklist for Autism in Toddlers (M-CHAT) in a population sample. J Autism Dev Disord. Jan. 2012;42(1):23-34. X-4. [pmid: 21373956].
365 Zwaigenbaum L, Bryson SE, Szatmari P, et al. Sex differences in children with autism spectrum disorder identified within a high-risk infant cohort. J Autism Dev Disord. Dec. 2012;42(12):2585-96. X-1, X-4. [pmid: 22453928].
366 Andersson GW, Gillberg C, Miniscalco C. Pre-school children with suspected autism spectrum disorders: Do girls and boys have the same profiles?. Research in Developmental Disabilities. 2013;34(1):413-22. X-1, X-4. [pmid: 23023300].
367 Barbaro J, Dissanayake C. Early markers of autism spectrum disorders in infants and toddlers prospectively identified in the Social Attention and Communication Study. Autism. Jan. 2013;17(1):64-86. X-4. [pmid: 22735682].
368 Barton ML, Robins DL, Jashar D, et al. Sensitivity and Specificity of Proposed DSM-5 Criteria for Autism Spectrum Disorder in Toddlers. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1184-95. X-1, X-3, X-4. [pmid: 23543293].
369 Begeer S, Mandell D, Wijnker-Holmes B, et al. Sex Differences in the Timing of Identification Among Children and Adults with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2013;43(5):1151-6. X-1, X-3, X-4. [pmid: 23001766].
370 Ben-Sasson A, Amit-Ben-Simhon H, Meyer S. Cross-parent reliability in rating ASD markers in infants. Dev Neurorehabil. 2013. Aug. 7. X-4. [pmid: 23924084].
371 Ben-Sasson A, Carter AS. The contribution of sensory–regulatory markers to the accuracy of ASD screening at 12 months. Research in Autism Spectrum Disorders. 2013;7(7):879-88. X-4.
372 Beuker KT, Schjølberg S, Lie KK, et al. The structure of autism spectrum disorder symptoms in the general population at 18 months. Journal of Autism and Developmental Disorders. 2013;43(1):45-56. X-1, X3, X-4. [pmid: 22562210].
373 Bond S. EPIDEMIOLOGIC STUDY LINKS INDUCTION AND AUGMENTATION OF LABOR TO DIAGNOSIS OF AUTISM. J Midwifery Womens Health. 2013. Dec. 10. X-1, X-2, X-3, X-4. [pmid: 24325141].
374 Charman T, Gotham K. Measurement Issues: Screening and diagnostic instruments for autism spectrum disorders - lessons from research and practice. Child Adolesc Ment Health. Feb. 1. 2013;18(1):52-63. X-2, X-3, X-4. [pmid: 23539140].
375 Chiang C-H, Wu C-C, Hou Y-M, et al. Development of T-STAT for Early Autism Screening. Journal of Autism and Developmental Disorders. 2013;43(5):1028-37. X-5. [pmid: 22976373].
376 Damiano CR, Nahmias A, Hogan-Brown AL, et al. What do repetitive and stereotyped movements mean for infant siblings of children with autism spectrum disorders?. Journal of Autism and Developmental Disorders. 2013;43(6):1326-35. X-1, X-4. [pmid: 23080207].
377 Daniels AM, Mandell DS. Children's Compliance with American Academy of Pediatrics' Well-Child Care Visit Guidelines and the Early Detection of Autism. Journal of Autism & Developmental Disorders. 2013;43(12):2844-54. X-1, X-3, X-4. [pmid: 23619952].
378 Davidson C, Greenwood N, Stansfield A, et al. Prevalence of Asperger syndrome among patients of an Early Intervention in Psychosis team. Early Interv Psychiatry. 2013. Mar. 8. X-3, X-4. [pmid: 23472601].
379 Elmose M, Trillingsgaard A, Jorgensen M, et al. Follow-up at mid-school age (9-13 years) of children assessed for autism spectrum disorder before the age of four. Nord J Psychiatry. 2013. Nov. 7. X-1, X-3, X-4. [pmid: 24199947].
380 Esposito G, Del Carmen Rostagno M, Venuti P, et al. Brief Report: Atypical Expression of Distress During the Separation Phase of the Strange Situation Procedure in Infant Siblings at High Risk for ASD. J Autism Dev Disord. 2013. Sep. 12. X-1, X-3, X-4. [pmid: 24026913].
381 Frazier TW, Youngstrom EA, Embacher R, et al. Demographic and clinical correlates of autism symptom domains and autism spectrum diagnosis. Autism. 2013. Oct. 8. X-1, X-3, X-4. [pmid: 24104512].
382 Freuler AC, Baranek GT, Tashjian C, et al. Parent reflections of experiences of participating in a randomized controlled trial of a behavioral intervention for infants at risk of autism spectrum disorders. Autism. 2013. Oct. 8. X-1, X-4. [pmid: 24104508].
383 Gan SM, Tung LC, Yeh CH, et al. The ICF-CY-based structural equation model of factors associated with participation in children with autism. Dev Neurorehabil. 2013. Oct. 2. X-1, X-3, X-4, X-5. [pmid: 24087923].
384 Gardner LM, Murphy L, Campbell JM, et al. Screening accuracy for risk of autism spectrum disorder using the Brief Infant-Toddler Social and Emotional Assessment (BITSEA). Research in Autism Spectrum Disorders. 2013;7(5):591-600. X-4.
385 Garg S, Green J, Leadbitter K, et al. Neurofibromatosis type 1 and autism spectrum disorder. Pediatrics. Dec. 2013;132(6):e1642-8. X-3, X-4. [pmid: 24190681].
386 Garg S, Lehtonen A, Huson SM, et al. Autism and other psychiatric comorbidity in neurofibromatosis type 1: evidence from a population-based study. Dev Med Child Neurol. Feb. 2013;55(2):139-45. X-3, X-4. [pmid: 23163236].
387 Gau SS-F, Liu L-T, Wu Y-Y, et al. Psychometric properties of the Chinese version of the Social Responsiveness Scale. Research in Autism Spectrum Disorders. 2013;7(2):349-60. X-3, X-4, X-5.
388 Guevara JP, Gerdes M, Localio R, et al. Effectiveness of developmental screening in an urban setting. Pediatrics. Jan. 2013;131(1):30-7. X-1, X-3, X-4. [pmid: 23248223].
389 Harrington JW, Bai R, Perkins AM. Screening children for autism in an urban clinic using an electronic M-CHAT. Clin Pediatr (Phila). Jan. 2013;52(1):35-41. X-4. [pmid: 23117237].
390 Harris B, Barton EE, Albert C. Evaluating Autism Diagnostic and Screening Tools for Cultural and Linguistic Responsiveness. J Autism Dev Disord. 2013. Nov. 2. X-1, X-3, X-4. [pmid: 24186120].
391 Hedvall A, Westerlund J, Fernell E, et al. Autism and developmental profiles in preschoolers: stability and change over time. Acta Paediatr. 2013. Oct. 8. X-1, X-3, X-4. [pmid: 24237479].
392 Horovitz M, Matson JL. The baby and infant screen for children with autism traits-part 2: The development of age-based cutoffs. Dev Neurorehabil. 2013. Jul. 19. X-1, X-4. [pmid: 23869771].
393 Hu VW, Lai Y. Developing a Predictive Gene Classifier for Autism Spectrum Disorders Based upon Differential Gene Expression Profiles of Phenotypic Subgroups. N Am J Med Sci (Boston). 2013;6(3). X-1, X-3, X-4. [pmid: 24363828].
394 Hus V, Bishop S, Gotham K, et al. Factors influencing scores on the Social Responsiveness Scale. Journal of Child Psychology and Psychiatry. 2013;54(2):216-24. X-3, X-4. [pmid: 22823182].
395 Jain R, Juneja M, Sairam S. Children with developmental disabilities in India: Age of initial concern and referral for rehabilitation services, and reasons for delay in referral. Journal of Child Neurology. 2013;28(4):455-60. X-1, X-3, X-4, X-5. [pmid: 22752480].
396 Jaspers M, de Winter AF, Buitelaar JK, et al. Early childhood assessments of community pediatric professionals predict autism spectrum and attention deficit hyperactivity problems. J Abnorm Child Psychol. Jan. 2013;41(1):71-80. X-1, X-3, X-4. [pmid: 22688680].
397 Jutley-Neilson J, Harris G, Kirk J. The identification and measurement of autistic features in children with septo-optic dysplasia, optic nerve hypoplasia and isolated hypopituitarism. Res Dev Disabil. Dec. 2013;34(12):4310-8. X-3, X-4. [pmid: 24210356].
398 Kakooza-Mwesige A, Ssebyala K, Karamagi C, et al. Adaptation of the ‘ten questions’ to screen for autism and other neuro-developmental disorders in Uganda. Autism. 2013. Nov. 8. X-4, X-5. [pmid: 23536263].
399 Kantzer AK, Fernell E, Gillberg C, et al. Autism in community pre-schoolers: developmental profiles. Res Dev Disabil. Sep. 2013;34(9):2900-8. X-1, X-4. [pmid: 23816626].
400 Kirby A, Sugden D, Purcell C. Diagnosing developmental coordination disorders. Arch Dis Child. 2013. Nov. 19. X-1, X-2, X-3, X-4. [pmid: 24255567].
401 Koh HC, Lim SH, Chan GJ, et al. The Clinical Utility of the Modified Checklist for Autism in Toddlers with High Risk 18-48 Month Old Children in Singapore. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812662].
402 Kumar VS, Webster M. A test in development. Clin Chem. Nov. 2013;59(11):1680-2. X-1, X-2, X-3, X-4. [pmid: 24167190].
403 Liu X, Zhou X, Lackaff J. Incremental Validity in the Clinical Assessment of Early Childhood Development. Journal of Psychoeducational Assessment. Oct. 2013. 2013;31(5):506-15. X-1, X-3, X-4.
404 Lukose R, Brown K, Barber CM, et al. Quantification of the stapedial reflex reveals delayed responses in autism. Autism Res. Oct. 2013;6(5):344-53. X-1, X-3, X-4. [pmid: 23825093].
405 Matson JL, Kozlowski AM, Fitzgerald ME, et al. True versus false positives and negatives on the Modified Checklist For Autism in Toddlers. Research in Autism Spectrum Disorders. 2013;7(1):17-22. X-4.
406 Mayes SD, Black A, Tierney CD. DSM-5 under-identifies PDDNOS: Diagnostic agreement between the DSM-5, DSM-IV, and Checklist for Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2013;7(2):298-306. X-1, X-3, X-4.
407 Myers CL, Gross AD, McReynolds BM. Broadband Behavior Rating Scales as Screeners for Autism?. J Autism Dev Disord. 2013. Nov. 28. [pmid: 24287879].
408 Nakai Y, Takashima R, Takiguchi T, et al. Speech intonation in children with autism spectrum disorder. Brain Dev. 2013. Aug. 20. X-1, X-3, X-4. [pmid: 23973369].
409 Narzisi A, Calderoni S, Maestro S, et al. Child Behavior Check List 1(1/2)-5 as a tool to identify toddlers with autism spectrum disorders: a case-control study. Res Dev Disabil. Apr. 2013;34(4):1179-89. X-4. [pmid: 23376628].
410 Neal D, Matson JL, Belva BC. An examination of the reliability of a new observation measure for Autism spectrum disorders: The autism spectrum disorder observation for children. Research in Autism Spectrum Disorders. 2013;7(1):29-34. X-1, X-3, X-4.
411 Nickel LR, Thatcher AR, Keller F, et al. Posture Development in Infants at Heightened vs. Low Risk for Autism Spectrum Disorders. Infancy. Sep. 2013;18(5):639-61. X-1, X-3, X-4. [pmid: 24027437].
412 Nordenbaek C, Jorgensen M, Kyvik KO, et al. A Danish population-based twin study on autism spectrum disorders. Eur Child Adolesc Psychiatry. 2013. May. 10. X-3, X-4. [pmid: 23661220].
413 Oner P, Oner O, Munir K. Three-item Direct Observation Screen (TIDOS) for autism spectrum disorder. Autism. 2013. Oct. 14. X-4, X-5. [pmid: 24126869].
414 Pringsheim T, Hammer T. Social behavior and comorbidity in children with tics. Pediatr Neurol. Dec. 2013;49(6):406-10. X-1, X-3, X-4. [pmid: 24095577].
415 Robinson EB, Howrigan D, Yang J, et al. Response to ‘Predicting the diagnosis of autism spectrum disorder using gene pathway analysis’. Mol Psychiatry. 2013. Oct. 22. X-1, X-3, X-4. [pmid: 24145379].
416 Samadi SA, McConkey R. The utility of the Gilliam autism rating scale for identifying Iranian children with autism. Disabil Rehabil. 2013. Jun. 5. X-3, X-4, X-5. [pmid: 23738615].
417 Sasson NJ, Lam KSL, Childress D, et al. The Broad Autism Phenotype Questionnaire: Prevalence and diagnostic classification. Autism Research. 2013;6(2):134-43. X-1, X-3, X-4. [pmid: 23427091].
418 Scarpa A, Reyes NM, Patriquin MA, et al. The Modified Checklist for Autism in Toddlers: Reliability in a diverse rural American sample. Journal of Autism and Developmental Disorders. 2013;43(10):2269-79. X-4. [pmid: 23386118].
419 Shibata A, Hitomi Y, Kambayashi Y, et al. Epidemiological study on the involvements of environmental factors and allergy in child mental health using the Autism Screening Questionnaire. Research in Autism Spectrum Disorders. 2013;7(1):132-40. X-3, X-4.
420 Shrestha M, Shrestha R. Symptom Recognition to Diagnosis of Autism in Nepal. J Autism Dev Disord. 2013. Nov. 29. X-1, X-3, X-4, X-5. [pmid: 24293038].
421 Sipes M, Matson JL. Factor Structure for Autism Spectrum Disorders with Toddlers Using DSM-IV and DSM-5 Criteria. J Autism Dev Disord. 2013. Aug. 25. X-1, X-4. [pmid: 23979069].
422 Smith NJ, Sheldrick RC, Perrin EC. An abbreviated screening instrument for autism spectrum disorders. Infant Mental Health Journal. 2013;34(2):149-55. X-4.
423 So P, Greaves-Lord K, van der Ende J, et al. Using the Child Behavior Checklist and the Teacher's Report Form for identification of children with autism spectrum disorders. Autism. 2013;17(5):595-607. X-3, X-4. [pmid: 22914776].
424 Sun X, Allison C, Auyeung B, et al. The Mandarin Chinese version of the Childhood Autism Spectrum Test (CAST): Test–retest reliability. Research in Developmental Disabilities. 2013;34(10):3267-75. X-3, X-4, X-5. [pmid: 23892873].
425 Sun X, Allison C, Auyeung B, et al. The Mandarin Chinese version of the childhood autism spectrum test (CAST): test-retest reliability. Res Dev Disabil. Oct. 2013;34(10):3267-75. X-3, X-4, X-5. [pmid: 23892873].
426 Sun X, Allison C, Matthews FE, et al. Prevalence of autism in mainland China, Hong Kong and Taiwan: a systematic review and meta-analysis. Mol Autism. 2013;4(1):7. X-1, X-2, X-3, X-4, X-5. [pmid: 23570419].
427 Tang LL, Kang L, Liu C, et al. An additive selection of markers to improve diagnostic accuracy based on a discriminatory measure. Acad Radiol. Jul. 2013;20(7):854-62. X-1, X-3, X-4. [pmid: 23611438].
428 Taylor LJ, Maybery MT, Whitehouse AJ. Moving beyond behaviour-only assessment: Incorporating biomarkers to improve the early detection and diagnosis of autism spectrum disorders. Int J Speech Lang Pathol. 2013. Nov. 18. X-1, X-2, X-3, X-4. [pmid: 24236911].
429 Tomlin A, Koch SM, Raches C, et al. Autism Screening Practices Among Early Intervention Providers in Indiana. Infants & Young Children An Interdisciplinary Journal of Special Care Practices. 2013. Jan-Mar. 2013;26(1):74-88. X-1, X-3, X-4.
430 Travers JC, Tincani M, Krezmien MP. A Multiyear National Profile of Racial Disparity in Autism Identification. Journal of Special Education. 2013;47(1):41-9. X-1, X-3, X-4.
431 Tuominen-Eriksson A-M, Svensson Y, Gunnarsson RK. Children with Disabilities Are Often Misdiagnosed Initially and Children with Neuropsychiatric Disorders Are Referred to Adequate Resources 30 Months Later than Children with Other Disabilities. Journal of Autism and Developmental Disorders. 2013;43(3):579-84. X-1, X-3, X-4. [pmid: 22798050].
432 Volkmar FR, Reichow B. Infants and toddlers with autism: The promise and the challenges. Int J Speech Lang Pathol. 2013. Dec. 18. X-1, X-2, X-3, X-4. [pmid: 24345000].
433 Wiggins LD, Robins DL, Yeargin-Allsopp M. Short report: Improving record-review surveillance of young children with an autism spectrum disorder. Autism. Sep. 2013;17(5):623-9. X-1, X-3, X-4. [pmid: 22987886].
434 Williams K, Perkins D, Wheeler D, et al. Can questions about social interaction correctly identify preschool aged children with autism?. J Paediatr Child Health. Feb. 2013;49(2):E167-74. [pmid: 23350819].
435 Wong HS, Huertas-Ceballos A, Cowan FM, et al. Evaluation of early childhood social-communication difficulties in children born preterm using the Quantitative Checklist for Autism in Toddlers. J Pediatr. Jan. 2014;164(1):26-33.e1. X-4. [pmid: 23972644].