# Quality/Risk of Bias of Diagnostic Accuracy Studies

Appendix D Table 1 Quality/Internal Validity Ratings for Diagnostic Accuracy Studies

Study, Year | Screening test clearly described | Representative population | Selection criteria clearly described | Credible reference standard | Reference standard time period appropriate | Reference test applied to all or subset of participants | Same reference standard applied to all participants | Reference standard independent of screening test | Replication of screening test possible | Replication of reference standard possible | Screening test and reference standard interpreted independently | Same data used to interpret test available if test used in clinical practice | Withdrawals from study explained | Methods/data for calculating accuracy clearly reported | Methods/data for calculating accuracy valid | Internal Validity Rating
Chlebowski 2013^1-5^ | yes | yes | yes | yes | yes | all | yes | yes | yes | yes | no | yes | yes | yes | yes | Good
Nygren 2012^6^ | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | unclear | yes | yes | yes | yes | Fair
Barbaro 2011^7,8^ | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | no | yes | yes | yes | yes | Fair
Canal-Bedia 2011a9 | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | yes | yes | no | yes | yes | Fair
Canal-Bedia 2011b9 | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | yes | yes | no | yes | yes | Fair
Inada 2011^10^ | yes | yes | yes | yes | yes | all | yes | yes | yes | yes | yes | yes | yes | yes | yes | Fair-Poor
Miller 2011^11^ | yes | yes | yes | yes | yes | subset | no | yes | yes | yes | yes | yes | yes | yes | yes | Fair
Pierce 2011^12^ | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | no | yes | yes | yes | yes | Good
Honda 2009^13^ | yes | unclear | yes | yes | yes | subset | yes | yes | yes | yes | yes | yes | yes | yes | yes | Fair
Wetherby 2008^14^ | yes | yes | yes | yes | yes | all | yes | yes | yes | yes | yes | yes | yes | yes | yes | Good
Oosterling 2007^15^ | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | yes | yes | no | yes | yes | Fair
VandenHeuvel 2007^16^ | yes | yes | yes | unclear | yes | subset | no | no | no | no | unclear | unclear | yes | no | yes | Poor
Oosterling 2006^17^ | yes | yes | yes | yes | yes | subset | yes | yes | yes | yes | yes | yes | no | yes | yes | Fair
Baird 2000^18^ | yes | yes | yes | yes | yes | all | yes | yes | yes | yes | yes | yes | yes | yes | yes | Good

Appendix D Quality Assessment Form for Diagnostic Accuracy Studies

Screening for ASD in Young Children Quality scoring—Diagnostic accuracy studies

### References

1 Kleinman JM, Robins DL, Ventola PE, et al. The modified checklist for autism in toddlers: a follow-up study investigating the early detection of autism spectrum disorders. J Autism Dev Disord. May. 2008;38(5):827-39. [pmid: 17882539].
2 Chlebowski C, Robins DL, Barton ML, et al. Large-scale use of the modified checklist for autism in low-risk toddlers. Pediatrics. Apr. 2013;131(4):e1121-7. [pmid: 23530174].
3 Robins DL. Screening for autism spectrum disorders in primary care settings. Autism. Sep. 2008;12(5):537-56. [pmid: 18805946].
4 Pandey J, Verbalis A, Robins DL, et al. Screening for autism in older and younger toddlers with the Modified Checklist for Autism in Toddlers. Autism. Sep. 2008;12(5):513-35. [pmid: 18805945].
5 Robins DL, Fein D, Barton ML, et al. The Modified Checklist for Autism in Toddlers: an initial study investigating the early detection of autism and pervasive developmental disorders. J Autism Dev Disord. Apr. 2001;31(2):131-44. [pmid: 11450812].
6 Nygren G, Sandberg E, Gillstedt F, et al. A new screening programme for autism in a general population of Swedish toddlers. Res Dev Disabil. Jul-Aug. 2012;33(4):1200-10. [pmid: 22502846].
7 Heyer NJ, Echeverria D, Woods JS. Disordered porphyrin metabolism: a potential biological marker for autism risk assessment. Autism Res. Apr. 2012;5(2):84-92. [pmid: 22298513].
8 Barbaro J, Dissanayake C. Prospective identification of autism spectrum disorders in infancy and toddlerhood using developmental surveillance: the social attention and communication study. J Dev Behav Pediatr. Jun. 2010;31(5):376-85. [pmid: 20495475].
9 Canal-Bedia R, Garcia-Primo P, Martin-Cilleros MV, et al. Modified checklist for autism in toddlers: cross-cultural adaptation and validation in Spain. J Autism Dev Disord. Oct. 2011;41(10):1342-51. [pmid: 21161677].
10 Inada N, Koyama T, Inokuchi E, et al. Reliability and validity of the Japanese version of the Modified Checklist for autism in toddlers (M-CHAT). Research in Autism Spectrum Disorders. 2011;5(1):330-6. 2010-22960-034.
11 Miller JS, Gabrielsen T, Villalobos M, et al. The each child study: systematic screening for autism spectrum disorders in a pediatric setting. Pediatrics. May. 2011;127(5):866-71. [pmid: 21482605].
12 Pierce K, Carter C, Weinfeld M, et al. Detecting, studying, and treating autism early: the one-year well-baby check-up approach. J Pediatr. Sep. 2011;159(3):458-65 e1-6. [pmid: 21524759].
13 Honda H, Shimizu Y, Nitto Y, et al. Extraction and Refinement Strategy for detection of autism in 18-month-olds: a guarantee of higher sensitivity and specificity in the process of mass screening. J Child Psychol Psychiatry. Aug. 2009;50(8):972-81. [pmid: 19298465].
14 Wetherby AM, Brosnan-Maddox S, Peace V, et al. Validation of the infant-toddler checklist as a broadband screener for autism spectrum disorders from 9 to 24 months of age. Autism. 2008;12(5):487-511. 2008-13622-005. [pmid: 18805944].
15 Dietz C, Swinkels SH, van Daalen E, et al. Parental compliance after screening social development in toddlers. Arch Pediatr Adolesc Med. Apr. 2007;161(4):363-8. [pmid: 17404133].
16 VanDenHeuvel A, Fitzgerald M, Greiner B, et al. Screening for autistic spectrum disorder at the 18-month developmental assessment: a population-based study. Ir Med J. Sep. 2007;100(8):565-7. [pmid: 17955715].
17 Dietz C, Swinkels S, van Daalen E, et al. Screening for autistic spectrum disorder in children aged 14-15 months. II: population screening with the Early Screening of Autistic Traits Questionnaire (ESAT). Design and general findings. J Autism Dev Disord. Aug. 2006;36(6):713-22. [pmid: 16633887].
18 Baird G, Charman T, Baron-Cohen S, et al. A screening instrument for autism at 18 months of age: a 6-year follow-up study. J Am Acad Child Adolesc Psychiatry. Jun. 2000;39(6):694-702. [pmid: 10846303].

Appendix D Table 2 Quality for Intervention Studies

First Author Year | Group Design | Random Assignment | Appropriate Comparison Group | Correct Randomization | Systematic Diagnostic Approach | Clear Sample Characterization | Clear Inclusion/ Exclusion Criteria | Attrition Reported | Drop out Characteristics Evaluated | Intervention Fully Described | Treatment Fidelity Monitored | Concomitant Interventions Held Steady/ Reported | Outcome Measures Reliable and Valid | Primary Outcomes Specified a priori | Outcome Data Collected From Appropriate Sources | Outcomes Coded Blindly | Appropriate Statistical Analysis | Rating
Kasari 2014^1^ | + | + | + | - | + | + | + | + | + | + | + | + | + | + | + | + | - | F
Boyd 2013^2^ | + | - | + | NA | + | + | + | + | + | + | + | - | + | + | + | - | - | F
Casenhiser 2013^3^ | + | + | + | + | + | + | + | + | + | + | + | - | + | + | + | + | + | F
Goods 2013^4^ | + | + | + | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | G
Peters-Scheffer 2013^5^ | + | - | + | NA | + | + | + | + | - | + | + | - | + | - | + | - | + | G
Schertz 2013^6^ | + | + | + | - | + | + | + | + | + | + | + | - | + | + | + | + | + | F
Schreibman 2013^7^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | - | + | G
Siller 2013^8^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | F
Warreyn 2013^9^ | + | + | + | - | + | + | + | + | - | + | - | - | + | + | + | - | - | F
Wong 2013^10^ | + | + | + | + | + | + | + | + | + | + | + | - | + | + | + | - | + | F
Dawson 2012^11,12^ | + | + | + | + | + | + | + | + | - | + | + | + | + | + | - | - | - | G
Eikeseth 2012^13^ | + | - | + | NA | - | + | - | + | - | + | - | + | + | + | + | - | - | F
Eldevik 2012^14^ | + | - | + | NA | - | + | + | + | + | + | - | - | + | - | + | - | + | F
Flanagan 2012^15,16^ | + | - | + | NA | + | + | + | NA | - | + | - | - | + | + | + | - | + | F
Kaale 2012^17^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | F
Landa 2012^18,19^ | + | + | + | - | + | + | + | + | + | + | + | + | + | + | + | + | + | G
Lawton 2012^20^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | - | F
Reed 2012^21^ | + | - | + | NA | + | + | + | - | - | + | - | - | + | + | + | + | - | F
Rogers 2012^22,23^ | + | + | + | + | + | + | + | - | - | + | + | + | + | + | + | - | - | F
Strauss 2012^24,25^ | + | - | + | NA | + | + | + | + | + | + | + | - | + | + | + | - | + | G
Venker 2012^26^ | + | + | + | - | + | + | - | - | - | + | + | - | + | + | + | - | + | F
Aldred 2011^27,28^ | + | + | + | + | + | + | + | + | + | + | - | - | + | + | + | + | + | G
Carter 2011^29^ | + | + | + | + | + | + | + | + | - | + | + | - | + | + | + | + | + | F
Itzchak 2011^30,31^ | + | - | + | NA | + | + | + | - | - | + | - | - | + | + | + | - | - | F
Landa 2011^18,19^ | + | + | + | - | + | + | + | + | + | + | + | + | + | + | + | + | + | G
Roberts 2011^32^ | + | + | + | + | + | + | + | + | - | + | + | + | + | + | + | + | + | G
Strain 2011^33^ | + | + | + | - | - | + | + | + | + | + | + | - | + | + | + | - | + | F
Green 2010^34^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | F
Ingersoll 2010^35,36^ | + | + | + | - | + | + | + | + | + | + | + | - | + | + | + | + | + | G
Itzchak 2010^30,31^ | + | - | + | NA | + | + | + | - | - | + | - | - | + | + | + | - | - | F
Kasari 2010^37^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | G
Keen 2010^38^ | + | - | + | NA | + | + | - | + | + | + | + | - | + | + | + | - | + | G
Oosterling 2010^39^ | + | + | + | - | + | + | + | + | - | + | + | - | + | + | + | - | - | F
Peters-Sheffer 2010^40^ | + | - | + | NA | + | + | + | + | + | + | - | + | + | + | + | - | + | F
Reed 2010^21^ | + | - | + | NA | + | + | + | - | - | + | - | - | + | + | + | + | - | F
Siller 2010^8^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | F
Hayward 2009^41,42^ | + | - | + | NA | - | + | + | + | + | + | + | - | + | + | + | + | + | F
Reed 2007^43^ | + | - | + | NA | - | + | + | + | - | + | - | - | + | + | + | - | + | F
Zachor 2007^44^ | + | - | + | NA | + | + | - | + | N | + | - | - | + | + | + | - | + | F
Cohen 2006^45^ | + | - | + | NA | + | + | + | + | + | + | - | - | + | + | + | - | + | F
Kasari 2006^46-49^ | + | + | + | - | + | + | + | + | - | + | + | - | + | + | + | + | + | F
Howard 2005^50^ | + | - | + | N | + | + | + | + | - | + | - | - | + | + | + | - | + | F
Sallows 2005^51^ | + | + | + | + | + | + | + | + | - | + | + | + | + | + | + | + | - | G
Aldred 2004^27,28^ | + | + | + | + | + | + | + | + | + | + | - | - | + | + | + | + | + | G
Drew 2002^52^ | + | + | + | + | - | + | + | + | + | + | - | + | + | + | + | - | + | F
Eikeseth 2002^53,54^ | + | - | + | NA | - | + | + | + | - | + | - | - | + | + | + | + | + | F
Smith 2000^21^ | + | + | + | - | - | + | + | + | + | + | + | - | + | + | + | + | + | F

F=fair; G=good; NA=not applicable.

Appendix D Quality/Risk of Bias Assessment Approach

### Study Design

1. Did the study employ a group design?
  - Group designs may include randomized controlled trials, prospective or retrospective cohorts, case-control studies
  - + = yes
  - - = no
2. Were the groups randomly assigned?
  - + = yes
  - - = no
3. Was there an appropriate comparison group?
  - The comparison group should accurately represent the characteristics of the intervention group in the absence of the intervention. Specifically, factors that are likely to be associated with the intervention selected and with outcomes observed should be evenly distributed between groups, if possible. These factors may include, for example, age, IQ, severity, etc.
  - + = yes
  - - = no or not reported (NR)
4. If an RCT, was randomization done correctly?
  - + = yes
  - - = no
  - NR
  - NA for all non-RCTs
  - Considerations:
    Was the approach to randomization described? Were random techniques like computer-generated, sequentially numbered opaque envelope used?
    Were technically non-random techniques, like alternate days of the week used?
    Any studies with randomization techniques not reported (NR) will also be reviewed by the team.

### Participant Ascertainment/Inclusion

1. Was a valid diagnostic approach for ASD used within the study, or were referred participants diagnosed using a valid approach?
  A. clinical DSM-IV-based diagnosis + ADI-R and/or ADOS
  B. [clinical DSM-IV-based diagnosis + other] OR [ADOS + other, such as SRS, CARS, SCQ, CAST, ASSQ, OR STAT, MCHAT for under 30 months]
  C. Only clinical DSM-IV-based diagnosis OR Only ADOS
  D. Neither clinical DSM-IV-based diagnosis NOR ADOS
2. Was the sample clearly characterized (e.g., information provided to characterize participants in terms of impairments associated with their ASD, such as cognitive or developmental level)?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Are baseline measures of IQ, mental age, language facility, etc. reported?
    How reproducible is the study in terms of the sample participants? Do the authors provide enough information that you could recreate the study population in a new study?
3. Were inclusion and exclusion criteria clearly stated?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Did the authors report this information?
4. Do the authors report attrition?
  - + = yes
  - - = no
  - Considerations:
    Do they report loss to follow-up and/or drop-out?
    If there is no attrition (i.e., baseline and follow up Ns are the same), score as YES
5. Were characteristics of drop-out group evaluated for differences with the participant group as a whole?
  - + = yes
  - - = no or not reported (NR)
  - NA or attrition was minimal
  - Considerations:
    Were reasons for dropping out evaluated?
    Does the paper describe a comparison between drop-outs and the whole group?
    Score as NA if attrition was minimal.

### Intervention

1. Was the intervention fully described?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Is there sufficient detail to allow replication of the intervention?
    Does the study describe the dosage, formulation, timing, duration, intensity, etc. of the intervention?
    Do the authors refer to a treatment manual (score as YES if so, even is manual is unpublished)?
2. For behavioral studies, was treatment fidelity monitored in a systematic way?
  - + = yes
  - - = no or not reported (NR)
  - NA
  - Considerations:
    Was a method in place to assess whether people providing he intervention were adherent to a manual/process? We're not assessing the quality of the fidelity, just whether it was performed.
3. Did the authors measure and report adherence to the intended treatment process?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Does the study report number of hours of treatment or treatment sessions or time period receiving therapy (planned vs. actually received)? Do they provide pill count data or parental medication diary, etc. for pharmacologic interventions?
4. Did the authors report differences in or hold steady all concomitant interventions?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Was an attempt made to assess/determine if other interventions were ongoing?

### Outcome Measurement

1. Did outcome measures demonstrate adequate reliability and validity (including interobserver reliability for behavior observation coding)?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    If the study used an established measure, has validity been established previously and do the authors provide a reference?
    If the study used a new measure, was validity established?
    For interobserver coding, was reliability and /or validity tested?
2. Were the primary & secondary outcomes clearly specified a priori?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Was there a “called shot?”
3. Were outcome data collected from sources appropriate to the target outcome (e.g. parent report, teacher report, direct behavior observation)?
  - + = yes
  - - = no or not reported (NR)
  - Considerations:
    Ex: Parent report for home-focused outcomes, teacher report for academic/school-focused, etc.
4. Were outcomes coded by individuals blinded to the intervention status of the participants?
  - + = yes
  - - = no or not reported (NR)

### Analysis

1 Was an appropriate statistical analysis used?
  - + = yes
  - - = no
1a For RCT's, was there an intent-to treat analysis?
  - + = yes
  - - = no
  - NA
  - Considerations:
    Does the study report ITT analyses or last observation carried forward or note that all subjects were included in the final analyses?
    If ≤2 participants were lost to follow-up, consider the analysis as ITT.
1b For negative studies, was a power calculation provided?
  - + = yes
  - - = no
  - NA
1c Did the study correct for multiple testing?
  - + = yes
  - - = no
  - NA
1d For observational studies, were potential confounders and effect measure modifiers captured?
  - + = yes
  - - = no
    - NA
  - Considerations:
    Were the groups well categorized at baseline? Were baseline differences assessed?
1e For observational studies, were potential confounders and effect measure modifiers handled appropriately?
  - + = appropriate analysis
  - - = inappropriate analysis
  - NA
  - Considerations:
    Confounders are variables that are associated both with the intervention and the outcome and that change the relationship of the intervention to the outcome. These are variables that we would control for in analysis.
    Effect measure modifiers are variables that we think of as stratifying, in that the relationship between the intervention and outcome is fundamentally different in different strata of the effect modifier. Observational research should include an assessment of potential confounders and modifiers, and if they are observed, analysis should control for or stratify on them.
    Was the candidate variable selection discussed/noted?
    Was the model-building approach described?
    Were any variables unrelated to the studied variables that could have altered the outcome handled appropriately?
    Were any variables not under study that affected the causal factors handled appropriately?

## References

1 Kasari C, Lawton K, Shih W, et al. Caregiver-mediated intervention for low-resourced preschoolers with autism: an RCT. Pediatrics. Jul. 2014;134(1):e72-9. [pmid: 24958585].
2 Boyd BA, Hume K, McBee MT, et al. Comparative Efficacy of LEAP, TEACCH and Non-Model-Specific Special Education Programs for Preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812661].
3 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. Mar. 2013;17(2):220-41. [pmid: 21949005].
4 Goods KS, Ishijima E, Chang Y-C, et al. Preschool Based JASPER Intervention in Minimally Verbal Children with Autism: Pilot RCT. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1050-6. EJ1000575. [pmid: 22965298].
5 Peters-Scheffer N, Didden R, Mulders M, et al. Effectiveness of low intensity behavioral treatment for children with autism spectrum disorder and intellectual disability. Research in Autism Spectrum Disorders. 2013;7(9):1012-25. 2013-27709-003.
6 Schertz HH, Odom SL, Baggett KM, et al. Effects of Joint Attention Mediated Learning for Toddlers with Autism Spectrum Disorders: An Initial Randomized Controlled Study. Early Childhood Research Quarterly 2013. 2013;28(2):249-58. EJ1008279.
7 Schreibman L, Stahmer AC. A Randomized Trial Comparison of the Effects of Verbal and Pictorial Naturalistic Communication Strategies on Spoken Language for Young Children with Autism. J Autism Dev Disord. 2013. Nov. 23. [pmid: 24272416].
8 Siller M, Hutman T, Sigman M. A Parent-Mediated Intervention to Increase Responsive Parental Behaviors and Child Communication in Children with ASD: A Randomized Clinical Trial. Journal of Autism and Developmental Disorders. 2013;43(3):540-55. EJ999150. [pmid: 22825926].
9 Warreyn P, Roeyers H. See what I see, do as I do: Promoting joint attention and imitation in preschoolers with autism spectrum disorder. Autism. 2013. Oct. 8. [pmid: 24104513].
10 Wong CS. A play and joint attention intervention for teachers of young children with Autism: A randomized controlled pilot study. Autism. May. 2013. 2013;17(3):340-57. 18038415. [pmid: 23610236].
11 Dawson G, Rogers S, Munson J, et al. Randomized, controlled trial of an intervention for toddlers with autism: the Early Start Denver Model. Pediatrics. Jan. 2010;125(1):e17-23. [pmid: 19948568].
12 Dawson G, Jones EJ, Merkle K, et al. Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. Nov. 2012;51(11):1150-9. [pmid: 23101741].
13 Eikeseth S, Klintwall L, Jahr E, et al. Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention in Mainstream Preschool and Kindergarten Settings. Research in Autism Spectrum Disorders. 2012;6(2):829-35. EJ966831.
14 Eldevik S, Hastings RP, Jahr E, et al. Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. Feb. 2012;42(2):210-20. [pmid: 21472360].
15 Flanagan HE, Perry A, Freeman NL. Effectiveness of large-scale community-based intensive Behavioral Intervention: A waitlist comparison study exploring outcomes and predictors. Research in Autism Spectrum Disorders. 2012;6(2):673-82. 2012-03990-011.
16 Perry A, Blacklock K, Dunn Geier J. The relative importance of age and IQ as predictors of outcomes in Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2013;7(9):1142-50. 2013-27709-017.
17 Kaale A, Smith L, Sponheim E. A randomized controlled trial of preschool-based joint attention intervention for children with autism. J Child Psychol Psychiatry. Jan. 2012;53(1):97-105. [pmid: 21883204].
18 Landa RJ, Holman KC, O'Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. [pmid: 21126245].
19 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. Nov. Suppl 2. 2012;130:S186-90. [pmid: 23118250].
20 Lawton K, Kasari C. Teacher-implemented joint attention intervention: pilot randomized controlled study for preschoolers with autism. J Consult Clin Psychol. Aug. 2012;80(4):687-93. [pmid: 22582764].
21 Reed P, Osborne L. Impact of Severity of Autism and Intervention Time-Input on Child Outcomes: Comparison across Several Early Interventions. British Journal of Special Education. 2012;39(3):130-6. EJ979673.
22 Rogers SJ, Estes A, Lord C, et al. Effects of a brief Early Start Denver Model (ESDM)–based parent intervention on toddlers at risk for autism spectrum disorders: A randomized controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(10):1052-65. [pmid: 23021480].
23 Estes A, Vismara L, Mercado C, et al. The Impact of Parent-Delivered Intervention on Parents of Very Young Children with Autism. J Autism Dev Disord. 2013. Jul. 10. [pmid: 23838727].
24 Strauss K, Vicari S, Valeri G, et al. Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. Mar-Apr. 2012;33(2):688-703. [pmid: 22188793].
25 Fava L, Strauss K, Valeri G, et al. The Effectiveness of a Cross-Setting Complementary Staff- and Parent-Mediated Early Intensive Behavioral Intervention for Young Children with ASD. Research in Autism Spectrum Disorders. 2011;5(4):1479-92. EJ927555.
26 Venker CE, McDuffie A, Weismer SE, et al. Increasing Verbal Responsiveness in Parents of Children with Autism: A Pilot Study. Autism: The International Journal of Research and Practice. 2012;16(6):568-85. EJ984594. [pmid: 21846665].
27 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. [pmid: 15482502].
28 Aldred C, Green J, Emsley R, et al. Mediation of treatment effect in a communication intervention for pre-school children with autism. Journal of Autism and Developmental Disorders. 2012;42(3):447-54. 2012-04398-013. [pmid: 21512834].
29 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of Hanen's ‘More Than Words’ in toddlers with early autism symptoms. Journal of Child Psychology and Psychiatry. 2011;52(7):741-52. [pmid: 21418212].
30 Itzchak EB, Zachor DA. Who Benefits from Early Intervention in Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 2011;5(1):345-50. EJ900428.
31 Zachor DA, Itzchak EB. Treatment Approach, Autism Severity and Intervention Outcomes in Young Children. Research in Autism Spectrum Disorders. 2010;4(3):425-32. EJ878590.
32 Roberts J, Williams K, Carter M, et al. A Randomised Controlled Trial of Two Early Intervention Programs for Young Children with Autism: Centre-Based with Parent Program and Home-Based. Research in Autism Spectrum Disorders. 2011;5(4):1553-66. EJ927523.
33 Strain PS, Bovey EH. Randomized, Controlled Trial of the Leap Model of Early Intervention for Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(3):133-54. EJ942105.
34 Green J, Charman T, McConachie H, et al. Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. 2010. May. 20. [pmid: 20494434].
35 Ingersoll B. Brief report: Pilot randomized controlled trial of reciprocal imitation training for teaching elicited and spontaneous imitation to children with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1154-60. 2010-17107-012. [pmid: 20155309].
36 Ingersoll B. Brief report: effect of a focused imitation intervention on social functioning in children with autism. J Autism Dev Disord. Aug. 2012;42(8):1768-73. [pmid: 22146934].
37 Kasari C, Gulsrud AC, Wong C, et al. Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1045-56. 2010-17107-001. [pmid: 20145986].
38 Keen D, Couzens D, Muspratt S, et al. The effects of a parent-focused intervention for children with a recent diagnosis of autism spectrum disorder on parenting stress and competence. Research in Autism Spectrum Disorders. 2010;4(2):229-41. 2011-03277-009.
39 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. [pmid: 20440639].
40 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov-Dec. 2010;31(6):1678-84. [pmid: 20627451].
41 Hayward D, Eikeseth S, Gale C, et al. Assessing progress during treatment for young children with autism receiving intensive behavioural interventions. Autism. Nov. 2009;13(6):613-33. [pmid: 19933766].
42 Eikeseth S, Hayward D, Gale C, et al. Intensity of Supervision and Outcome for Preschool Aged Children Receiving Early and Intensive Behavioral Interventions: A Preliminary Study. Research in Autism Spectrum Disorders. Jan. 2009;3(1):67-73. PMID: EJ820616.
43 Reed P, Osborne LA, Corness M. Brief report: relative effectiveness of different home-based behavioral approaches to early teaching intervention. J Autism Dev Disord. Oct. 2007;37(9):1815-21. [pmid: 17180714].
44 Zachor DA, Ben-Itzchak E, Rabinovich A-L, et al. Change in autism core symptoms with intervention. Research in Autism Spectrum Disorders. 2007;1(4):304-17.
45 Cohen H, Amerine-Dickens M, Smith T. Early intensive behavioral treatment: replication of the UCLA model in a community setting. J Dev Behav Pediatr. Apr. 2006;27(2 Suppl):S145-55. [pmid: 16685181].
46 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. Jun. 2006;47(6):611-20. [pmid: 16712638].
47 Kasari C, Gulsrud A, Freeman S, et al. Longitudinal follow-up of children with autism receiving targeted interventions on joint attention and play. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):487-95. [pmid: 22525955].
48 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. Feb. 2008;76(1):125-37. [pmid: 18229990].
49 Lawton K, Kasari C. Brief Report: Longitudinal Improvements in the Quality of Joint Attention in Preschool Children with Autism. Journal of Autism and Developmental Disorders. 2012;42(2):307-12. EJ954567. [pmid: 22187107].
50 Howard JS, Sparkman CR, Cohen HG, et al. A comparison of intensive behavior analytic and eclectic treatments for young children with autism. Res Dev Disabil. Jul-Aug. 2005;26(4):359-83. [pmid: 15766629].
51 Sallows GO, Graupner TD. Intensive behavioral treatment for children with autism: four-year outcome and predictors. Am J Ment Retard. Nov. 2005;110(6):417-38. [pmid: 16212446].
52 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. Dec. 2002;11(6):266-72. [pmid: 12541005].
53 Eikeseth S, Smith T, Jahr E, et al. Intensive behavioral treatment at school for 4- to 7-year-old children with autism. A 1-year comparison controlled study. Behav Modif. Jan. 2002;26(1):49-68. [pmid: 11799654].
54 Eikeseth S, Smith T, Jahr E, et al. Outcome for children with autism who began intensive behavioral treatment between ages 4 and 7: a comparison controlled study. Behav Modif. May. 2007;31(3):264-78. [pmid: 17438342].