# Evidence Table for Diagnostic Accuracy Studies

Appendix C Evidence Table: Screening Studies in Primary Care Populations

## References

1 Chlebowski C, Robins DL, Barton ML, et al. Large-scale use of the modified checklist for autism in low-risk toddlers. Pediatrics. Apr. 2013;131(4):e1121-7. [pmid: 23530174].
2 Robins DL. Screening for autism spectrum disorders in primary care settings. Autism. Sep. 2008;12(5):537-56. [pmid: 18805946].
3 Kleinman JM, Robins DL, Ventola PE, et al. The modified checklist for autism in toddlers: a follow-up study investigating the early detection of autism spectrum disorders. J Autism Dev Disord. May. 2008;38(5):827-39. [pmid: 17882539].
4 Pandey J, Verbalis A, Robins DL, et al. Screening for autism in older and younger toddlers with the Modified Checklist for Autism in Toddlers. Autism. Sep. 2008;12(5):513-35. [pmid: 18805945].
5 Robins DL, Fein D, Barton ML, et al. The Modified Checklist for Autism in Toddlers: an initial study investigating the early detection of autism and pervasive developmental disorders. J Autism Dev Disord. Apr. 2001;31(2):131-44. [pmid: 11450812].
6 Nygren G, Sandberg E, Gillstedt F, et al. A new screening programme for autism in a general population of Swedish toddlers. Res Dev Disabil. Jul-Aug. 2012;33(4):1200-10. [pmid: 22502846].
7 Barbaro J, Ridgway L, Dissanayake C. Developmental surveillance of infants and toddlers by maternal and child health nurses in an Australian community-based setting: promoting the early identification of autism spectrum disorders. J Pediatr Nurs. Aug. 2011;26(4):334-47. [pmid: 21726784].
8 Barbaro J, Dissanayake C. Prospective identification of autism spectrum disorders in infancy and toddlerhood using developmental surveillance: the social attention and communication study. J Dev Behav Pediatr. Jun. 2010;31(5):376-85. [pmid: 20495475].
9 Canal-Bedia R, Garcia-Primo P, Martin-Cilleros MV, et al. Modified checklist for autism in toddlers: cross-cultural adaptation and validation in Spain. J Autism Dev Disord. Oct. 2011;41(10):1342-51. [pmid: 21161677].
10 Inada N, Koyama T, Inokuchi E, et al. Reliability and validity of the Japanese version of the Modified Checklist for autism in toddlers (M-CHAT). Research in Autism Spectrum Disorders. 2011;5(1):330-6. 2010-22960-034.
11 Miller JS, Gabrielsen T, Villalobos M, et al. The each child study: systematic screening for autism spectrum disorders in a pediatric setting. Pediatrics. May. 2011;127(5):866-71. [pmid: 21482605].
12 Pierce K, Carter C, Weinfeld M, et al. Detecting, studying, and treating autism early: the one-year well-baby check-up approach. J Pediatr. Sep. 2011;159(3):458-65 e1-6. [pmid: 21524759].
13 Honda H, Shimizu Y, Nitto Y, et al. Extraction and Refinement Strategy for detection of autism in 18-month-olds: a guarantee of higher sensitivity and specificity in the process of mass screening. J Child Psychol Psychiatry. Aug. 2009;50(8):972-81. [pmid: 19298465].
14 Wetherby AM, Brosnan-Maddox S, Peace V, et al. Validation of the infant-toddler checklist as a broadband screener for autism spectrum disorders from 9 to 24 months of age. Autism. 2008;12(5):487-511. 2008-13622-005. [pmid: 18805944].
15 Dietz C, Swinkels SH, van Daalen E, et al. Parental compliance after screening social development in toddlers. Arch Pediatr Adolesc Med. Apr. 2007;161(4):363-8. [pmid: 17404133].
16 Dietz C, Swinkels S, van Daalen E, et al. Screening for autistic spectrum disorder in children aged 14-15 months. II: population screening with the Early Screening of Autistic Traits Questionnaire (ESAT). Design and general findings. J Autism Dev Disord. Aug. 2006;36(6):713-22. [pmid: 16633887].
17 VanDenHeuvel A, Fitzgerald M, Greiner B, et al. Screening for autistic spectrum disorder at the 18-month developmental assessment: a population-based study. Ir Med J. Sep. 2007;100(8):565-7. [pmid: 17955715].
18 Baird G, Charman T, Baron-Cohen S, et al. A screening instrument for autism at 18 months of age: a 6-year follow-up study. J Am Acad Child Adolesc Psychiatry. Jun. 2000;39(6):694-702. [pmid: 10846303].