# Screening and Quality/Risk of Bias Assessment Forms

Screening for ASD Systematic Evidence Review Abstract Review Form

Screening for ASD Systematic Evidence Review Full Text Review Form