# Search Strategies

Table 1 PubMed search strategies

Search terms | | Search results
#1 | autistic[tiab] OR autism[tiab] OR autistic disorder[mh] OR asperger syndrome[mh] OR child development disorders, pervasive[mh:noexp] OR asperger[tiab] OR asperger's[tiab] OR aspergers[tiab] OR pervasive development[tiab] OR pervasive developmental[tiab] | 24402
#2 | mass screening[mh] OR screening[tiab] OR screened[tiab] OR screen[tiab] OR screener[tiab] OR screeners[tiab] OR early diagnosis[mh] OR identify[tiab] OR identification[tiab] | 1219531
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 2325
#4 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR jsubsetk | 4819874
#5 | #3 NOT #4 AND 2000:2014[dp] | 1511

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [dp] publication date; jsubsetk consumer health literature

Table 2 PsycINFO search strategies (ProQuest interface)

Search terms | | Search results
#1 | SU.EXACT.EXPLODE(“pervasive developmental disorders” or “aspergers syndrome” or “autism”) | 23790
#2 | SU.EXACT.EXPLODE(screening) or SU.EXACT.EXPLODE(screening tests) or screening or screened or screen or screener or screeners or identify or identification | 232628
#3 | #1 and #2 and DTYPE(journal article) and (ME(empirical study) or ME(field study) or ME(followup study) or ME(longitudinal study) or ME(prospective study) or ME(qualitative study) or ME(quantitative study) or ME(retrospective study) or ME(treatment outcome/clinical trial)) and LA(English), limited to peer-reviewed journals and human population, limited to publication date 2000 to present | 1267

Key: SU.EXACT.EXPLODE subject descriptor; DTYPE publication type; ME methodology; LA language

Table 3 ERIC search strategies (ProQuest interface)

Search terms | | Search results
#1 | (“pervasive developmental disorders”) or autism or autistic or (“asperger syndrome”) | 11548
#2 | screening or screened or screen or screener or screeners or identify or identification | 92626
#3 | #1 and #2, limited to peer reviewed journals, scholarly journals, English only, publication date 2000 to present | 1089

Table 4 CINAHL search strategies (EBSCO interface)

Search terms | | Search results
#1 | (MH “Child Development Disorders, Pervasive”) OR (MH “Asperger Syndrome”) OR (MH “Autistic Disorder”) | 8841
#2 | (MH “Early Diagnosis”) OR (MH “Health Screening”) or screening or screened or screen or screener or screeners or identify or identification | 147216
#3 | #1 AND #2 AND PT systematic review | 23
#4 | #1 AND #2 AND PT review | 49
#5 | #1 AND #2 AND PT case study | 33
#6 | #1 AND #2 NOT (#3 OR #4 OR #5), limited to English, research articles, peer-reviewed journals, and publication date 2000 to present, excluding MEDLINE records | 33

Key: MH subject term; PT publication type