# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders (DSM-5). Arlington, VA. American Psychiatric Publishing. 2013. PMID: None.
2 Gaynes BN, Gavin N, Meltzer-Brody S, et al. Perinatal depression: prevalence, screening accuracy and screening outcomes. AHRQ Publication No. 05-E006-2. Rockville, MD. Agency for Healthcare Research and Quality. 2005. PMID: None.
3 Mojtabai R, Jorm AF. Trends in psychological distress depressive episodes and mental health treatment-seeking in the United States: 2001-2012. J Affect Disord. 2015;174:556-61. PMID:. [pii: S0165-0327(14)00825-8]. [doi: 10.1016/j.jad.2014.12.039]. [pmid: 25556674].
4 Pratt LA, Brody DJ. Depression in the U.S. household population, 2009-2012. Atlanta. U.S. Department of Health and Human Services. 2014. PMID: None.
5 American Psychological Association. Postpartum depression. Washington, D.C. American Psychological Association. 2007. http://www.apa.org/pi/women/programs/depression/postpartum.aspx?item=1 (http://www.apa.org/pi/women/programs/depression/postpartum.aspx?item=). November 20, 2013. PMID: None.
6 Ko JY, Farr SL, Dietz PM, et al. Depression and treatment among U.S. pregnant and nonpregnant women of reproductive age, 2005-2009. J Womens Health (Larchmt ). Aug. 2012;21(8):830-6. PMID:. [doi: 10.1089/jwh.2011.3466]. [pmid: 22691031].
7 Hoertel N, Lopez S, Peyre H, et al. Are symptom features of depression during pregnancy, the postpartum period and outside the peripartum period distinct? Results from a nationally representative sample using item response theory (IRT). Depress Anxiety. Nov. 25. 2014;32:129-40. [pmid: 25424539].
8 Mitchell AJ, Rao S, Vaze A. International comparison of clinicians' ability to identify depression in primary care: meta-analysis and meta-regression of predictors. Br J Gen Pract. Feb. 2011;61(583):e72-e80. [pmid: 21276327].
9 Results from the 2013 National Survey on Drug Use and Health: Mental Health. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2015. PMID: None.
10 Delville CL, McDougall G. A systematic review of depression in adults with heart failure: instruments and incidence. Issues Ment Health Nurs. Sep. 2008;29(9):1002-17. [pmid: 18770104].
11 Massie MJ. Prevalence of depression in patients with cancer. J Natl Cancer Inst Monogr. 2004;(32):57-71. [pmid: 15263042].
12 Davis L, Uezato A, Newell JM, et al. Major depression and comorbid substance use disorders. Curr Opin Psychiatry. Jan. 2008;21(1):14-8. [pmid: 18281835].
13 Hirschfeld RM, Weissman MM. Risk factors for major depression and bipolar disorder. Davis KL, Charney D, Coyle JT, et al., editors. Neuropsychopharmacology: The Fifth Generation of Progress. Brentwood, TN. American College of Neuropsychopharmacology. 2002:1017-25. PMID: None.
14 Beck CT. Predictors of postpartum depression: an update. Nurs Res. Sep. 2001;50(5):275-85. [pmid: 11570712].
15 Cole MG, Dendukuri N. Risk factors for depression among elderly community subjects: a systematic review and meta-analysis. Am J Psychiatry. Jun. 2003;160(6):1147-56. [pmid: 12777274].
16 Beck A, Crain AL, Solberg LI, et al. Severity of depression and magnitude of productivity loss. Ann Fam Med. 2011;9(4):305-11. [pmid: 21747101].
17 Jain G, Roy A, Harikrishnan V, et al. Patient-reported depression severity measured by the PHQ-9 and impact on work productivity: results from a survey of full-time employees in the United States. J Occup Environ Med. Mar. 2013;55(3):252-8. [pmid: 23439268].
18 Witters D, Agrawal S, Liu D. Depression costs U.S. workplaces $23 billion in absenteeism. Washington, D.C. Gallup, Inc. 2013. http://www.gallup.com/poll/163619/depression-costs-workplaces-billion-absenteeism.aspx. September 13, 2013. PMID: None.
19 Soni A. Trends in use and expenditures for depression among U.S. adults age 18 and older, civilian noninstitutionalized population, 1999 and 2009. Statistical Brief No. 377. Rockville, MD. Agency for Healthcare Research and Quality. 2012. PMID: None.
20 Whooley MA, Browner WS. Association between depressive symptoms and mortality in older women. Study of Osteoporotic Fractures Research Group. Arch Intern Med. Oct. 26. 1998;158(19):2129-35. [pmid: 9801180].
21 Stromberg R, Backlund LG, Johansson SE, et al. Mortality in depressed and non-depressed primary care Swedish patients: a 12-year follow-up cohort study. Fam Pract. Oct. 2013;30(5):514-9. [pmid: 23913789].
22 Chang HJ, Lin HC, Lee HC, et al. Risk of mortality among depressed younger patients: a five-year follow-up study. J Affect Disord. Mar. 2009;113(3):255-62. [pmid: 18640727].
23 Pan A, Sun Q, Okereke OI, et al. Depression and risk of stroke morbidity and mortality: a meta-analysis and systematic review. JAMA. Sep. 21. 2011;306(11):1241-9. [pmid: 21934057].
24 Zivin K, Ilgen MA, Pfeiffer PN, et al. Early mortality and years of potential life lost among Veterans Affairs patients with depression. Psychiatr Serv. Aug. 2012;63(8):823-6. [pmid: 22854727].
25 Li Z, Page A, Martin G, et al. Attributable risk of psychiatric and socio-economic factors for suicide from individual-level, population-based studies: a systematic review. Soc Sci Med. Feb. 2011;72(4):608-16. [pmid: 21211874].
26 Bolton JM, Robinson J. Population-attributable fractions of Axis I and Axis II mental disorders for suicide attempts: findings from a representative sample of the adult, noninstitutionalized US population. Am J Public Health. Dec. 2010;100(12):2473-80. [pmid: 21068419].
27 Kessler RC, Merikangas KR, Wang PS. Prevalence, comorbidity, and service utilization for mood disorders in the United States at the beginning of the twenty-first century. Annu Rev Clin Psychol. 2007;3:137-58. [pmid: 17716051].
28 Unutzer J, Patrick DL, Diehr P, et al. Quality adjusted life years in older adults with depressive symptoms and chronic medical disorders. Int Psychogeriatr. Mar. 2000;12(1):15-33. [pmid: 10798451].
29 van Wijngaarden B, Schene AH, Koeter MW. Family caregiving in depression: impact on caregivers' daily life, distress, and help seeking. J Affect Disord. Sep. 2004;81(3):211-22. [pmid: 15337325].
30 Sobieraj M, Williams J, Marley J, et al. The impact of depression on the physical health of family members. Br J Gen Pract. Oct. 1998;48(435):1653-5. [pmid: 10071397].
31 Luciano M, Del Vecchio V, Giacco D, et al. A ‘family affair’? The impact of family psychoeducational interventions on depression. Expert Rev Neurother. 2012;12(1):83-92. [pmid: 22243046].
32 Kersten-Alvarez LE, Hosman CM, Riksen-Walraven JM, et al. Early school outcomes for children of postpartum depressed mothers: comparison with a community sample. Child Psychiatry Hum Dev. Apr. 2012;43(2):201-18. [pmid: 22011810].
33 Beardslee WR, Versage EM, Gladstone TR. Children of affectively ill parents: a review of the past 10 years. J Am Acad Child Adolesc Psychiatry. Nov. 1998;37(11):1134-41. [pmid: 9808924].
34 Kessler RC, Berglund P, Demler O, et al. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):593-602. [pmid: 15939837].
35 Whiteford HA, Harris MG, McKeon G, et al. Estimating remission from untreated major depression: a systematic review and meta-analysis. Psychol Med. Aug. 2013;43(8):1569-85. [pmid: 22883473].
36 Hughes S, Cohen D. A systematic review of long-term studies of drug treated and non-drug treated depression. J Affect Disord. Nov. 2009;118(1-3):9-18. [pmid: 19249104].
37 Meeks TW, Vahia IV, Lavretsky H, et al. A tune in “a minor” can “b major”: A review of epidemiology, illness course, and public health implications of subthreshold depression in older adults. J Affect Disord. 2011;129(1-3):126-42. [pmid: 20926139].
38 Hardeveld F, Spijker J, De Graaf R, et al. Prevalence and predictors of recurrence of major depressive disorder in the adult population. Acta Psychiatr Scand. 2010;122(3):184-91. [pmid: 20003092].
39 Tsuang MT, Bar JL, Stone WS, et al. Gene-environment interactions in mental disorders. World Psychiatry. Jun. 2004;3(2):73-83. [pmid: 16633461].
40 Disner SG, Beevers CG, Haigh EA, et al. Neural mechanisms of the cognitive model of depression. Nat Rev Neurosci. Aug. 2011;12(8):467-77. [pmid: 21731066].
41 Lewinsohn PM, Clarke GN, Rohde P, et al. A course in coping: A Cognitive-behavioral approach to the treatment of adolescent depression. Hibbs ED, Jensen PS, editors. Psychosocial Treatments for Children and Adolescent Disorders: Empiricially Based Strategies for Clinical Practice. Washington, DC. 1996:109-35. PMID: None.
42 Palazidou E. The neurobiology of depression. Br Med Bull. 2012;101:127-45. [pmid: 22334281].
43 Kempton MJ, Salvador Z, Munafo MR, et al. Structural neuroimaging studies in major depressive disorder. Meta-analysis and comparison with bipolar disorder. Arch Gen Psychiatry. Jul. 2011;68(7):675-90. [pmid: 21727252].
44 Sexton CE, Mackay CE, Ebmeier KP. A systematic review and meta-analysis of magnetic resonance imaging studies in late-life depression. Am J Geriatr Psychiatry. Feb. 2013;21(2):184-95. [pmid: 23343492].
45 Levinson DF. The genetics of depression: a review. Biol Psychiatry. Jul. 15. 2006;60(2):84-92. [pmid: 16300747].
46 McGuffin P, Katz R. The genetics of depression and manic-depressive disorder. Br J Psychiatry. Sep. 1989;155:294-304. [pmid: 2692760].
47 Pence BW, O'Donnell JK, Gaynes BN. The depression treatment cascade in primary care: a public health perspective. Curr Psychiatry Rep. Aug. 2012;14(4):328-35. [pmid: 22580833].
48 Mitchell AJ, Vaze A, Rao S. Clinical diagnosis of depression in primary care: a meta-analysis. Lancet. 2009;374(9690):609-19. [pmid: 19640579].
49 Mojtabai R. Diagnosing depression in older adults in primary care. N Engl J Med. Mar. 27. 2014;370(13):1180-2. [pmid: 24670164].
50 Gaynes BN, Rush AJ, Trivedi MH, et al. Major depression symptoms in primary care and psychiatric care settings: a cross-sectional analysis. Ann Fam Med. Mar. 2007;5(2):126-34. [pmid: 17389536].
51 Centers for Disease Control and Prevention. National Hospital Ambulatory Medical Care Survey: 2010 outpatient department summary tables. Atlanta, GA. Centers for Disease Control and Prevention. 2010. PMID: None.
52 Harrison DL, Miller MJ, Schmitt MR, et al. Variations in the probability of depression screening at community-based physician practice visits. Prim Care Companion J Clin Psychiatry. 2010;12(5):e1-e8. [pmid: 21274358].
53 Margaretten ME, Katz P, Schmajuk G, et al. Missed opportunities for depression screening in patients with arthritis in the United States. J Gen Intern Med. Jul. 30. 2013;28(12):1637-42. [pmid: 23897128].
54 Gonzalez HM, Vega WA, Williams DR, et al. Depression care in the United States: too little for too few. Arch Gen Psychiatry. Jan. 2010;67(1):37-46. [pmid: 20048221].
55 Wang PS, Berglund P, Olfson M, et al. Failure and delay in initial treatment contact after first onset of mental disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):603-13. [pmid: 15939838].
56 Wang PS, Lane M, Olfson M, et al. Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):629-40. [pmid: 15939840].
57 Mojtabai R, Olfson M. National trends in psychotropic medication polypharmacy in office-based psychiatry. Arch Gen Psychiatry. Jan. 2010;67(1):26-36. [pmid: 20048220].
58 Mojtabai R. Clinician-identified depression in community settings: concordance with structured-interview diagnoses. Psychother Psychosom. 2013;82(3):161-9. [pmid: 23548817].
59 Lyell DJ, Chambers AS, Steidtmann D, et al. Antenatal identification of major depressive disorder: a cohort study. Am J Obstet Gynecol. Dec. 2012;207(6):506. [pmid: 23099192].
60 Connelly CD, Baker MJ, Hazen AL, et al. Pediatric health care providers' self-reported practices in recognizing and treating maternal depression. Pediatr Nurs. Mar. 2007;33(2):165-72. 127. [pmid: 17542239].
61 Leiferman JA, Dauber SE, Heisler K, et al. Primary care physicians' beliefs and practices toward maternal depression. J Womens Health (Larchmt). Sep. 2008;17(7):1143-50. [pmid: 18657043].
62 Horwitz SM, Kelleher KJ, Stein RE, et al. Barriers to the identification and management of psychosocial issues in children and maternal depression. Pediatrics. Jan. 2007;119(1):e208-e218. [pmid: 17200245].
63 Larocco-Cockburn A, Reed SD, Melville J, et al. Improving depression treatment for women: Integrating a collaborative care depression intervention into OB-GYN care. Contemp Clin Trials. Nov. 2013;36(2):362-70. [pmid: 23939510].
64 Leddy M, Haaga D, Gray J, et al. Postpartum mental health screening and diagnosis by obstetrician-gynecologists. J Psychosom Obstet Gynaecol. Mar. 2011;32(1):27-34. [pmid: 21261561].
65 Seehusen DA, Baldwin LM, Runkle GP, et al. Are family physicians appropriately screening for postpartum depression?. J Am Board Fam Pract. Mar. 2005;18(2):104-12. [pmid: 15798139].
66 Chadha-Hooks PL, Hui PJ, Hilty DM, et al. Postpartum depression: an original survey of screening practices within a healthcare system. J Psychosom Obstet Gynaecol. Sep. 2010;31(3):199-205. [pmid: 20482291].
67 Sleath BL, Thomas N, Jackson E, et al. Physician reported communication about depression and psychosocial issues during postpartum visits. N C Med J. May. 2007;68(3):151-5. [pmid: 17674685].
68 Wu J, Davis-Ajami ML. Antidepressant treatment persistence in low-income, insured pregnant women. J Manag Care Pharm. Jun. 2014;20(6):631-7. [pmid: 24856601].
69 Yawn BP, Dietrich AJ, Wollan P, et al. TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Ann Fam Med. Jul. 2012;10(4):320-9. [pmid: 22778120].
70 American Psychiatric Association. American Psychiatric Association Practice Guidelines for the Treatment of Psychiatric Disorders. Arlington. American Psychiatry Publishing. 2006. PMID: None.
71 Adler DA, Bungay KM, Wilson IB, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. Gen Hosp Psychiatry. May. 2004;26(3):199-209. [pmid: 15121348].
72 Bergus GR, Hartz AJ, Noyes R Jr., et al. The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. J Rural Health. 2005;21(4):303-9. [pmid: 16294652].
73 Rost K, Nutting P, Smith J, et al. Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. Mar. 2001;16(3):143-9. [pmid: 11318908].
74 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. Dec. 11. 2002;288(22):2836-45. [pmid: 12472325].
75 LeFevre ML. Screening for suicide risk in adolescents, adults, and older adults in primary care: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. May. 20. 2014;160(10):719-26. [pmid: 24842417].
76 Maurer DM. Screening for depression. Am Fam Physician. Jan. 15. 2012;85(2):139-44. [pmid: 22335214].
77 Centers for Disease Control and Prevention. The New Ambulatory Care Drug Reporting System. Atlanta, GA. Centers for Disease Control and Prevention. 2012. http://www2.cdc.gov/drugs/applicationnav1.asp. January 7, 2014. PMID: None.
78 Pratt LA, Brody DJ, Gu Q. Antidepressant use in persons aged 12 and over: United States, 2005-2008. NCHS Data Brief. 2011;(76):1-8. PMID: None. [pmid: 22617183].
79 American Psychiatric Association. Practice guideline for the treatment of patients with a major depressive disorder. Arlington, VA. American Psychiatric Association. 2010. PMID: None.
80 O'Connor EA, Whitlock EP, Gaynes B, et al. Screening for Depression in Adults and Older Adults in Primary Care: An Updated Systematic Review. AHRQ Publication No.10-05143-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2009. [pmid: 20722174].
81 Kux L. Content and format of labeling human prescription drug and biological products; requirements for pregnancy and lactation labeling. Washington D.C. Office of the Federal Register. 2014. https://www.federalregister.gov/articles/2014/12/04/2014-28241/content-and-format-of-labeling-for-human-prescription-drug-and-biological-products-requirements-for. PMID: None.
82 Hale TW. Medications and mother's milk. Amarillo, TX. Hale Publishing, L.P. 2012. PMID: None.
83 Thota AB, Sipe TA, Byard GJ, et al. Collaborative care to improve the management of depressive disorders: a community guide systematic review and meta-analysis. Am J Prev Med. 2012;42(5):525-38. [pmid: 22516495].
84 U.S.Department of Health and Human Services. Healthy People 2020 summary of objectives: mental health and mental disorders. Washington DC. U.S. Department of Health and Human Services. 2013. http://www.healthypeople.gov/2020/topicsobjectives2020/objectiveslist.aspx?topicId=28 (http://www.healthypeople.gov/2020/topicsobjectives2020/objectiveslist.aspx?topicId=). September 11, 2013. PMID: None.
85 Rhodes AM, Segre LS. Perinatal depression: a review of US legislation and law. Arch Womens Ment Health. Aug. 2013;16(4):259-70. [pmid: 23740222].
86 Screening for depression in adults: U.S. preventive services task force recommendation statement. Ann Intern Med. Dec. 1. 2009;151(11):784-92. [pmid: 19949144].
87 Pignone MP, Gaynes BN, Rushton JL, et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. May. 21. 2002;136(10):765-76. [pmid: 12020146].
88 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. May. 20. 2008;148(10):776-82. [pmid: 18490690].
89 Myers ER, Aubuchon-Endsley N, Bastian LA, et al. Efficacy and safety of screening for postpartum depression. Comparative Effectiveness Review. Rockville, MD. Agency for Healthcare Research and Quality. 2013;106. [pmid: 23678510].
90 Hewitt C, Gilbody S, Brealey S, et al. Methods to identify postnatal depression in primary care: an integrated evidence synthesis and value of information analysis. Health Technology Assessment (Winchester, England). 2009;13(36):1-145. [pmid: 19624978].
91 McDonagh M, Matthews A, Phillipi C, et al. Treatment of depression during pregnancy and the postpartum period. Rockville, MD. Agency for Healthcare Research and Quality. 2013. PMID: None.
92 Wallace BC, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium. 2012:819-24. PMID: None.
93 United Nations Development Programme. Human Development Report 2013. The Rise of the South: Human Progress in a Diverse World. New York, NY. United Nations Development Programme. 2013. PMID: None.
94 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
95 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
96 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Ottawa. Ottawa Hospital Research Institute. 2014. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. January 21, 2014. PMID: None.
97 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
98 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemp Clin Trials. 2007;28(2):105-14. [pmid: 16807131].
99 Egger M, Davey SG, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 13. 1997;315(7109):629-34. [pmid: 9310563].
100 Morrell CJ, Warner R, Slade P, et al. Psychological interventions for postnatal depression: cluster randomised trial and economic evaluation. The PONDER trial. Health Technol Assess. 2009;13(30):1-176. PMID: None. [pmid: 19624978].
101 Cox JL, Chapman G, Murray D, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. Jul. 29. 1996;39(3):185-9. [pmid: 8856422].
102 Garcia-Esteve L, Ascaso C, Ojuel J, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Spanish mothers. J Affect Disord. Jun. 2003;75(1):71-6. [pmid: 12781353].
103 Begg CB, Greenes RA. Assessment of diagnostic tests when disease verification is subject to selection bias. Biometrics. Mar. 1983;39(1):207-15. [pmid: 6871349].
104 Glavin K, Smith L, Sorum R, et al. Redesigned community postpartum care to prevent and treat postpartum depression in women--a one-year follow-up study. J Clin Nurs. Nov. 2010;19(21-22):3051-62. [pmid: 20726926].
105 Leung SS, Leung C, Lam TH, et al. Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). Jun. 2011;33(2):292-301. [pmid: 20884642].
106 MacArthur C, Winter HR, Bick DE, et al. Effects of redesigned community postnatal care on womens' health 4 months after birth: a cluster randomised controlled trial. Lancet. Feb. 2. 2002;359(9304):378-85. [pmid: 11844507].
107 Wickberg B, Tjus T, Hwang P. Using the EPDS in routine antenatal care in Sweden: a naturalistic study. J Reprod Infant Psychol. Feb. 1. 2005;23(1):33-41. PMID: None.
108 Adouard F, Glangeaud-Freudenthal NM, Golse B. Validation of the Edinburgh postnatal depression scale (EPDS) in a sample of women with high-risk pregnancies in France. Arch Womens Ment Health. Jun. 2005;8(2):89-95. [pmid: 15883653].
109 Beck CT, Gable RK. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. Jul. 2001;50(4):242-50. [pmid: 11480533].
110 Benvenuti P, Ferrara M, Niccolai C, et al. The Edinburgh Postnatal Depression Scale: validation for an Italian sample. J Affect Disord. May. 1999;53(2):137-41. [pmid: 10360408].
111 Bunevicius A, Kusminskas L, Bunevicius R. Validation of the Lithuanian version of the Edinburgh Postnatal Depression Scale. Medicina (Kaunas, Lithuania). 2009;45(7):544-8. [pmid: 19667749].
112 Bunevicius A, Kusminskas L, Pop VJ, et al. Screening for antenatal depression with the Edinburgh Depression Scale. J Psychosom Obstet Gynaecol. Dec. 2009;30(4):238-43. [pmid: 19845492].
113 Carpiniello B, Pariante CM, Serri F, et al. Validation of the Edinburgh Postnatal Depression Scale in Italy. J Psychosom Obstet Gynaecol. Dec. 1997;18(4):280-5. [pmid: 9443138].
114 Chen H, Bautista D, Ch'ng YC, et al. Screening for postnatal depression in Chinese-speaking women using the Hong Kong translated version of the Edinburgh Postnatal Depression Scale. Asia Pac Psychiatry. Jun. 2013;5(2):E64-E72. [pmid: 23857814].
115 Guedeney N, Fermanian J. Validation study of the French version of the Edinburgh Postnatal Depression Scale (EPDS): new results about use and psychometric properties. Eur Psychiatry. 1998;13(2):83-9. [pmid: 19698604].
116 Harris B, Huckle P, Thomas R, et al. The use of rating scales to identify post-natal depression. Br J Psychiatry. Jun. 1989;154:813-7. [pmid: 2597888].
117 Lee DT, Yip AS, Chiu HF, et al. Screening for postnatal depression: are specific instruments mandatory?. J Affect Disord. Mar. 2001;63(1-3):233-8. [pmid: 11246101].
118 Leverton TJ, Elliott SA. Is the EPDS a magic wand?: 1. A comparison of the Edinburgh Postnatal Depression Scale and health visitor report as predictors of diagnosis on the Present State Examination. J Reprod Infant Psychol. Nov. 1. 2000;18(4):279-96. PMID: None.
119 Tandon SD, Cluxton-Keller F, Leis J, et al. A comparison of three screening tools to identify perinatal depression among low-income African American women. J Affect Disord. Jan. 2012;136(1-2):155-62. [pmid: 21864914].
120 Teng HW, Hsu CS, Shih SM, et al. Screening postpartum depression with the Taiwanese version of the Edinburgh Postnatal Depression scale. Compr Psychiatry. Jul. 2005;46(4):261-5. [pmid: 16175756].
121 Toreki A, Ando B, Kereszturi A, et al. The Edinburgh Postnatal Depression Scale: translation and antepartum validation for a Hungarian sample. Midwifery. Apr. 2013;29(4):308-15. [pmid: 22417756].
122 Toreki A, Ando B, Dudas RB, et al. Validation of the Edinburgh Postnatal Depression Scale as a screening tool for postpartum depression in a clinical sample in Hungary. Midwifery. Aug. 2014;30(8):911-8. [pmid: 24742635].
123 Yamashita H, Yoshida K, Nakano H, et al. Postnatal depression in Japanese women. Detecting the early onset of postnatal depression by closely monitoring the postpartum mood. J Affect Disord. May. 2000;58(2):145-54. [pmid: 10781704].
124 Alvarado R, Jadresic E, Guajardo V, et al. First validation of a Spanish-translated version of the Edinburgh postnatal depression scale (EPDS) for use in pregnant women. A Chilean study. Arch Womens Ment Health. 2014. Oct. 11. [pmid: 25300676].
125 Murray D, Cox JL. Screening for depression during pregnancy with the Edinburgh Depression Scale (EPDS). J Reprod Infant Psychol. 1990;8:99-107. PMID: None.
126 Clarke PJ. Validation of two postpartum depression screening scales with a sample of First Nations and Metis women. Can J Nurs Res. Mar. 2008;40(1):113-25. [pmid: 18459275].
127 Felice E, Saliba J, Grech V, et al. Validation of the Maltese version of the Edinburgh Postnatal Depression Scale. Arch Womens Ment Health. Mar. 2006;9(2):75-80. [pmid: 16172837].
128 Gjerdingen D, Crow S, McGovern P, et al. Postpartum depression screening at well-child visits: validity of a 2-question screen and the PHQ-9. Ann Fam Med. Jan. 2009;7(1):63-70. [pmid: 19139451].
129 Mann R, Adamson J, Gilbody SM. Diagnostic accuracy of case-finding questions to identify perinatal depression. CMAJ. May. 15. 2012;184(8):E424-E430. [pmid: 22451686].
130 Smith MV, Gotman N, Lin H, et al. Do the PHQ-8 and the PHQ-2 accurately screen for depressive disorders in a sample of pregnant women?. Gen Hosp Psychiatry. Sep. 2010;32(5):544-8. [pmid: 20851275].
131 Ammerman RT, Putnam FW, Altaye M, et al. A clinical trial of in-home CBT for depressed mothers in home visitation. Behav Ther. Sep. 2013;44(3):359-72. [pmid: 23768664].
132 Andersen JT, Andersen NL, Horwitz H, et al. Exposure to selective serotonin reuptake inhibitors in early pregnancy and the risk of miscarriage. Obstet Gynecol. Oct. 2014;124(4):655-61. [pmid: 25198261].
133 Appleby L, Warner R, Whitton A, et al. A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ. Mar. 29. 1997;314(7085):932-6. [pmid: 9099116].
134 Ban L, Gibson J, West J, et al. Maternal depression, antidepressant prescriptions, and congenital anomaly risk in offspring: a population-based cohort study. BJOG. 2014. Mar. 11. [pmid: 24612301].
135 Cooper PJ, Murray L, Wilson A, et al. Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression. I. Impact on maternal mood. Br J Psychiatry. May. 2003;182:412-9. [pmid: 12724244].
136 Gjerdingen D, Crow S, McGovern P, et al. Stepped care treatment of postpartum depression: impact on treatment, health, and work outcomes. J Am Board Fam Med. Sep. 2009;22(5):473-82. [pmid: 19734392].
137 Hayes RM, Wu P, Shelton RC, et al. Maternal antidepressant use and adverse outcomes: a cohort study of 228,876 pregnancies. [Erratum appears in Am J Obstet Gynecol. 2013 Apr;208(4):326]. Am J Obstet Gynecol. Jul. 2012;207(1):49. [pmid: 22727349].
138 Heh SS, Fu YY. Effectiveness of informational support in reducing the severity of postnatal depression in Taiwan. J Adv Nurs. Apr. 2003;42(1):30-6. [pmid: 12641809].
139 Holden JM, Sagovsky R, Cox JL. Counselling in a general practice setting: controlled study of health visitor intervention in treatment of postnatal depression. BMJ. Jan. 28. 1989;298(6668):223-6. [pmid: 2493868].
140 Honey KL, Bennett P, Morgan M. A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol. Nov. 2002;41(Pt 4):405-9. [pmid: 12437794].
141 Horowitz JA, Bell M, Trybulski J, et al. Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 2001;33(4):323-9. [pmid: 11775301].
142 Huybrechts KF, Palmsten K, Avorn J, et al. Antidepressant use in pregnancy and the risk of cardiac defects. N Engl J Med. Jun. 19. 2014;370(25):2397-407. [pmid: 24941178].
143 Jensen HM, Gron R, Lidegaard O, et al. The effects of maternal depression and use of antidepressants during pregnancy on risk of a child small for gestational age. Psychopharmacology. Jul. 2013;228(2):199-205. [pmid: 23455598].
144 Kjaersgaard MI, Parner ET, Vestergaard M, et al. Prenatal antidepressant exposure and risk of spontaneous abortion - a population-based study. PLOS ONE. 2013;8(8):e72095. [pmid: 24015208].
145 Kozinszky Z, Dudas RB, Devosa I, et al. Can a brief antepartum preventive group intervention help reduce postpartum depressive symptomatology?. Psychother Psychosom. 2012;81(2):98-107. [pmid: 22261988].
146 Lupattelli A, Spigset O, Kore G, et al. Risk of vaginal bleeding and postpartum hemorrhage after use of antidepressants in pregnancy: A study from the Norwegian Mother and Child Cohort Study. J Clin Psychopharmacol. 2014;34(1):143-8. [pmid: 24135843].
147 McGregor M, Coghlan M, Dennis CL. The effect of physician-based cognitive behavioural therapy among pregnant women with depressive symptomatology: a pilot quasi-experimental trial. Early Interv Psychiatry. Jul. 15. 2013;8(4):348-57. [pmid: 23855406].
148 Milgrom J, Negri LM, Gemmill AW, et al. A randomized controlled trial of psychological interventions for postnatal depression. Br J Clin Psychol. Nov. 2005;44(Pt 4):529-42. [pmid: 16368032].
149 Milgrom J, Holt CJ, Gemmill AW, et al. Treating postnatal depressive symptoms in primary care: a randomised controlled trial of GP management, with and without adjunctive counselling. BMC Psychiatry. 2011;11:95. [pmid: 21615968].
150 Palmsten K, Hernandez-Diaz S, Huybrechts KF, et al. Use of antidepressants near delivery and risk of postpartum hemorrhage: cohort study of low income women in the United States. BMJ. 2013;347:f4877. [pmid: 23965506].
151 Palmsten K, Huybrechts KF, Michels KB, et al. Antidepressant use and risk for preeclampsia. Epidemiology. Sep. 2013;24(5):682-91. [pmid: 23873072].
152 Polen KN, Rasmussen SA, Riehle-Colarusso T, et al. Association between reported venlafaxine use in early pregnancy and birth defects, national birth defects prevention study, 1997-2007. Birth Defects Res. Jan. 2013;97(1):28-35. [pmid: 23281074].
153 Prendergast J, Austin MP. Early childhood nurse-delivered cognitive behavioural counselling for post-natal depression. Australas Psychiatry. 2001;9(3):255-9. PMID: None.
154 Wickberg B, Hwang CP. Counselling of postnatal depression: A controlled study on a population based Swedish sample. J Affect Disorder. 1996;39:209-16. [pmid: 8856425].
155 Wiklund I, Mohlkert P, Edman G. Evaluation of a brief cognitive intervention in patients with signs of postnatal depression: a randomized controlled trial. Acta Obstet Gynecol Scand. Aug. 2010;89(8):1100-4. [pmid: 20636249].
156 Segre LS, Brock RL, O'Hara MW. Depression treatment for impoverished mothers by point-of-care providers: a randomized controlled trial. J Consult Clin Psychol. 2014. Dec. 8. [pmid: 25486371].
157 Goodman JH, Prager J, Goldstein R, et al. Perinatal Dyadic Psychotherapy for postpartum depression: a randomized controlled pilot trial. Arch Womens Ment Health. 2014. Dec. 20. [pmid: 25522664].
158 Yazdy MM, Mitchell AA, Louik C, et al. Use of selective serotonin-reuptake inhibitors during pregnancy and the risk of clubfoot. Epidemiology. Nov. 2014;25(6):859-65. [pmid: 25171134].
159 Louik C, Kerr S, Mitchell AA. First-trimester exposure to bupropion and risk of cardiac malformations. Pharmacoepidemiol Drug Saf. Oct. 2014;23(10):1066-75. [pmid: 24920293].
160 O'Mahen H, Himle JA, Fedock G, et al. A pilot randomized controlled trial of cognitive behavioral therapy for perinatal depression adapted for women with low incomes. Depress Anxiety. Jul. 2013;30(7):679-87. [pmid: 23319454].
161 Callahan CM, Hendrie HC, Dittus RS, et al. Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. Aug. 1994;42(8):839-46. [pmid: 8046193].
162 Williams J, Mulrow CD, Kroenke K. Case-finding for depression in primary care: A randomized trial. Am J Med. 1999;106(1):36-43. [pmid: 10320115].
163 Wells KB, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: A randomized controlled trial. JAMA. 2000;283(2):212-20. [pmid: 10634337].
164 Whooley M, Stone B. Randomized trial of case-finding for depression in elderly primary care patients. J Gen Intern Med. 2000;15(5):293-300. [pmid: 10840264].
165 Jarjoura D, Polen A, Baum E, et al. Effectiveness of screening and treatment for depression in ambulatory indigent patients. J Gen Intern Med. 2004;19(1):78-84. [pmid: 14748864].
166 van der Weele GM, de Waal MW, van den Hout WB, et al. Effects of a stepped-care intervention programme among older subjects who screened positive for depressive symptoms in general practice: the PROMODE randomised controlled trial. Age Ageing. Jul. 2012;41(4):482-8. [pmid: 22427507].
167 Bijl D, van Marwijk HWJ, Ader HJ, et al. A randomised controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice - primary and secondary outcomes of the West Friesland Study. Diemen. College Voor Zortgverskeringen. 2003. PMID: None.
168 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. Lawrence Earlbaum Associates. 1988. PMID: None.
169 Ban L, Tata LJ, West J, et al. Live and non-live pregnancy outcomes among women with depression and anxiety: a population-based study. PLOS ONE. 2012;7(8):e43462. [pmid: 22937052].
170 Nakhai-Pour HR, Broy P, Berard A. Use of antidepressants during pregnancy and the risk of spontaneous abortion. CMAJ. Jul. 13. 2010;182(10):1031-7. [pmid: 20513781].
171 Yawn BP, Bertram S, Kurland M, et al. Repeated depression screening during the first postpartum year. Ann Fam Med. May. 2015;13(3):228-34. [pmid: 25964400].
172 Farr SL, Dietz PM, O'Hara MW, et al. Postpartum anxiety and comorbid depression in a population-based sample of women. J Womens Health (Larchmt). Feb. 2014;23(2):120-8. [pmid: 24160774].
173 Guico-Pabia CJ, Fayyad RS, Soares CN. Assessing the relationship between functional impairment/recovery and depression severity: a pooled analysis. Int Clin Psychopharmacol. Jan. 2012;27(1):1-7. [pmid: 21971533].
174 Sockol LE, Epperson CN, Barber JP. A meta-analysis of treatments for perinatal depression. Clin Psychol Rev. 2011;31(5):839-49. [pmid: 21545782].
175 Howard LM, Molyneaux E, Dennis CL, et al. Non-psychotic mental disorders in the perinatal period. Lancet. Nov. 15. 2014;384(9956):1775-88. [pmid: 25455248].
176 Blanco C, Olfson M, Goodwin RD, et al. Generalizability of clinical trial results for major depression to community samples: results from the National Epidemiologic Survey on Alcohol and Related Conditions. J Clin Psychiatry. Aug. 2008;69(8):1276-80. [pmid: 18557666].
177 Wisniewski SR, Rush AJ, Nierenberg AA, et al. Can phase III trial results of antidepressant medications be generalized to clinical practice? A STAR*D report. Am J Psychiatry. May. 2009;166(5):599-607. [pmid: 19339358].
178 Cuijpers P, van SA, Bohlmeijer E, et al. The effects of psychotherapy for adult depression are overestimated: a meta-analysis of study quality and effect size. Psychol Med. Feb. 2010;40(2):211-23. [pmid: 19490745].
179 Cuijpers P, Smit F, Bohlmeijer E, et al. Efficacy of cognitive-behavioural therapy and other psychological treatments for adult depression: meta-analytic study of publication bias. Br J Psychiatry. Mar. 2010;196(3):173-8. [pmid: 20194536].
180 Niemeyer H, Musch J, Pietrowsky R. Publication bias in meta-analyses of the efficacy of psychotherapeutic interventions for depression. J Consult Clin Psychol. Feb. 2013;81(1):58-74. [pmid: 23244368].
181 Cuijpers P, van SA, Warmerdam L, et al. Characteristics of effective psychological treatments of depression: a metaregression analysis. Psychother Res. Mar. 2008;18(2):225-36. [pmid: 18815968].
182 Reefhuis J, Devine O, Friedman JM, et al. Specific SSRIs and birth defects: bayesian analysis to interpret new data in the context of previous reports. BMJ. 2015;351:h3190. [pmid: 26156519].
183 Dennis CL, Chung-Lee L. Postpartum depression help-seeking barriers and maternal treatment preferences: a qualitative systematic review. Birth. Dec. 2006;33(4):323-31. [pmid: 17150072].
184 Sword W, Busser D, Ganann R, et al. Women's care-seeking experiences after referral for postpartum depression. Qual Health Res. Sep. 2008;18(9):1161-73. [pmid: 18689530].
185 Turner KM, Sharp D, Folkes L, et al. Women's views and experiences of antidepressants as a treatment for postnatal depression: a qualitative study. Fam Pract. Dec. 2008;25(6):450-5. [pmid: 18826994].
186 Chabrol H, Teissebre F, Armitage J, et al. Acceptability of psychotherapy and antidepressants for postnatal depression among newly delivered mothers. J Reprod Infant Psychol. 2004;22(1):5-12. PMID: None.
187 Weissman AM, Levy BT, Hartz AJ, et al. Pooled analysis of antidepressant levels in lactating mothers, breast milk, and nursing infants. Am J Psychiatry. Jun. 2004;161(6):1066-78. [pmid: 15169695].
188 O'Connor EA, Whitlock EP, Beil TL, et al. Screening for depression in adult patients in primary care settings: a systematic evidence review. Ann Intern Med. Dec. 1. 2009;151(11):793-803. [pmid: 19949145].
189 Gartlehner G, Hansen RA, Reichenpfader U, et al. Drug Class Review: Second-Generation Antidepressants: Final Update 5. 2011. [pmid: 21595099].
190 Ferguson JM. SSRI Antidepressant Medications: Adverse Effects and Tolerability. Prim Care Companion J Clin Psychiatry. Feb. 2001;3(1):22-7. [pmid: 15014625].
191 Renoir T. Selective serotonin reuptake inhibitor antidepressant treatment discontinuation syndrome: a review of the clinical evidence and the possible mechanisms involved. Front Pharmacol. 2013;4:45. [pmid: 23596418].
192 Walker LO, Im EO, Tyler DO. Maternal health needs and interest in screening for depression and health behaviors during pediatric visits. J Pediatr Health Care. Jul. 2013;27(4):267-77. [pmid: 22240267].
193 Gemmill AW, Leigh B, Ericksen J, et al. A survey of the clinical acceptability of screening for postnatal depression in depressed and non-depressed women. BMC Public Health. 2006;6:211. [pmid: 16914061].
194 Buist A, Condon J, Brooks J, et al. Acceptability of routine screening for perinatal depression. J Affect Disord. Jul. 2006;93(1-3):233-7. [pmid: 16647761].
195 Shakespeare J, Blake F, Garcia J. A qualitative study of the acceptability of routine screening of postnatal women using the Edinburgh Postnatal Depression Scale. Br J Gen Pract. Aug. 2003;53(493):614-9. [pmid: 14601337].
196 Scope A, Booth A, Sutcliffe P. Women's perceptions and experiences of group cognitive behaviour therapy and other group interventions for postnatal depression: a qualitative synthesis. J Adv Nurs. 2012;68(9):1909-19. [pmid: 22384864].
197 Boath E, Bradley E, Henshaw C. Women's views of antidepressants in the treatment of postnatal depression. J Psychosom Obstet Gynaecol. Sep. 2004;25(3-4):221-33. [pmid: 15715021].
198 Kozhimannil KB, Adams AS, Soumerai SB, et al. New Jersey's efforts to improve postpartum depression care did not change treatment patterns for women on medicaid. Health Aff (Millwood). Feb. 2011;30(2):293-301. [pmid: 21289351].
199 Armstrong S, Small R. Screening for postnatal depression: not a simple task. Aust N Z J Public Health. Feb. 2007;31(1):57-61. [pmid: 17333610].
200 Georgiopoulos AM, Bryan TL, Wollan P, et al. Routine screening for postpartum depression. J Fam Pract. Feb. 2001;50(2):117-22. [pmid: 11219558].
201 Olson AL, Dietrich AJ, Prazar G, et al. Brief maternal depression screening at well-child visits. Pediatrics. Jul. 2006;118(1):207-16. [pmid: 16818567].
202 Yawn BP, Olson AL, Bertram S, et al. Postpartum Depression: Screening, Diagnosis, and Management Programs 2000 through 2010. Depress Res Treat. 2012;2012:363964. [pmid: 22900157].
203 Conner KO, Copeland VC, Grote NK, et al. Mental health treatment seeking among older adults with depression: the impact of stigma and race. Am J Geriatr Psychiatry. Jun. 2010;18(6):531-43. [pmid: 20220602].
204 Sirey JA, Franklin AJ, McKenzie SE, et al. Race, stigma, and mental health referrals among clients of aging services who screened positive for depression. Psychiatr Serv. Apr. 1. 2014;65(4):537-40. [pmid: 24687104].
205 Hall CA, Reynolds-Iii CF. Late-life depression in the primary care setting: challenges, collaborative care, and prevention. Maturitas. Oct. 2014;79(2):147-52. [pmid: 24996484].
206 Raue PJ, Weinberger MI, Sirey JA, et al. Preferences for depression treatment among elderly home health care patients. Psychiatr Serv. May. 2011;62(5):532-7. [pmid: 21532080].
207 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. [pmid: 17302651].
208 Turner EH, Rosenthal R. Efficacy of antidepressants. BMJ. Mar. 8. 2008;336(7643):516-7. [pmid: 18319297].
209 Linde K, Kriston L, Rucker G, et al. Efficacy and acceptability of pharmacological treatments for depressive disorders in primary care: systematic review and network meta-analysis. Ann Fam Med. Jan. 2015;13(1):69-79. [pmid: 25583895].
210 Linde K, Sigterman K, Kriston L, et al. Effectiveness of psychological treatments for depressive disorders in primary care: systematic review and meta-analysis. Ann Fam Med. Jan. 2015;13(1):56-68. [pmid: 25583894].
211 Levesque DA, Marter DF, Schneider RJ, et al. Randomized trial of a computer-tailored intervention for patients with depression. Am J Health Promot. 2011;26(2):77-89. [pmid: 22040388].
212 Kilbourne AM, Li D, Lai Z, et al. Pilot randomized trial of a cross-diagnosis collaborative care program for patients with mood disorders. Depression & Anxiety. Feb. 2013;30(2):116-22. [pmid: 23077119].
213 Schulberg HC, Block MR, Madonia MJ, et al. Treating major depression in primary care practice. Eight-month clinical outcomes. Arch Gen Psychiatry. Oct. 1996;53(10):913-9. [pmid: 8857868].
214 Lang AJ, Norman GJ, Casmar PV. A randomized trial of a brief mental health intervention for primary care. J Consult Clin Psychol. 2006;74(6):1173-9. [pmid: 17154746].
215 Alexopoulos GS, Reynolds CF III, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. Aug. 2009;166(8):882-90. [pmid: 19528195].
216 Simpson S, Corney R, Fitzgerald P, et al. A randomized controlled trial to evaluate the effectiveness and cost-effectiveness of psychodynamic counselling for general practice patients with chronic depression. Psychol Med. Feb. 2003;33(2):229-39. [pmid: 12622302].
217 Schreuders B, van MH, Smit J, et al. Primary care patients with mental health problems: outcome of a randomised clinical trial. Br J Gen Pract. Nov. 2007;57(544):886-91. [pmid: 17976289].
218 Seekles W, van SA, Beekman A, et al. Effectiveness of guided self-help for depression and anxiety disorders in primary care: a pragmatic randomized controlled trial. Psychiatry Res. May. 15. 2011;187(1-2):113-20. [pmid: 21145112].
219 Casañas R, Catalán R, Val JL, et al. Effectiveness of a psycho-educational group program for major depression in primary care: a randomized controlled trial. BMC Psychiatry. 2012;12:230. [pmid: 23249399].
220 Berghofer A, Hartwich A, Bauer M, et al. Efficacy of a systematic depression management program in high utilizers of primary care: a randomized trial. BMC Health Serv Res. 2012;12:298. [pmid: 22943609].
221 Huijbregts KM, de Jong FJ, van Marwijk HW, et al. A target-driven collaborative care model for Major Depressive Disorder is effective in primary care in the Netherlands. A randomized clinical trial from the depression initiative. J Affect Disord. Apr. 25. 2013;146(3):328-37. [pmid: 23068021].
222 Menchetti M, Sighinolfi C, Di M V, et al. Effectiveness of collaborative care for depression in Italy. A randomized controlled trial. Gen Hosp Psychiatry. Nov. 2013;35(6):579-86. [pmid: 23969143].
223 van Schaik A, van Marwijk H, Ader H, et al. Interpersonal psychotherapy for elderly patients in primary care. Am J Geriatr Psychiatry. Sep. 2006;14(9):777-86. [pmid: 16943174].
224 Serfaty MA, Haworth D, Blanchard M, et al. Arch Gen Psychiatry. 2009;66(12):1332-40. [pmid: 19996038].
225 van Marwijk HW, Ader H, de HM, et al. Primary care management of major depression in patients aged > or =55 years: outcome of a randomised clinical trial. Br J Gen Pract. Oct. 2008;58(555):680-II. [pmid: 18826778].
226 Lam CL, Fong DY, Chin WY, et al. Clinical effectiveness of individual cognitive behavioral therapy for depressed older people in primary care: a randomized controlled trial. Int J Geriatr Psychiatry. Oct. 2010;25(10):968-80. [pmid: 20033901].
227 King M, Davidson O, Taylor F, et al. Effectiveness of teaching general practitioners skills in brief cognitive behaviour therapy to treat patients with depression: randomised controlled trial. BMJ. Apr. 20. 2002;324(7343):947-50. [pmid: 11964340].
228 Brodaty H, Andrews G. Brief psychotherapy in family practice. A controlled prospective intervention trial. Br J Psychiatry. Jul. 1983;143:11-9. [pmid: 6349737].
229 Seekles W, van SA, Beekman A, et al. Stepped care treatment for depression and anxiety in primary care. a randomized controlled trial. Trials. 2011;12:171. [pmid: 21736720].
230 Serfaty MA, Haworth D, Blanchard M, et al. Clinical effectiveness of individual cognitive behavioral therapy for depressed older people in primary care: a randomized controlled trial. Archives of General Psychiatry. 2009;66:1332-40. [pmid: 19996038].
231 Lam CL, Fong DY, Chin WY, et al. Brief problem-solving treatment in primary care (PST-PC) was not more effective than placebo for elderly patients screened positive of psychological problems. Int J Geriatr Psychiatry. 2010;25:968-80. [pmid: 20033901].
232 Manea L, Gilbody S, McMillan D. Optimal cut-off score for diagnosing depression with the Patient Health Questionnaire (PHQ-9): a meta-analysis. CMAJ: Canadian Medical Association Journal. 2012;184(3):E191-E196. [pmid: 22184363].
233 Thombs BD, Benedetti A, Kloda LA, et al. The diagnostic accuracy of the Patient Health Questionnaire-2 (PHQ-2), Patient Health Questionnaire-8 (PHQ-8), and Patient Health Questionnaire-9 (PHQ-9) for detecting major depression: protocol for a systematic review and individual patient data meta-analyses. Syst Rev. 2014;3:124. [pmid: 25348422].
234 Mitchell AJ, Bird V, Rizzo M, et al. Diagnostic validity and added value of the Geriatric Depression Scale for depression in primary care: a meta-analysis of GDS30 and GDS15. J Affect Disord. Sep. 2010;125(1-3):10-7. [pmid: 19800132].
235 Vohringer PA, Jimenez MI, Igor MA, et al. Detecting mood disorder in resource-limited primary care settings: comparison of a self-administered screening tool to general practitioner assessment. J Med Screen. 2013;20(3):118-24. [pmid: 24080916].
236 Katzman MA, Bleau P, Blier P, et al. Canadian clinical practice guidelines for the management of anxiety, posttraumatic stress and obsessive-compulsive disorders. BMC Psychiatry. Suppl 1. 2014;14:S1. [pmid: 25081580].
237 Wilson H, Mannix S, Oko-Osi H, et al. The mpact of medication on health-related quality of life in patients with generalized anxiety disorder. CNS Drugs. 2014. Dec. 17. [pmid: 25516469].
238 Ravindran LN, Stein MB. The pharmacologic treatment of anxiety disorders: a review of progress. J Clin Psychiatry. Jul. 2010;71(7):839-54. [pmid: 20667290].
239 Samuels S, Abrams R, Shengelia R, et al. Integration of geriatric mental health screening into a primary care practice: a patient satisfaction survey. Int J Geriatr Psychiatry. 2014. Jul. 30. [pmid: 25132003].
240 Brown RL, Moberg PD, Allen JB, et al. A team approach to systematic behavioral screening and intervention. Am J Manag Care. 2014;20(4):e113-e121. [pmid: 24884956].
241 Yackel EE, McKennan MS, Fox-Deise A. A nurse-facilitated depression screening program in an Army primary care clinic: an evidence-based project. Nurs Res. Jan. 2010;59(1 Suppl):S58-S65. [pmid: 20010279].
242 Casado BL, Quijano LM, Stanley MA, et al. Healthy IDEAS: implementation of a depression program through community-based case management. Gerontologist. Dec. 2008;48(6):828-38. [pmid: 19139256].
243 Romera I, Montejo AL, Aragones E, et al. Systematic depression screening in high-risk patients attending primary care: a pragmatic cluster-randomized trial. BMC Psychiatry. 2013;13:83. [pmid: 23497463].
244 Thombs BD, Ziegelstein RC. Depression screening in primary care: why the Canadian task force on preventive health care did the right thing. [Review]. Can J Psychiatry. Dec. 2013;58(12):692-6. [pmid: 24331289].
245 Thombs BD, Ziegelstein RC, Roseman M, et al. There are no randomized controlled trials that support the United States Preventive Services Task Force guideline on screening for depression in primary care: a systematic review. BMC Med. 2014;12:13. [pmid: 24472580].
246 Thombs BD, Coyne JC, Cuijpers P, et al. Rethinking recommendations for screening for depression in primary care. [References]. CMAJ. 2012;184(4):413-8. [pmid: 21930744].
247 National Institute for Health and Clinical Excellence. Depression in adults: recognition and management. London. NICE. 2013. PMID: None.
248 Joffres M, Jaramillo A, Dickinson J, et al. Recommendations on screening for depression in adults. CMAJ. Jun. 11. 2013;185(9):775-82. [pmid: 23670157].
249 Thombs BD, Stewart DE. Depression screening in pregnancy and postpartum: how close are we?. J Psychosom Res. Sep. 2014;77(3):244-5. [pmid: 25149036].
250 Fournier JC, DeRubeis RJ, Hollon SD, et al. Antidepressant drug effects and depression severity: a patient-level meta-analysis. JAMA. Jan. 6. 2010;303(1):47-53. [pmid: 20051569].
251 Kirsch I, Deacon BJ, Huedo-Medina TB, et al. Initial severity and antidepressant benefits: a meta-analysis of data submitted to the Food and Drug Administration. PLoS Med. Feb. 2008;5(2):e45. [pmid: 18303940].
252 Driessen E, Cuijpers P, Hollon SD, et al. Does pretreatment severity moderate the efficacy of psychological treatment of adult outpatient depression? A meta-analysis. J Consult Clin Psychol. Oct. 2010;78(5):668-80. [pmid: 20873902].
253 Depression in adults. London. National Institute for Health and Care Excellence. 2009. PMID: None.
254 Kasckow J, Klaus J, Morse J, et al. Using problem solving therapy to treat veterans with subsyndromal depression: a pilot study. Int J Geriatr Psychiatry. May. 1. 2014;29(12):1255-61. [pmid: 24789736].
255 Lynch DJ, Tamburrino MB, Nagel R. Telephone counseling for patients with minor depression: preliminary findings in a family practice setting. J Fam Pract. Mar. 1997;44(3):293-8. [pmid: 9071250].
256 Williams JW Jr., Barrett J, Oxman T, et al. Treatment of dysthymia and minor depression in primary care: A randomized controlled trial in older adults. JAMA. Sep. 27. 2000;284(12):1519-26. [pmid: 11000645].
257 Lynch D, Tamburrino M, Nagel R, et al. Telephone-based treatment for family practice patients with mild depression. Psychol Rep. Jun. 2004;94(3 Pt 1):785-92. [pmid: 15217028].
258 Hegerl U, Hautzinger M, Mergl R, et al. Effects of pharmacotherapy and psychotherapy in depressed primary-care patients: a randomized, controlled trial including a patients' choice arm. Int J Neuropsychopharmacol. Feb. 2010;13(1):31-44. [pmid: 19341510].
259 Cuijpers P, van SA, van SA, et al. Psychological treatment of depression in primary care: a meta-analysis. Br J Gen Pract. Feb. 2009;59(559):e51-e60. [pmid: 19192368].
260 Cerimele JM, Vanderlip ER, Croicu CA, et al. Presenting symptoms of women with depression in an obstetrics and gynecology setting. Obstet Gynecol. Aug. 2013;122(2 Pt 1):313-8. [pmid: 23969800].
261 Ghio L, Vaggi M, Amore M, et al. Unmet needs and research challenges for late-life mood disorders. Aging Clin Exp Res. Sep. 30. 2013;26(2):101-14. [pmid: 24078460].
262 American Academy of Family Physicians. Clinical preventive services: depression, adults. Leawood, KS. American Academy of Family Physicians. 2010. http://www.aafp.org/patient-care/clinical-recommendations/all/depression.html. September 11, 2013. PMID: None.
263 Earls MF. Incorporating recognition and management of perinatal and postpartum depression into pediatric practice. Pediatrics. Nov. 2010;126(5):1032-9. [pmid: 20974776].
264 Nimalasuriya K, Compton MT, Guillory VJ. Screening adults for depression in primary care: A position statement of the American College of Preventive Medicine. J Fam Pract. Oct. 2009;58(10):535-8. [pmid: 19874732].
265 Committee opinion no. 453: Screening for depression during and after pregnancy. Obstet Gynecol. Feb. 2010;115(2 Pt 1):394-5. [pmid: 20093921].
266 Mitchell J, Trangle M, Degnan B, et al. Adult depression in primary care. Bloomington, MN. Institute for Clinical Systems Improvement. 2013. PMID: None.
267 Recommendation from the community preventive services task force for use of collaborative care for the management of depressive disorders. Am J Prev Med. May. 2012;42(5):521-4. [pmid: 22516494].
268 Bobo WV, Wollan P, Lewis G, et al. Depressive symptoms and access to mental health care in women screened for postpartum depression who lose health insurance coverage after delivery: findings from the Translating Research into Practice for Postpartum Depression (TRIPPD) effectiveness study. Mayo Clin Proc. Sep. 2014;89(9):1220-8. [pmid: 25091871].
269 Morrell CJ, Slade P, Warner R, et al. Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ. 2009;338:a3045. [pmid: 19147636].
270 Beattie-Clarke P. Validation of two postpartum screening scales in a sample of Saskatchewan First Nations and Metis women. Regina, Canada. University of Regina. 2003. PMID: None.
271 Cox JL, Murray D, Chapman G. A controlled study of the onset, duration and prevalence of postnatal depression. Br J Psychiatry. Jul. 1993;163:27-31. [pmid: 8353695].
272 Elliott SA, Leverton TJ, Sanjack M, et al. Promoting mental health after childbirth: a controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. Sep. 2000;39(Pt 3):223-41. [pmid: 11033746].
273 Murray L, Cooper PJ, Wilson A, et al. Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression: 2. Impact on the mother-child relationship and child outcome. Br J Psychiatry. May. 2003;182:420-7. [pmid: 12724245].
274 Ammerman RT, Putnam FW, Altaye M, et al. Treatment of depressed mothers in home visiting: impact on psychological distress and social functioning. Child Abuse Negl. Aug. 2013;37(8):544-54. [pmid: 23623623].
275 Ammerman RT, Putnam FW, Stevens J, et al. An open trial of in-home CBT for depressed mothers in home visitation. Matern Child Health J. 2011;15(8):1333-41. [pmid: 20936338].
276 Ammerman RT, Altaye M, Putnam FW, et al. Depression improvement and parenting in low-income mothers in home visiting. Arch Womens Ment Health. 2014. Nov. 5. [pmid: 25369906].
277 Ammerman RT, Peugh JL, Teeters AR, et al. Child maltreatment history and response to CBT treatment in depressed mothers participating in home visiting. J Interpers Violence. 2014. Nov. 13. [pmid: 25395221].
278 Jordan AE, Jackson GL, Deardorff D, et al. Serotonin reuptake inhibitor use in pregnancy and the neonatal behavioral syndrome. J Matern Fetal Neonatal Med. Oct. 2008;21(10):745-51. [pmid: 19012191].
279 Rost K, Nutting PA, Smith J, et al. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. Gen Hosp Psychiatry. 2000;22(2):66-77. [pmid: 10822094].
280 Rost K, Nutting P, Smith JL, et al. Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. Oct. 26. 2002;325(7370):934. [pmid: 12399343].
281 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Arch Gen Psychiatry. Jul. 2001;58(7):696-703. [pmid: 11448378].
282 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: Results of a group-level randomized controlled trial. Arch Gen Psychiatry. 2004;61(4):378-86. [pmid: 15066896].
283 Bosmans J, de Bruijne M, van Hout H, et al. J Gen Intern Med. 2006;21(10):1020-6. [pmid: 16836625].
284 Arroll B, Elley CR, Fishman T, et al. Antidepressants versus placebo for depression in primary care. Cochrane Database of Systematic Reviews. 2009;(3). CD007954. [pmid: 19588448].
285 Kroenke K, Spitzer RL. The PHQ-9: A New Depression Diagnostic and Severity Measure. Psychiatric Annals. 2002;32(9). PMID: None.
286 Kroenke K, Spitzer RL, Williams JB. The PHQ-9: validity of a brief depression severity measure. J Gen Intern Med. Sep. 2001;16(9):606-13. PMID:. [pii: jgi01114]. [pmid: 11556941].
287 Thombs BD, Arthurs E, El-Baalbaki G, et al. Risk of bias from inclusion of patients who already have diagnosis of or are undergoing treatment for depression in diagnostic accuracy studies of screening tools for depression: systematic review. [Review]. BMJ. 2011;343:d4825. [pmid: 21852353].
288 Izal M, Montorio I, Nuevo R, et al. Optimising the diagnostic performance of the Geriatric Depression Scale. Psychiatry Res. Jun. 30. 2010;178(1):142-6. [pmid: 20452060].
289 Wancata J, Alexandrowicz R, Marquart B, et al. The criterion validity of the Geriatric Depression Scale: a systematic review. Acta Psychiatr Scand. Dec. 2006;114(6):398-410. PMID:. [pii: ACP888]. [doi: 10.1111/j.1600-0447.2006.00888.x]. [pmid: 17087788].
290 Kingston D, Austin MP, Hegadoren K, et al. Study protocol for a randomized, controlled, superiority trial comparing the clinical and cost- effectiveness of integrated online mental health assessment-referral-care in pregnancy to usual prenatal care on prenatal and postnatal mental health and infant health and development: the Integrated Maternal Psychosocial Assessment to Care Trial (IMPACT). Trials. [Electronic Resource]. 2014;15:72. [pmid: 24597683].
291 Meijer JL, Bockting CL, Beijers C, et al. PRegnancy Outcomes after a Maternity Intervention for Stressful EmotionS (PROMISES): study protocol for a randomised controlled trial. Trials. 2011;12:157. [pmid: 21689394].
292 Dennis CL, Ravitz P, Grigoriadis S, et al. The effect of telephone-based interpersonal psychotherapy for the treatment of postpartum depression: study protocol for a randomized controlled trial. Trials. [Electronic Resource]. 2012;13:38. [pmid: 22515528].
293 Flanagan T, Mosen S, White H, et al. Computerized skills-based psychotherapy for postpartum depression versus treatment as usual. Arch Womens Ment Health. 2011;14:S65-S66. PMID: None.
294 Katz KS, Gantz M, Rodan M, et al. Depression reduction and adherence to treatment in pregnant African American women. Pediatric Academic Society. 2009. PMID: None.
295 Joseph JG, El-Mohandes AA, Kiely M, et al. Reducing psychosocial and behavioral pregnancy risk factors: results of a randomized clinical trial among high-risk pregnant african american women. Am J Public Health. 2009;99:1053-61. [pmid: 19372532].
296 Kammerer M. Keeping well: only cognitive behavior therpay for pregnant women with depressive symptoms. London. Imperial College London. 2014. https://clinicaltrials.gov/ct2/show/NCT01909167?term=postpartum+depression+treatment&rank=5 (https://clinicaltrials.gov/ct2/show/NCT01909167?term=).
297 Lenze S. Mommy-baby treatment for perinatal depression. St. Louis. Washing University. 2014. https://clinicaltrials.gov/ct2/show/NCT01744041?term=postpartum+depression+treatment&rank=4 (https://clinicaltrials.gov/ct2/show/NCT01744041?term=).
298 Monk C. Effectiveness of group interpersonal psychotherapy in treating women with prenatal depression. New York. New York State Psychiatric Institute. 2011. https://clinicaltrials.gov/ct2/show/NCT00633178?term=postpartum+depression+treatment&rank=8 (https://clinicaltrials.gov/ct2/show/NCT00633178?term=). PMID: None.
299 O'Mahen H, Wilkinson E, Woodford J, et al. The netmums project: A randomized controlled trial of online behavioural activation for postnatal depression. Arch Womens Ment Health. 2013;16:S64. PMID: None.
300 Posmontier B, Stuart S, Neugebauer R, et al. Multidisciplinary model of nurse midwife administered psychotherapy for postpartum depression. Arch Womens Ment Health. 2013;16:S7. PMID: None.
301 Wisner K. Identification and therapy of postpartum depression. clinicaltrials. 2013. PMID: None.
302 Sadavoy J. Screening for mental health concerns for at-risk community living Chinese seniors. Washington, D.C. ClinicalTrials.gov. 2007. http://clinicaltrials.gov/show/NCT00433238. September 13, 2013. PMID: None.