# Discussion

## Summary of Evidence

Data related to pregnant and postpartum populations primarily targeted postpartum women, except for harms of antidepressants, which was usually limited to antidepressant use during pregnancy (Table 22). We found evidence suggesting that programs involving depression screening of pregnant and postpartum women, with or without additional treatment-related supports, reduce depression prevalence and increase remission or treatment response. Most included trials, however, included additional treatment elements beyond screening. Further, the English-language version of the EPDS has acceptable sensitivity and specificity for detecting postpartum MDD. This evidence also showed that psychotherapy can help reduce depressive symptoms in women with postpartum depression. Data was insufficient on benefits of antidepressant use in pregnant and postpartum women. Second-generation antidepressant use during pregnancy may be associated with increased risk of some serious harms. Important limitations to the evidence, however, were noted for all KQs related to pregnant and postpartum women, including a relatively small number of studies, few trials with good applicability to primary care in the United States, and many studies with very small study sizes, as well as other concerns. Information on harms was almost entirely limited to observational studies. Effect sizes in trials of treatment benefit may slightly overestimate the effect sizes found in typical primary care populations.

Table 22 Summary of Evidence in Pregnant and Postpartum Women

Key Question | No. of Studies, No. of Observations (n), Design | Summary of Findings | Consistency/Precision | Reporting Bias | Overall Study Quality | Body of Evidence Limitations | Applicability
Key Question 1 Benefits of screening | k=6 n=11,869 5 RCTs, 1 CCT | Trials reported approximately 20% to 60% reductions in prevalence of depression with depression screening (+/- additional components), and approximately 20-30% increases in remission or treatment response in those with depressive symptoms at baseline. Two interventions that focused on screening without additional supports or counseling showed reductions in depression in the near-term (up to 4 months); 4 interventions providing additional provider supports or counseling consistently showed improvement in depression outcomes; one of these also reported numerous quality of life outcomes that largely showed improvement with screening + CBT or person-centered counseling | Reasonably consistent, Imprecise | None detected | Fair | Limited number of studies, wide range of intervention approaches with no replication of any interventions, minimal descriptions of samples (e.g., age, race/ethnicity, previous depression); minimal information on the role of screening in the beneficial results | All conducted in maternal health or other primary care settings, however only one conducted in the United States, three involved home visits, which are rarely used in the United States.
Key Question 2 Performance characteristics of the EPDS | k=23 (k=8, English language version) n= 5,398 (n=1,905, English language version) Studies reporting performance characteristics | For detecting MDD, sensitivity of the English language EPDS likely approximately 0.80 and specificity likely approximately 0.90 with a cutoff of 13 in the first 3 months postpartum. In a population with 10% MDD prevalence, PPV is estimated at 47% for detecting MDD. Using a cutoff of 10 for detecting depressive disorders, including minor depression: sensitivity is estimated between 0.63 to 0.84, specificity likely between 0.80 and 0.90. Positive predictive values were 43% and 50% at these sensitivity levels and specificity of 0.85 in a population with 15% prevalence depressive disorders.. | English version: Cutoff 13: Reasonably consistent for detecting MDD, reasonably precise Cutoff 10: Somewhat inconsistent for detecting depressive disorders, imprecise | Possible; some studies reported optimal cutoff, but most English language version studies reported commonly used cutoffs of 10 and 13. | Fair | Limited data on English-language version, much of it collected 15-25 years ago, small ns. Training and fidelity associated with the reference standard were rarely reported, two English-version studies did not report the interval between the EPDS and the reference test. | Uncertain, only two of the studies of the English-language version were conducted in the United States. However, study with best applicability reported relatively good performance characteristics.
Key Question 2 Performance characteristics of the PHQ | k=3, n=777 Studies reporting performance characteristics | Sensitivity and specificity were fairly wide-ranging over different versions of the PHQ, scoring methods, cut-offs, and comparator (MDD vs major or minor depression). Sensitivities ranged from 0.62 to 1.00 and specificities ranged from 0.59 to 0.91 | Inconsistent, imprecise | Possible, 1 of 3 reported optimal cut-points based on receiver operating curve | Fair | Limited number of studies with no replication for any specific version, scoring method, cutoff, and comparator; small samples resulting in 5 or fewer false negatives | 2 of 3 conducted in the United States, within past 5 years, including 18-20% Black participants, but other racial/ethnic minority groups not represented
Key Question 3 Harms of Screening | Reported harms: k=1, n=462 | One of the included studies reported no adverse events. We found no additional data addressing harms of screening beyond trials of screening's benefit. No evidence of paradoxical deleterious effects. | NA | NA | NA | No evidence directly examined harms. | NA
Key Question 4 Benefits of Treatment | k=18 n=1,638 17 RCTs, 1 CCT | CBT and related therapeutic approaches were associated with an increased likelihood of remission (RR, 1.34 [95% CI 1.19 to 1.50]) in the short term (<8 months) and reduced symptom severity in 10 trials. Larger effects were generally associated with greater contact hours, however contact hours was confounded with other important sources of heterogeneity. Data were insufficient to evaluate other treatment approaches, including stepped care (k=1) and fluoxetine (k=1). | CBT: Reasonably consistent, Reasonably precise for remission/response | Possible; variety of definitions used for remission, possibility that definition with largest effect was presented in some studies. | Fair | Mostly small studies with one or more methodological limitations | Limited to studies of screen-detected depression conducted in or recruited from primary care, but only 3 conducted in the United States with little information about population characteristics, particularly racial/ethnic background.
Key Question 5 Harms of Treatment (Behaviorally-based) | k=0 | None of the included studies reported on adverse events or other specific harms. We found no additional data addressing harms of screening beyond trials of screening's benefit. No evidence of paradoxical deleterious effects. | NA | N NA | NA | No evidence directly examined harms. | NA
Key Question 5 Harms of Treatment (antidepressants) | k=14 1 SER 1 RCT 9 large cohort studies 3 large case-control study N=4,759,822 (excluding studies in the SER) | 2^nd^ gen. AD were associated w/ an increased risk of some serious AEs. Positive associations were reported between AD & harms for preeclampsia (venlafaxine), postpartum hemorrhage (SSRIs [≥60d exposure], SNRIs), miscarriage (SSRIs 1^st^ tri.; SNRIs), perinatal death (SSRIs); preterm birth (SSRIs in 1^st^ and 2^nd^ tri., SNRIs), small for gestational age (SSRIs), infant seizures (SSRIs), serotonin withdrawal syndrome (SSRIs, SNRIs), neonatal respiratory distress (SSRIs), pulmonary HTN (SSRIs, particularly late in pregnancy), major malformations (fluoxetine, paroxetine, and escitalopram), and cardiac malformations (paroxetine, venlafaxine, bupropion). Negative studies are not summarized here, but for most outcomes w/ studies showing a positive association, other studies showed no association. | Consistent direction of effect for most outcomes Reasonably precise. | Unlikely, most included limited number of outcomes and used medical records to ascertain exposure and outcomes. | Good | No RCTs; only observational evidence, so causality cannot be clearly determined. Many studies compared harms in groups of women with unknown depression status, exaggerating the potential confounding by indication. No data was available to examine harms by dose; some did examine harms by length of exposure. Most used pharmacy fills to examine exposure, but did not verify women were actually taking antidepressants as prescribed. | Only approximately one-third of studies were conducted in the United States, but the majority of the remaining was conducted in Europe, and applicability is likely moderately good.

Abbreviations: AD = antidepressants; AE = adverse effects; CBT = cognitive behavioral therapy; CI = confidence interval; EPC = Evidence-based Practice Center; EPDS = Edinburgh Postnatal Depression Scale; gen = generation; HTN = hypertension; MDD = major depressive disorder; NA = not applicable; PE = preeclampsia; PPH = postpartum hemorrhage; RCT = randomized controlled trial; RDS = respiratory distress; RR = relative risk; SER = systematic evidence review; SGA = small for gestational age; SNRI = selective norepinephrine reuptake inhibitors; SS = serotonin syndrome; SSRI = selective serotonin reuptake inhibitors; tri = trimester; ven = venlafaxine; vs = versus; w/ = with.

In general adult primary care populations, the current review found evidence suggesting that programs that include screening, or screening results feedback, improve the likelihood of symptom reduction or treatment response. This was particularly true for patients with newly-identified depression and when screening was combined with other depression care supports for providers (Table 23). We found insufficient data to determine whether these programs are beneficial when targeted specifically at older adults. It may be reasonable to generalize findings in general adults to older adults, however, given that they were not specifically excluded in many general adult studies and the relative paucity of specific evidence in older adults that is applicable to U.S. primary care.

Table 23 Summary of Evidence in General and Older Adults

Key Question | No. of Studies (k), No. of Observations (n), Design | Summary of Findings | Consistency/Precision | Reporting Bias | Overall Study Quality | Body of Evidence Limitations | Applicability
Key Question 1 Benefits of screening General Adult Population | k=5 RCTs n=2,924 | Screening programs were likely to increase the likelihood of remission and treatment response in general adult populations experiencing depressive symptoms, particularly programs with greater provider supports and those focused on newly- identified depression. Remission or treatment response was increased by approximately 20-80% with screening (+/- additional components), but results were statistically significant in only two of the largest studies with greatest additional supports beyond simple screening results feedback, one of which only found a benefit for those with newly-identified depression. Other studies were smaller and underpowered for statistical significance of even fairly large group differences (e.g., 48% remission in IG vs. 27% in CG). | Reasonably consistent, Imprecise | Possible, some studies reported response to treatment instead of remission, other beneficial outcomes sparsely reported | Fair | Only one trial had an unscreened control group; most trials provided components in addition to screening results feedback so cannot isolate importance of screening component; many studies had small n with limited power and were studied only patients who screened positive (so cannot assess population-based impact assess); Few studies altogether, all conducted 10+ years ago. | All conducted in primary care settings in the United States, with geographic and economic diversity among the studies.
Key Question 1 Benefits of screening Older Adults | k=4 RCTs n=890 | Screening programs were not successful in older adults, and even had a paradoxically negative (but not statistically significant) effect in two studies conducted in The Netherlands. Evidence specific to the United States were limited to two trials, neither or which showed a benefit of screening programs, and neither had substantial added provider supports beyond screening results feedback. | Inconsistent, Imprecise | Same as general adult populations | Fair | Very limited data relevant to the United States, and smaller total n, with conflicting results. | 2 of 4 conducted in The Netherlands, where usual care may be quite different from United States.
Key Question 2 Harms of screening | Reported harms: k=1, n=211 Paradoxical effect: k=1, n=239 | One trial reported that no adverse events were attributable to the intervention in the subset with newly-identified depression. We found no additional data addressing harms of screening beyond trials of screening's benefit; One trial from The Netherlands in older adults showed a non-statistically significant deleterious effect, with questionable applicability to the United States. | NA | NA | Fair | No evidence directly examined harms. | Low

Abbreviations: EPC = Evidence-based Practice Center; NA = not applicable; RCT = randomized controlled trial; vs = versus.

### Pregnant and Postpartum Women

Direct evidence on effects of screening for depression in pregnant and postpartum women is somewhat limited, but suggests that programs that include screening reduce overall depression prevalence and increase likelihood of remission or treatment response by 23 to 30 percent in postpartum women with depression. This evidence base is relatively small, however, including only six trials with relatively short followup, but more than 10,000 women. Most of the research was conducted outside of the United States in health care systems that are very different from those of the United States. For example, several studies on the benefits of screening were conducted as part of home visit programs,100,104,106 which are not typical of the care provided in the United States. These studies also included treatment components beyond screening. Two trials provided minimal additional components beyond screening and showed a benefit for either reduced depression prevalence105 or increased treatment response.107 The most applicable study, conducted in U.S. primary care, included screening results feedback along with care supports, such as treatment guidelines, scripts for monitoring calls from nurses, and patient self-help materials.69 This study reported a 33 percent increase in the likelihood of treatment response in the intervention group among women who screened positive at baseline. A recently published substudy of this trial noted that 13.5 percent of women who did not have elevated depressive symptoms at 4 to 12 weeks postpartum screened positive 6 or 12 months later, suggesting that frequent rescreening may be particularly important for postpartum women.171 We found very little data on harms of screening, and none to suggest that screening could be harmful. A potential harm is that false-positive screening results may lead to unnecessary treatment, and its attendant harms, when careful assessment is not undertaken after a positive screening test. This highlights the importance of provider training in assessment of mental health issues.

Our results are consistent with two recent comprehensive reviews of depression identification in pregnant and postpartum women, which included overlapping, but not identical, evidence bases.89,90 One review concluded that the EPDS had beneficial effects, although it was difficult to disentangle the effects of using an identification strategy from the effects of subsequent interventions provided.90 The other review concluded that screening was associated with modest improvement in depression across a variety of low-intensity interventions.89

The English-language version of the EPDS appears to have acceptable properties for identifying women with MDD. While the range of sensitivity and specificity was quite wide, the largest and most applicable studies reported sensitivity to detect MDD (cutoff of 13) of around 0.80 and specificity of 0.90 or greater, primarily examined in postnatal women. While this body of evidence was fairly large (k=23), only eight studies addressed the English-language version of the EPDS. Likewise, only two of these studies were conducted in the United States. Further, the literature on the English-language version of the EPDS and the PHQ was hampered by small study sizes, usually including fewer than 30 persons who met criteria for MDD. Some of these trials had fewer than 10 cases either overall or for reported subgroups, which resulted in low precision and very few false negatives.101,118,119,130 On the other hand, the broad application of the EPDS with relatively acceptable results in various languages and populations can be seen as reassuring as to its applicability to a diverse U.S. perinatal population. Data on accuracy of the PHQ were limited to only three small studies, with no replication of PHQ version, scoring method, or comparator. Other reviews drew similar conclusions, which included a broader range of screening instruments.89,90 When considering all the translated versions of the EPDS, one group concluded that the EPDS performs reasonably well, with sensitivity for MDD ranging from 0.60 to 0.96 and specificity ranging from 0.45 to 0.97.^90^ This group further noted that while the identification tools that were not specific to pregnant and postpartum women, such as the BDI and HAM-D, may be less sensitive, they are more specific than the EPDS for pregnant and postpartum women. Similarly, the other review concluded that both sensitivity and specificity generally were in the 0.80 to 0.90 range for most screening tests.89

One could argue that sensitivity is more important than specificity for depression screening because depression often co-occurs with other mental health disorders, particularly anxiety-spectrum and substance use disorders. One third of women with postpartum anxiety disorders, for example, also met criteria for depression, based on a large population-based epidemiologic survey.172 The principal components of most behavioral-based treatments were not developed specifically for depression or expected to only benefit persons meeting full diagnostic criteria for MDD. Rather, behavioral-based treatments are well suited to treating a wide range of mental health issues, including anxiety and substance misuse, and are very unlikely to cause harm to persons whose symptoms do not meet criteria for MDD, but who are distressed, overwhelmed, or unhappy nevertheless. Thus, highly sensitive but not specific instruments are likely to identify some women for whom depression is not the primary diagnosis, but who would likely benefit from further evaluation and treatment.

Counseling pregnant and postpartum women with screen-detected depression using CBT or related behavioral-based approaches reduced postpartum depression symptomatology and increased the likelihood of remission over usual care. We found insufficient data to determine whether the use of other treatment modalities was beneficial in either pregnant or postpartum women, including antidepressants. Although most of the studies of CBT and related interventions were conducted outside of the United States, one study conducted in the United States found a benefit of CBT at both 4.5- and 7.5-month followup.131 Another highly applicable U.S.-based study that assessed a stepped-care approach with high-risk, low-income postpartum women found the intervention was not beneficial, although the study was hampered by a very small sample size.136 Additionally, lack of benefit in a stepped-care approach does not provide evidence against expected benefit from provision of effective therapies, such as CBT, to all screen-detected women.

Typically, studies generally reported that the intervention groups improved more than usual care, although both groups improved. Women in the usual care group generally showed improvements on the EPDS of two to six points (on a 30-point scale) compared with 5- to 10-point improvements with CBT or related therapies. One group explored the relationship between depressive symptoms and assessments of functional impairment and emotional well-being.173 It found that a change of three points on the HAM-D (a 52-point scale) was associated with clinically important changes in these other areas. While it is difficult to directly translate this finding to the EPDS, the improvements reported in the intervention groups were very likely to represent clinically important changes, as did changes seen in many of the usual care groups. We could not find information on the availability of CBT in the United States or ease of accessibility. Unfortunately, this treatment is unlikely to be universally accessible. On the other hand, antidepressants, which do not have evidence to support their use in pregnant or postpartum women, are widely available.

Other reviews have also concluded that behavioral-based treatment of depression is beneficial during the postpartum period. They have also reported that data on the use of antidepressants are lacking. These reviews were not limited to studies of women with screen-detected depression.174, 175 For example, based on 27 studies, including open trials, quasirandomized trials, and RCTs of pharmacologic and psychological interventions, one review concluded that women undergoing treatment for postpartum depression showed substantial reductions in depressive symptoms, with an estimated standardized effect size of 0.65, compared with control groups (Hedge's g, 0.65 [95% CI, 0.45 to 0.86]; I^2^=43%; after excluding an outlier with large beneficial effect).174 Symptom levels at posttreatment were generally below cutoffs indicative of clinically important symptoms.174

In addition to the lack of applicability to the United States, some concerns exist about generalizability and overestimation of effect size in the broader depression treatment literature. Some (but not all) of these concerns apply to the trials included in this review. Some researchers have found that generalizability of clinical trial treatment results in general may be reduced by restrictive inclusion and exclusion criteria. In general, most real-world patients (not limited to pregnant and postpartum women) with depression do not meet typical criteria for inclusion in clinical trials.176 In a large observational study of individuals with a major depressive episode, 75.8 percent would have met at least one of the typical exclusion criteria for clinical trials of depression treatment. The criteria that would lead to the greatest number of exclusions include the presence of comorbid nondepressive, nonsubstance-related Axis I disorders (e.g., anxiety disorders) (47.4% of sample) and the duration of the depressive episode (<4 weeks or >2 years; 40.3% of sample).176 This finding was confirmed by the Sequenced Treatment Alternative to Relieve Depression (STAR*D) study of stepped-care treatment for depression in primary care (not limited to peripartum women), which had minimal exclusion criteria. This study found that patients meeting inclusion criteria for typical efficacy trials had shorter average duration of illness and lower rates of family history of substance abuse, prior suicide attempts, and anxious and atypical features.177 The treatment studies included in this review generally excluded women with greatest disease severity, such as history of psychosis, current suicidal ideation, or need for crisis management. Some also excluded women taking psychotropic medications, and a few excluded patients with substance abuse disorders and perinatal complications. The included trials, however, rarely excluded patients for long duration of depression, and none excluded women with any other Axis I disorder. As such, most women with comorbid anxiety disorders, for example, would have been included.

The STAR*D study also found higher response and remission rates in the subgroup that met typical trial inclusion criteria (even after controlling for baseline factors),177 suggesting trial evidence may overestimate effects of treatment. Further, a review of psychotherapy trials found that high-quality studies consistently found smaller effects than lower-quality trials, even after controlling for a number of study characteristics (including control group type). This finding is consistent with our finding of relatively smaller effects in good-quality studies.178 Indeed, the two good-quality studies included for this KQ had two of the three smallest effect sizes for remission/response in the CBT group. One of these trials did show a statistically significant benefit,145 which was very similar to the pooled estimate. While the other trial did not show a benefit of CBT at 4.5, 9, or 18 months, it did show a benefit for psychodynamic therapy at 4.5 months only.135

Also, while small study bias has been reported in psychotherapy literature,179,180 one analysis suggested that the statistical significance of pooled results may be only minimally affected.180 Many of our included studies had very small sample sizes. The largest study was a good-quality Hungarian trial of women identified and treated with CBT during pregnancy. This trial reported a benefit of CBT therapy at 6 week postpartum. Not surprisingly, the effect size of this study was almost identical to the pooled estimate, suggesting that overestimation of effect was probably less of a concern in the current review than in other meta-analyses.145

Our belief that overestimation of effect size is likely limited in this review is further supported by the fact that other reviewers have shown that trials that recruited through screening generally found smaller effect sizes than those enrolling self-selected volunteers from broadbased community recruitment through media advertisements and other means.181 Since we limited our included studies to those that used screening to identify eligible participants, this likely limited the degree to which our pooled effect size overestimates real-world results.

We found very little evidence related to the harms of behavioral-based treatment in pregnant or postpartum women, and no study that suggested that these treatments could be harmful. We found evidence suggesting use of some specific agents or classes of antidepressants, particularly SSRIs and venlafaxine, during pregnancy may be associated with increases in the risk of preeclampsia, postpartum hemorrhage, and miscarriage, as well as a number of adverse infant outcomes (e.g., preterm birth, neonatal seizures). Conclusions from a recently published re-analysis of data from the National Birth Defects Prevention Study (NBDPS),182 published after our literature searches were completed, were largely consistent with evidence included in our review, both from the NBDPS and other sources. This new re-analysis, however, did suggest a possible association between fluoxetine and right ventricular outflow tract obstruction cardiac defects (OR, 2.0 [95% credible interval, 1.4 to 3.1]), unlike studies included in our review.

For antidepressants, there is an imbalance of evidence such that most available studies suggest potential harms when used during pregnancy while showing very little evidence related to benefits. Data on harms from antidepressants were exclusively observational, however, so we could not definitively determine whether these agents were the direct cause of these adverse events. Indeed, one large observational study that noted increases in miscarriage with SSRI use also found increases when women had discontinued the SSRIs more than 3 months before becoming pregnant.132 This suggests that the increased risk may be due to some other confounding factor, perhaps related to depression itself, because this study was not limited to women with depression.

In summary, available data suggest caution in prescribing antidepressants during pregnancy, especially since we found no evidence related to treatment efficacy in pregnant women. Indeed, many women express a preference for nonpharmacologic treatment during pregnancy.183-186 However, pragmatically, CBT is not an option for every woman with depression, as some will not want it, some will not have access to trained CBT providers, and some may not respond fully to CBT treatment. For women with more severe depression who are not interested in or able to participate in CBT, further research is needed on the risks versus benefits of antidepressant therapy in order to guide shared decisionmaking.

The only evidence we included related to harm of antidepressant treatment in postpartum women, on the other hand, was the small efficacy trial of fluoxetine in screen-detected women. This trial reported no differences in discontinuation due to side effects. Postpartum women may have concerns about breastfeeding, since antidepressants are detected in breast milk. However, not all are found in infant serum.187 For example, paroxetine and sertraline tend to be undetectable in infant blood levels, while levels of citalopram and fluoxetine can sometimes exceed recommended maximum levels.

In adults in general, serious adverse events can include suicidality (particularly in younger adults), hyponatremia, seizures, gastrointestinal bleeding, and serotonin syndrome.188,189 Other studies have commonly reported adverse effects that include discontinuation syndrome, gastrointestinal upset, sexual side effects, agitation, anxiety, and weight gain.190,191

#### Acceptability of Screening in Pregnant and Postpartum Women to Patients and Providers

In the included screening studies, screening was completed in 81 to 93 percent of women invited to screening, suggesting high feasibility and low refusal rates. None of the included studies, however, specifically reported participants' feelings about depression screening. In a recent study of 145 postpartum American women screened during a pediatric visit, the majority (95.7%) found discussing symptoms of depression with their pediatrician to be acceptable and welcome.192 Similarly, in an Australian study of 479 postpartum women who were screened with the EPDS, nearly all women (96.7%) thought it would be a good idea to screen new mothers for postnatal depression.193 Although not limited to pregnant and postpartum women, universal screening in an obstetrics/gynecology service was generally seen in a positive light among participants in a collaborative care RCT. Many patients reported that while they had been feeling depressed, they would not have brought it up with their providers if they had not been specifically asked.63

Studies from Australia and the United Kingdom, however, suggest that women with depressive symptoms may feel some discomfort with depression screening.193-195 For example, 29 percent of women in an Australian study who were informed that they had screened positive reported feeling upset or a little upset.194 Also, a small qualitative study conducted in the United Kingdom of postnatal screening in the home found some women felt anxious about the consequence of the results and were reluctant to answer the questions or answer them truthfully; others felt it was intrusive and that a diagnosis of depression would be stigmatizing.195 These results suggest sensitive screening procedures and handling of positive screening results are important.

One Australian study also evaluated the general practitioners', maternal child health nurses', and midwives' level of comfort and perceived usefulness of the EPDS after 3 years of routine perinatal use.194 Almost all providers reported an intent to keep using the EPDS (97% to 99%), and most rated it as “certainly/very” useful (55% of general practitioners, 75% of maternal child health nurses, and 57% of midwives). Similarly, most of the remaining providers rated the EPDS as “somewhat” useful. Midwives were more likely to experience discomfort in explaining the EPDS than physicians and nurses.194

#### Acceptability of Treatment in Pregnant and Postpartum Women

None of our included treatment studies in pregnant and postpartum women reported on acceptability of depression treatment. Women in six qualitative studies of participation in psychosocial groups for postpartum depression reported that the groups helped them develop better relationships with their babies and assess their roles of partner and mother. They reported they were better able to understand their feelings associated with postpartum depression, appreciated the support and decreased isolation, and benefited from normalizing/social comparisons with other women suffering from postpartum depression. Some participants, however, reported difficulty applying CBT principles, difficulty talking openly in group settings, negative social comparisons, and being distressed by other women's stress and dysfunction.196 Descriptive studies among postpartum women—either diagnosed with postpartum depression or not—showed they are more accepting of psychotherapy as treatment for depression than using antidepressants.183-186 The women's main concerns with antidepressant treatment included their effects on parenting and breastfeeding as well as a fear of dependence and the stigma associated with their use.183 Women with postpartum depression who are prescribed antidepressants tend to have poor compliance.197

#### Estimated Effect of Screening Alone

It is difficult to isolate the effect of screening using available data. Therefore, we are unable to translate these results into downstream clinical benefits. The usual care for identifying depression in postpartum women is not well understood and varies considerably across settings. A few states have mandated depression screening in pregnant or postpartum women and others have funded programs to guarantee reimbursement for screening, train providers, or raise awareness about depression in pregnant and postpartum women.85 Most states, however, do not have such programs and the standard of care varies considerably, even within states with related legislation. Previous observational cohort studies that assessed the implementation of systematic screening without further care supports reported mixed findings—some reported continued low rates of screening or care initiation while others did not.198-201 Among the trials included in our review, the proportion of women with depression who recovered or responded to treatment varied widely, undoubtedly fueled at least in part by different outcome definitions. The U.S.-based study of screening included in this review found that 41 percent of postpartum women with elevated EPDS scores had been correctly identified by providers as being depressed with usual clinical practice. Sixty-six percent of these women were identified with EPDS results, which is a 61 percent increase in correct identification of depression.202 This seems to support the likelihood that the 23 to 30 percent reduction in prevalence in mostly nonU.S.-based screening studies would be plausible in the United States.

### General and Older Adult Populations

We found that evidence generally supported the benefits of depression screening programs in general adult populations, with the most robust findings in programs that included substantial care supports beyond simple screening, in persons with newly-identified depression. We found no evidence of benefit of screening in older adults, but data with high applicability to the United States were limited to only two older studies.

One trial conducted in older adults hinted that a program of home-based screening and referral to specialty care with limited role for the primary care provider may have a harmful effect on older adults. This result must be interpreted with great caution, however, given that it was only found in a single study, was not statistically significant, and was conducted in the context of a health care system that may be quite different from what many experience in the United States. Older adults, however, may have unique needs with regards to depression identification and care for a number of reasons. First, older adults have an increased likelihood of serious comorbid illness, which may make it both difficult to diagnose depression and increase the risk of harmful drug interactions with antidepressant use. Older adults may have recognized or unrecognized cognitive impairment that can increase their risk for depression and decrease their odds of responding to treatment, in part due to either difficulty engaging in therapy, decreased adherence to treatment recommendations due to cognitive issues, or both. In addition, older adults may be more likely to endorse a high level of stigma associated with depression (particularly African Americans), a preference for depression treatment from primary care providers (vs. specialty care), and preference for nonactive treatments, such as supportive care and watchful waiting, over active treatments.203-206

The current body of evidence was almost the same as the evidence included in the previous review. These reviews differed by only two trials, both of which were in older adults; we excluded one previously included trial207 due to a slight change in inclusion criteria in the current review and we also identified one newly published study.166 The excluded study did not report remission, so the data on remission was identical in the previous and current reviews, except for the addition of the newly published study. However, the excluded study did report a 1-point statistically significant greater improvement in depressive symptoms on a 30-point scale. We excluded this study because depression screening results were not directly returned to providers. Instead, providers received the results of a thorough geriatric assessment that was triggered by the positive screening test. We used a more narrow interpretation of screening test results in this review than was used in the previous review.

As with the previous review, the number of studies that examined screening programs in general and older adults was limited, and most screening interventions provided additional treatment support components, at times quite extensive, making it impossible to isolate the effects of screening alone. In addition, several trials included only a small number of participants, limiting statistical power and precision of effects. An important strength of the subset of studies that were not limited to older adults was that they had good applicability to the U.S. primary care system, as all were conducted in the United States and in a wide variety of primary care settings.

Previous reviews supporting the USPSTF recommendations on depression screening have examined the complete chain of evidence in an expanded analytic framework.87,188 The USPSTF previously concluded that brief, accurate, and feasible screening tests are available for detecting depressive disorders in adults (good evidence) and older adults (fair-to-good evidence), and that effective pharmacologic (good evidence) and psychotherapeutic treatments (fair evidence) are available for adult primary care patients with major depression.87 Further, the 2009 review clarified that the benefits to older adults from antidepressants, psychotherapy, or both were comparable to younger adults. However, one group of researchers requested unpublished results of antidepressant trials from the FDA and found that published results reported larger effect sizes than unpublished data; this group raised concerns that reported benefits of antidepressant treatment may be overstated.208 Regarding serious harms of antidepressants, the 2009 review found that older adults have a higher risk for upper gastrointestinal bleeding with antidepressant use.188 The 2009 review also concluded that data linking antidepressant use to suicide deaths was inconclusive, but may be elevated in younger adults, particularly with the use of paroxetine for the treatment of major depressive disorder.

Since the current review only assessed the direct effects of screening programs in general adult populations, and some information on benefits of treatment and screening instrument accuracy were last examined in the 2002 review, we nonsystematically examined current evidence for these two areas.

For benefits of treatment, recent reviews reported that collaborative care interventions, SSRIs, venlafaxine, and certain psychological treatments are effective in reducing depressive symptoms in studies of patients recruited from primary care settings, even without systematic screening.83, 209,210 For example, the Community Preventive Services Task Force found that collaborative care interventions improve depressive symptoms, adherence to treatment, response to treatment, and remission and recovery from depression. Many of these interventions involved screening.83 We were unable to include most of these collaborative care trials in our review since screening (or results feedback) alone were typical control groups in these trials.

Further, we searched for studies in adults or older adults whose depression was identified through screening in primary care. We found 18 trials that were published between 1983 and 2013. Details of these studies can be found in Appendix E.211-228 We found seven trials of collaborative care or other system-level approaches,212,215,220-222,225,229 and five of these showed beneficial results after 6 or more months, including both trials that were limited to older adults.215,225 For example, the Prevention of Suicide in Primary Care Elderly: Collaborative Trial found greater declines in suicidal ideation, earlier treatment response, and higher depression remission rates at 24-month followup.215 Eleven trials tested behavioral interventions in the general or older adult population,211,213,214,216,217,219,223,227,228,230,231 and results were mixed. In general, studies that utilized more intensive (e.g., greater number of sessions) behavioral-based treatments were more likely to report positive effects than less intensive approaches. Some studies noted that participants with more severe depression symptoms at baseline showed greater treatment effects211,223 and that treatment effects tended to diminish over longer followup periods.220,225 One trial studied the effect of an antidepressant in a screened population and reported a beneficial effect after 8 months of treatment.213

For screening instrument accuracy, we focused on the examination of the GDS (for older adult populations) and PHQ family of instruments, which are widely used in current practice. These instruments were largely not represented in published studies until after the 2002 review was completed. Authors of a recent review of the PHQ-9 concluded that it had acceptable diagnostic properties for detecting major depressive disorder for cutoff scores between 8 and 11, with a pooled specificity from 0.83 (95% CI, 0.69 to 0.92) for a cutoff score of 8, to 0.89 (95% CI, 0.79 to 0.94) for a cutoff score of 11. Corresponding pooled sensitivity estimates ranged from 0.82 (95% CI, 0.66 to 0.92) for a cutoff score of 8, to 0.89 (95% CI, 0.75 to 0.96) for a cutoff score of 11. While a cutoff score of 11 appeared to have the optimal tradeoff between sensitivity and specificity, this may vary according to clinical setting.232 An individual-level pooled data analysis is underway to examine the PHQ family of instruments, which can overcome some important limitations of the study-level data, including the risk of overestimation of accuracy due to reporting of optimal cutoffs (rather than the full range).233 In a separate review, studies evaluating the GDS-15 (k=7) used cutoffs ranging from 3 to 7, which resulted in an adjusted sensitivity of 81.3 percent (95% CI, 77.2 to 85.2) and a specificity of 78.4 percent (95% CI, 71.2 to 84.8).234 Authors concluded that the GDS-15 had adequate diagnostic value. Furthermore, they concluded that the use of the GDS-15 by general practitioners could increase unassisted case detection by 8 percent. Similarly, Chilean researchers found that self-administered screening tools were much more sensitive than general practitioners in identifying depression, but with comparable specificity.235 A more detailed writeup of instrument accuracy of the PHQ and GDS is available in Appendix F. Ultimately, sensitivity may be more important than specificity for patients with depressive symptoms. As many as half of persons with mood disorders are likely to also have anxiety disorders, and both antidepressants and behavioral-based interventions are also likely to benefit those with anxiety symptoms in addition to depressive symptoms.236-238

#### Acceptability of Screening Programs to Patients and Providers

In most of the included studies that reported screening completion rates, 80 to 90 percent of persons invited to screening completed the screening test, which suggests depression screening was both feasible and generally acceptable to patients. One Dutch study used mail or phone for screening rather than incorporating the screening into a clinic visit and had a substantially lower completion rate (53%).166 Two of the included screening studies—one in U.S. adults162 and one in Dutch older adults167—determined screening did not affect the patient's satisfaction with care. In a recent patient satisfaction survey among 107 U.S. geriatric patients, 62.9 percent found mental health screening questions acceptable.239 Less than 3 percent of respondents found the questions very difficult, stressful, intrusive, embarrassing, upsetting, or uncomfortable as it raised difficult emotions and an awareness of their current mental health status. In another U.S. study, patients reported that they appreciated learning how to help themselves with their depression after being screened with the PHQ-9.^240^

Only two of the included screening trials evaluated the physician's perception of the utility of screening for depression in adults.72,162 In one study, physicians found the PHQ-9 useful in 78 percent of baseline patient visits regardless of depression status.72 In the other study, 433 physicians randomized to use a case-finding instrument (1- or 20-item) returned a questionnaire regarding its helpfulness.162 The majority (76%) found the instrument to be very or somewhat helpful, while only 4 percent found it unhelpful.

One depression screening implementation study surveyed providers 1 year after implementation of a program in a U.S. Army medical clinic. This intervention involved staff training, depression screening, automatic entry of results in the chart, automatic scheduling of a followup appointment with the primary care provider, and an offer for a mental health referral. This study reported 54 percent of primary care providers and 95 percent of nurses strongly agreed that screening for depression enhanced quality of care.241 An implementation effort in three U.S. nonprofit and county agencies that provided case management to older adults revealed some challenges.242 In this intervention, older adults screening positive for depression and their families received education on depression and printed materials. Case managers facilitated referrals and helped clients communicate with a medical or mental health provider. Case managers also provided behavioral activation counseling. Challenges included clients' reluctance to acknowledge depressive symptoms and difficulty engaging in behavioral activation; differences among case managers' mental health knowledge, skills, and “buy-in”; limited time for case managers' intervention and referral activities; and agency cultures that don't foster in-agency supervision. The screening and patient education components of the intervention were rated “easy” by 90 percent of case managers; most of the challenges came with implementation of the referrals and behavioral activation counseling.

#### Estimated Effect of Screening Alone

As with pregnant and postpartum women, correct identification of depression by primary care providers undoubtedly varies across different settings. Reviews examining correct identification rates estimate an average rate of approximately 47 percent.47,48 This result is consistent with a recently conducted trial in Spain that reported 48 percent of primary care patients with depression were correctly identified by their providers.243 This trial reported a 21 percent increase in identification after training providers in screening and implementing a screening program.243 Similarly, after implementing a screening program in a U.S. Army clinic, the number of depression cases identified increased from approximately 100 per month to 130 to 140 per month.241 Assuming that all other parts of the treatment process are constant, a 20 to 40 percent increase in recognition of depression would translate to a 20 to 40 percent increase in remission of cases of depression. This result is consistent with the effect sizes reported by studies of screening programs in general adult populations. As the work by Pence and colleagues makes clear, improvements in other steps in the process after recognition of depression have the potential for additional gains in depression remission.47 Indeed, failure to deliver effective treatment negates the benefits of greater depression identification. As a result, it appears that the most active area of research is in testing collaborative care and care management models for screen-detected or otherwise identified depression, rather than examining the specific effects of screening in the absence of other treatment supports.

### Concerns About Routine Depression Screening

Other reviewers have questioned the evidence supporting a recommendation favoring depression screening.244-246 These reviewers cite a number of concerns, including the lack of true direct evidence to support depression screening; the concern that most cases identified through screening will not be newly-identified persons with previously unknown depression, but will primarily be persons already known to have depression and who have been treated for depression; and the concern that those who are newly identified through screening will have milder cases of depression that may not warrant treatment, thus increasing the risk of unnecessary treatment and direct harms of treatment. For example, the National Institute for Health and Clinical Excellence does not recommend routine depression screening, but rather that providers be alert to possible depression, particularly in certain high-risk groups, such as those with functional impairment related to health problems.247 Similarly, the Canadian Task Force on Preventive Health Care has recently recommended not routinely screening for depression in either average- or increased-risk adults in the primary care setting, due to lack of direct evidence on benefit and harms of screening.248 The Canadian Task Force review required an unscreened control group and only included five quasiexperimental studies of community screening programs conducted in Japan as its evidence base. We excluded these studies because they examined public health interventions, not health care–based interventions. The Canadian Task Force did not consider any of our included KQ 1a studies because they did not include unscreened control groups (even though providers did not receive the screening results). It also excluded the studies we included in KQ 1 that had unscreened control groups. In the KQ 1 study that was conducted in a population of general adults, control group participants underwent a diagnostic interview as part of the study process, which may have been the reason for exclusion by the Canadian Task Force reviewers.162 They also excluded two KQ 1 trials that were conducted in postpartum women—one due to lack of appropriate comparator105 (perhaps because both groups were treated by the same study-trained providers, if treatment was recommended) and one because it was not an eligible population106 (perhaps because they were recruited from midwives' postnatal care practices, rather than general primary care).

We agree that very little data exist that allow us to determine the effects of screening alone compared with no screening. Instead, most KQ 1/KQ 1a interventions included screening and additional treatment elements. Thombs and colleagues likened this to testing usual case-finding for cancer plus less-than-ideal cancer care versus screening plus state-of-the-art treatment.249 Unfortunately, depression is a condition that is plagued by both underidentification and less-than-ideal care.56,68

While limited, we did find one trial conducted in a general adult population and one conducted in a postpartum population that looked specifically at the addition of systematic use of a screening instrument versus usual case-identification, either without further enhancements to depression care162 or with the same treatment offered to both groups, if depression treatment was indicated.105 The latter, which was conducted in a population of postpartum women, reported reduced depression prevalence at 4 months, although this effect disappeared at 16-months followup. The other trial, which was conducted in a general adult population, reported increased likelihood of remission at 3-month followup among those with depression at baseline. This study, however, did not find statistically significant group differences in overall depression prevalence (37% in the intervention group vs. 46% in the control group; p=0.19).162

While these are very minimal data that are directly on point, it is further supported by two streams of indirect evidence. First, critics have not acknowledged that there is a complete chain of indirect evidence showing that screening instruments can identify depression, and that treatment with net benefits is available for persons with depression, as determined by the previous USPSTF reviews on this topic. Our updated, nonsystematic examination of this evidence clarifies that depression treatment can be effective in persons whose depression is detected by screening in primary care settings, further solidifying the indirect chain. Second, screening trials with additional supports may be interpreted as providing evidence for a complete system of care in which the sum is more important than the parts.

While few trials had unscreened control groups, we believe that screening in the control group that did not provide results feedback to the provider would be most likely to attenuate results. This is because screened persons may have heightened awareness of their depression and, therefore, be more likely to bring it up with their provider. Thus, we believe the effects seen in studies of screening results feedback versus no feedback may, if anything, underestimate the true effect of screening.

A second concern is that few new cases of depression will be found with screening. In most of the included studies, a high proportion of persons who screened positive had already been identified by health providers as having depression, unless patients with previously known or treated depression were specifically excluded. Since depression is often inadequately treated,56,68 however, we believe it is also important for persons who still have depression despite previous treatment efforts to be identified so their provider can continue to help them until they are able to find a successful treatment. While this falls outside the traditional definition of screening, it is nevertheless a potentially important side benefit of depression screening programs. Further, depression screening presents an opportunity to query suicidal ideation among those who screen positive. While the USPSTF has not recommended routine screening for suicide risk, it did note that “primary care clinicians should be aware of psychiatric problems in their patients and should consider asking these patients about suicidal ideation and referring them” for treatment.75 Thus, pragmatically, identifying incompletely treated patients could be considered an added benefit of routine depression screening, although it falls more in the realm of depression management than prevention through early detection, which is the traditional definition of screening.

A third concern is that additional cases found through screening are more likely to have very mild depression. Critics note that treatment may not be necessary or even beneficial with mild depression, and could lead to overuse of antidepressants and unnecessary harms associated with them. Indeed, studies of antidepressants do show larger beneficial effects in patients with more severe depression than those with mild depression.250,251 In fact, an analysis of data submitted to the FDA found that efficacy of second-generation antidepressants only met criteria for clinical significance at the highest depression severity levels.251 A review of psychological treatments for depression, however, did not find an association between baseline depression severity and effect size, and although within-study results suggested larger effects with greater severity, differences between subgroups were not statistically significant and the pooled effect was statistically significant for those with lower baseline severity.252 Thus, if the only or primary treatment available is antidepressants, this argument has merit. If behavioral-based treatment is available, however, this concern is diminished. The U.K. National Institute for Health and Care Excellence recommends active monitoring, low-intensity psychosocial interventions, or advice on sleep and anxiety management as initial strategies in persons with newly-identified mild or subthreshold depression, rather than antidepressants.253

To examine this further and focus on screen-detected depression, we identified nine RCTs published between 1997 and 2014 that examined the effectiveness of behavioral-based, pharmacologic, or both treatments for relatively mild depression (subthreshold depression, subsyndromal depression, minor depression, dysthymia, and major depressive disorder with mild-to-moderate symptoms) in patients who had screened positive for depression in primary care settings.215,218,219,223,254-258 Two trials had both medication and behavioral-based treatment arms.256,258 Two other trials examined a stepped-care approach that may have included options for both behavioral-based and pharmacologic interventions.215,218 All but one of these trials excluded participants with current or recent treatment for depression.219 We found limited empirical support for the effectiveness of behavioral interventions in the treatment of mild depression and three of the seven behavioral-based treatment arms showed a benefit of treatment. Both of the treatment arms that tested antidepressants (paroxetine and sertraline) showed a benefit of treatment.256,258 Both of the stepped-care approaches, however, did not show group differences in the subgroup of patients with minor depression.215,218 Both intervention and control groups showed substantial improvement in the two stepped-care studies, including a large U.S.-based study in older adults.215 This evidence strengthens the concern that there may be limited downstream benefits for persons with relatively mild depression whose depression is detected through screening. This is consistent with a review of psychological therapies, which showed smaller effects in primary care–based trials of screen-detected depression compared with referral-based recruitment.259

Although simple logic supports the notion that screen-detected depression would be milder, on average, than depression identified through usual clinical care, we found very limited evidence to clarify whether this is the case. One collaborative care trial examined PHQ-9 scores in women with depression in an obstetrics/gynecology practice who were identified through systematic screening versus usual case-finding and found no differences in depression severity.260

## Limitations of the Review

In addition to the limitations of the evidence discussed above, this review did not cover areas of research that may be pertinent. For example, we limited our examination of screening instrument accuracy in pregnant and postpartum women to only two instruments, the PHQ and the EPDS, which we believe are most widely used in clinical practice. However, additional instruments may also be valid for depression screening. We also did not include nontrial evidence related to harms of screening or behavioral-based treatment. We believe the risks for these treatments are minimal. We did consider pertinent observational evidence in the Discussion, primarily associated with acceptability of these treatments. Further, we limited our evidence of antidepressant harms in pregnant and postpartum women to a prespecified list of serious harms. We did not examine other harms that may be important, if not life-threatening, such as developmental and behavioral outcomes in babies (e.g., crying and sleeping). In addition, we only examined evidence limited to pregnant and postpartum women, rather than providing a comprehensive examination of all harms in adults. Also, we did not review effectiveness of interventions in pregnant and postpartum women that are generally offered outside of the health care setting but are widely available, such as yoga, exercise, and light therapy. We did not examine benefits of screening or treatment in pregnant or postpartum adolescents. Finally, we relied on other reviews to identify evidence for some KQs in certain search windows, and for harm of antidepressants, we relied on the synthesized work of previous reviewers. While we assessed the pertinent parts of these reviews' methods as being of good quality, it is nonetheless possible that the reviewers missed or incorrectly interpreted evidence that we are unaware of.

We did not systematically review the accuracy of depression screening instruments or benefits and harms of treatment for general and older adult populations. Thus, while we did not complete the entire chain of indirect evidence, we instead focused only on direct evidence of screening benefits and harms. This indirect data was previously systematically reviewed and found to adequately support a screening recommendation, and we did informally review data published in these areas since the previous reviews. A systematic update may have revealed more data than we found.

## Future Research Needs

In general, the field of depression screening and treatment research would benefit from standardized definitions of important outcomes, such as depression remission or depression prevalence. Cross-study comparisons would also be enhanced by adopting a small number of depression symptom measures, such as the PHQ instruments, the GDS, and the EPDS. Evidence with high applicability to the United States was limited for most KQs. Specific needs include:

- Large trials conducted in the United States of screening alone compared with usual case-finding in pregnant and postpartum women, general adult populations, and older adults, covering a variety of primary care settings.
- Trials that examine the relative importance of screening and other treatment support components, such as treatment guidelines and training, staff-assisted symptom monitoring, ease of referral, and role of the primary care provider.
- Large-scale good-quality U.S.-based trials of depression treatment in pregnant and postpartum women.
- More information on screening instrument accuracy of the PHQ family of instruments, likely the most widely used instrument in practice (underway, protocol published).233
- More trials with sufficient power to explore variability in benefits and harms of screening and treatment by patient characteristics such as age, race/ethnicity, sex, and comorbid conditions.

Ghio and colleagues261 discuss unmet needs and research challenges for late-life mood disorders, including “critical aspects of clinical trials in late-life mood disorders that limit our knowledge about diagnosis/treatment of depression in older adults,” with which we concur. These include use of heterogeneous age ranges in inclusion criteria, exclusion of very old patients, atypical presentation of late-life depression, few rating scales specific for geriatric populations, lack of evidence in patients with more than one comorbid condition, high frequency of suboptimal prescribing, heterogeneity of secondary outcomes, high attrition rates, and uncertainty about optimal trial duration, among others.

We identified a number of additional ongoing studies that may be relevant for updates of this review, primarily trials of behavioral treatment in pregnant and postpartum women (Appendix G).

## Conclusion

Although direct evidence of the isolated health benefit of depression screening in primary care is weak, the totality of the evidence supports the benefits of screening in pregnant and postpartum and general adult populations, particularly in the presence of additional treatment supports, such as treatment protocols, care management, and availability of specially trained depression care providers. The indirect evidence shows that depression screening instruments can identify adults, including older adults and pregnant and postpartum women, who need further evaluation and may need treatment for depression, and that depression treatment is likely to be effective. The only risk of harm we identified was with the use of antidepressants during pregnancy, although the risks appear to be small and CBT does appear to be an effective alternative treatment approach. Evidence is the least supportive of screening in older adults, where direct evidence is most limited and did not demonstrate a beneficial effect. Generalizing from evidence in all adults to older adults may be reasonable.