# Results

## Literature Search

We screened 6,536 abstracts and identified 71 included studies that reported results in 91 publications. For pregnant and postpartum women, we included six trials addressing the benefits or harms of screening,69,100,104-107 26 diagnostic accuracy studies,100-102,108-130 and 32 studies91,131-160 that assessed the benefits or harms of treatment. This final group included one recent systematic review on the harms of antidepressants91 (Appendix B Figure 1). In general and older adults, we included nine trials that addressed the benefits or harms of screening (Appendix B Figure 2).72,73,161-167

## Results of Included Studies in Pregnant and Postpartum Women

We used five KQs and related subquestions to assess depression screening and treatment for pregnant and postpartum women. These KQs addressed benefits of screening (KQ 1), accuracy of selected depression screening instruments (KQ 2), harms of depression screening (KQ 3), benefits of depression treatment in screen-detected patients (KQ 4), and harms of depression treatment, particularly antidepressants (KQ 5).

### KQ 1 Do Primary Care Depression Screening Programs in Pregnant and Postpartum Women Result in Improved Health Outcomes?

### KQ 1a Does Sending Depression Screening Test Results to Providers (With or Without Additional Care Management Supports) Result in Improved Health Outcomes?

#### Study Characteristics

We included six trials that examined the benefits of screening for pregnant and postpartum depression (n=11,869), with or without additional provider training or treatment optimization. These trials were primarily conducted in postpartum women. All of these trials studied women identified through health care settings and included women both with and without depression in their samples (Table 5).69,100,104-107 Two trials included unscreened control groups105,106 and four trials screened all participants and sent results only to intervention group providers.69,100,104,107 None of the studies, however, used a straightforward design that compared usual care plus screening (and no additional treatment components) to usual care without screening.

Table 5 Study Characteristics of Included Studies for KQs 1 and 1a (Pregnant and Postpartum Women)

Author, Year and Quality | KQ1 | Study Design | N | Intervention | Weeks Postpartum at Baseline | Followup (m) | Country | Setting | Invited to Screen (% Screened) | % Screened Positive for Depression | Definition of Screened Positive
Leung, 2011^105^ Good | KQ1 | RCT | 462 | Screening | 8 | 4, 16 | Hong Kong | Primary care | NR | 25.1 | EPDS ≥ 10
Wickberg, 2005^107^ Fair | KQ1a | Cluster RCT | 669 | Screening results + brief depression training | 25 weeks gestation | 2.75 | Sweden | Primary care | 717 (93.3%) | 13.9 | EPDS ≥ 12 at gestational week 25
Yawn, 2012^69,268^ Fair | KQ1a | Cluster RCT | 2343 | Screening results + provider training & supports | 8 | 6, 12 | United States | Primary care | 2398 (97.7%) | 27.9 | EPDS ≥ 10 or PHQ-9 ≥ 10
MacArthur, 2002^106^ Fair | KQ1 | Cluster RCT | 2064 | Screening + midwife training & supports | 4 | 3 | United Kingdom | Primary care/home visits | NR | NR | EPDS ≥ 13 at 4 weeks postpartum
Morrell, 2009a100,269 Fair | KQ1a | Cluster RCT | 4084 | Screening results + CBT or person-centered counseling | 6 | 5 | United Kingdom | Primary care/home visits | NR | 17.3 | EPDS ≥ 12 at 6 weeks postpartum
Glavin, 2010^104^ Fair | KQ1a | CCT | 2247 | Screening results + redesigned followup care | 6 | 1.5, 4.5 | Norway | Primary care/home visits | 2508 (89.6%) | 10.1 | EPDS ≥ 10 at 6 weeks postpartum

Abbreviations: CBT = cognitive behavioral therapy; CCT = controlled clinical trial; EPDS = Edinburgh Postnatal Depression Scale; KQ = Key Question; m = months; NR = not reported; PHQ = Patient Health Questionnaire; RCT = randomized controlled trial.

All six of these trials were conducted in primary care settings, including obstetric clinics and routine in-home postpartum services offered in some countries. Only one trial was conducted in the United States.69 The remaining trials were conducted in northern Europe,104,107 the United Kingdom,100,106 and Hong Kong.105 While most trials screened women at 1 to 2 months postpartum, one trial screened women during gestational week 25.^107^ Followup ranged from 11 weeks107 to approximately 16.5 months postbaseline.100

All studies used the EPDS for screening with variable cutoffs (range, 10 to 13). One study used both the EPDS and the PHQ.69 Screening in these trials took place in the context of clinic, hospital, or maternal home visits. Acceptance of screening in these studies was high—90 to 98 percent of those invited completed the screening, where reported.

#### Populations

Our six included studies provided few details about sample characteristics (Table 6). Few trials reported average age of the mothers or race/ethnicity and only two described participants' depression history. Between 10 and 28 percent of the study samples screened positive for depression, with higher positivity rates generally associated with lower EPDS cutoffs. While two trials were specifically limited to women with live-born children, exclusion criteria were fairly minimal in the remaining studies.100,104

Table 6 Population Characteristics of Included Studies for KQs 1 and 1a (Pregnant and Postpartum Women)

Author, Year and Quality | Mean Age and Range (years) | Race/Ethnicity (%) | SES | Depression History, n (%)
Leung, 2011^105^ Good | NR | NR | Family income ≤ HK$19,999, n (%): 233 (50.4) | NR
Wickberg, 2005^107^ Fair | NR | NR | NR | NR
Yawn, 2012^69^ Fair | 26.4 (≥ 18) | Black: 18 Hispanic: 12 White: NR | Uninsured at 2 months postpartum, n (%): 862 (36.8) | History of depression: 709 (30.3%)
MacArthur, 2002^106^ Fair | NR | NR | Most deprived Townsend quartile, n (%): 503 (24.4) | NR
Morrell, 2009a100 Fair | NR (≥ 18) | Black: NR Hispanic: NR White: 95.3 | Rent council or housing association, n (%): 547 (13.4) | Previous pregnancy w/ postnatal depression: 617 (15.1%)
Glavin, 2010^104^ Fair | 32.5 (≥ 18) | NR | NR | NR

Abbreviations: NR = not reported; HK = Hong Kong; SES = socioeconomic status.

#### Screening Program Interventions

This evidence included six widely differing interventions that accompanied or supplemented screening (Table 7; Appendix D Table 1). While two trials involved minimal additional intervention beyond screening or feedback of screening results in postpartum105 and pregnant107 women, two other trials examined the effects of screening plus provider supports in postpartum women.69,105,106 Finally, two trials examined screening strategies that gave providers results feedback plus adjunctive counseling by home health visitors in postpartum women.100,104

Table 7 Intervention Characteristics of Included Studies for KQs 1 and 1a (Pregnant and Postpartum Women)

Author, Year Quality | Intervention | Train PCP in Screening | Train PCP in Depression Diagnosis | Train PCP in Depression Treatment | Treatment Guidance Provided | Patient Materials Provided | Patient-specific Treatment Recommendations | Referral Support for PCP | Symptom Monitoring by Support Staff | Treatment Adherence Monitoring by Support Staff | Counseling to Support Adherence | Behavioral Counseling Approach | Estimated Hours of Behavioral Counseling | Target Provider
Leung, 2011^105^ Good | Screening + training in nondirective counseling | ✓ | | ✓ | | | | | | | | NA | NA | Nurse
Wickberg, 2005^107^ Fair | Screening results + brief depression training | | ✓ | ✓ | | | | | | | | NA | NA | Midwife
Yawn, 2012^69^ Fair | Screening results + provider training & supports | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | NR | 0.25 | Physician
MacArthur, 2002^106^ Fair | Screening + midwife training & supports | | | ✓ | ✓ | | | | | | | NA | NA | Midwife
Morrell, 2009a100 Fair | Screening + person-centered counseling or CBT | | ✓ | ✓ | ✓ | | | | | | | Person-centered or CBT | 8 | Health visitor
Glavin, 2010^104^ Fair | Screening + redesigned followup care | | ✓ | ✓ | ✓ | ✓ | | | | | | Non-directive counseling | NR | Public health nurse visitor

Abbreviations: CBT = cognitive behavioral therapy; NA = not applicable; PCP = primary care provider.

The two trials that focused primarily on the effects of screening (with few additional treatment components) used EPDS to screen women treated at maternal health centers. The nurses or midwives caring for participants scoring at or above 10 or 12 were notified of their patients' elevated scores.105,107 One of these studies used the same nurse providers to provide nondirective counseling to women in both the treatment and control groups, and the two groups differed only in the case-finding approach (screening plus usual clinical interview vs. usual clinical interview alone). As such, this study provided the purest test of screening in this body of evidence.105 This study design, however, could also contaminate results because the intervention component was delivered to both groups by the same individual. By holding the intervention component constant, however, it increased the likelihood that differences between groups are due to the effects of adding EPDS screening to usual care.

The two trials that targeted providers involved guidelines, provider materials, and (in one trial) patient handouts.69,106 Both studies also used screening tests for symptom monitoring and screening. They integrated test results into the treatment algorithms. The U.S.-based study conducted by Yawn and colleagues targeted family medicine practices and provided training in, and tools for, identifying, diagnosing, and treating depression in postpartum women.69 The intervention included: an immediate action protocol with a treatment algorithm based in part on PHQ-9 test results; a suggested schedule of followup visits and phone calls, along with an outline for what should be covered at followup; information about antidepressants (including safety for pregnant and breastfeeding mothers); and materials for the patient and her partner. Similarly, the trial from the United Kingdom provided midwives with training, treatment guidelines, materials, and patient handouts.106

The final two trials tested specific therapeutic approaches delivered by nurses or health visitors in the patient's home, including nondirective/person-centered counseling or CBT.100,104 These studies administered EPDS to all intervention participants in an attempt to identify those in need of treatment. While control group participants completed the EPDS, these results were not routinely sent to their provider.

#### Quality Assessment

We rated one trial as good quality105 and the remaining five as fair. Among the fair-quality studies, one reported generally good methods (e.g., valid randomization, allocation concealment, good measurement procedures, and baseline comparability between groups), but was rated fair for fairly low retention (84% at 5-month followup). The longer-term followup data were excluded because they had very low retention (43% at 11 months).100 The remaining studies generally had low retention (<75%) and frequently failed to report valid randomization procedures or allocation concealment. Some of these studies did not clearly demonstrate comparable groups at baseline.104,107 None of the trials reported blinding of outcomes assessment, but all used self-report questionnaires for primary outcomes, usually collected via mail. One of the trials assigned two comparable municipalities in Norway to be intervention and control areas, but because they did not report random assignment, we considered this study as a CCT.104

#### Findings

##### Depression Outcomes

Five of the six trials reported the proportion of women scoring above a specified cutoff on the EPDS, which we refer to as depression prevalence, at followup ranging from 1.5 to 16 months (Appendix D Table 2).100,104-106,154 Trials in postpartum women showed a 28 to 59 percent reduction in the risk of depression at followup compared to usual care when their babies were age 4 to 6.5 months (Figure 3). This effect was smaller and not statistically significant in the trial of pregnant women, which included little beyond screening results feedback.107 Depression prevalence was lower in the screened group in the Hong Kong-based screening-only intervention in the near term (4 months), but this effect was not sustained at 16 months compared to usual clinical case-finding.105 Four studies reported an increase in the likelihood that patients no longer screened positive at followup (akin to remission) or showed a predetermined level of improvement on a scale score (akin to treatment response) among those who screened positive at baseline (Figure 4).69,100,104,107 There was a 21 to 33 percent increase in the likelihood of remission or response in trials of postpartum women at 4.5 to 12 months (6 to 14 months postpartum). While the effect was even larger in the trial of pregnant women, followup was only 2.75 months.107 Appendix D Figure 1 shows the prevalence and remission/response results for all intervention groups at all available followup timepoints.

Figure 3 Forest Plot of Depression Prevalence in Pregnant and Postpartum Women (KQ 1)

Abbreviations: CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; IG = intervention group; RR = relative risk.

This figure displays a forest plot of depression prevalence among pregnant and postpartum women after screening.

Figure 4 Forest Plot of Depression Remission in Pregnant and Postpartum Women (KQ 1)

* Response to treatment (rather than remission).

Abbreviations: CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; IG = intervention group; PHQ = Patient Health Questionnaire; pt = point; RR = relative risk.

This figure is a forest plot of depression remission in pregnant and postpartum women after screening.

All trials also reported mean or median EPDS scores, except the U.S.-based trial. These data were insufficient to allow us to create forest plots, so we only present these in tabular form (Table 8). While the results were typically statistically significant, absolute differences between the groups were very small—on the order of a 1-point mean or median difference between groups on the 30-point EPDS. These studies, however, were in general postpartum or pregnant populations. These studies included women both with and without depression, with low average symptom scores, so the small effect sizes are not surprising. These results also reflect group mean or median differences and not differences in the proportion testing above a depression cutpoint. The largest difference between groups was apparent in a subgroup analysis limited to patients who scored 12 or higher on the EPDS at baseline. Intervention participants reduced their score by an average of 5.9 points compared to an average 4.1-point reduction in the control group. This result is still a very small, clinically nonsignificant between-group effect. Of the three intervention groups in this trial, all three had an average in the “mild” depressive symptom range (<10) at followup, but the control group was still slightly above the cutoff of 10.^100^ Both of the trials that employed few provider supports or depression counseling reported slightly lower scores up to 4-month followup (5.1 to 5.8 in the intervention groups vs. 6.5 to 6.1 in the control groups; p<0.05) after a screening intervention.105,107 These groups, however, did not differ at 16-month followup in one of these studies.105

Table 8 Results of Included Studies for KQs 1 and 1a (Pregnant and Postpartum Women): Depressive Symptoms

Author, Year Quality | Intervention | Subgroup | F/U (mo) | IG n | BL IG Mean | BL IG SD | F/U IG Mean | F/U IG SD | IG Mean Change | IG SD Change | CG n | BL CG Mean | BL CG Mean SD | F/U CG Mean | F/U CG SD | CG Mean Change | CG SD Change | Between Group Difference (p-value)
Leung, 2011^105^ Good | Screening + training in nondirective counseling | All participants | 4 | 231 | NR | NR | 5.1 | 3.6 | NR | NR | 231 | NR | NR | 6.5 | 4.4 | NR | NR | <0.001
Leung, 2011^105^ Good | Screening + training in nondirective counseling | All participants | 16 | 231 | NR | NR | 5.8 | 3.9 | NR | NR | 231 | NR | NR | 5.8 | 3.6 | NR | NR | 0.819
Wickberg, 2005^107^ Fair | Screening results + brief depression training | All participants | 2.75 | 226 | 6.4 | NR | 5.4 | NR | -1.0 | NR | 231 | 6.1 | NR | 6.1 | NR | 0.0 | NR | <0.05
MacArthur, 2002^106^ Fair | Screening + community-based postnatal care | All participants | 3 | 801 | NR | NR | 6.4 | NR | NR | NR | 702 | NR | NR | 8.1 | NR | NR | NR | <0.001 (un-adjusted)
Morrell, 2009a100 Fair | Screening + intervention (combined) | All participants | 5 | 1745 | 6.6 | 4.8 | 5.5 | 4.7 | -1.1 | 4.8 | 914 | 6.8 | 5.0 | 6.4 | 5.2 | -0.4 | 5.1 | 0.001
Morrell, 2009a100 Fair | Screening + intervention (combined) | EPDS ≥12 at 6 weeks postpartum | 5 | 271 | 15.1 | 2.9 | 9.2 | 5.4 | -5.9 | 4.7 | 147 | 15.4 | 3.2 | 11.3 | 5.8 | -4.1 | 5.0 | 0.001
Glavin, 2010^104^ Fair | Screening + redesigned followup care | All participants | 1.5 | 1516 | 4.0 | NR | 2.9 | NR | NR | NR | 405 | 5.1 | NR | 4.0 | NR | NR | NR | NR
Glavin, 2010^104^ Fair | Screening + redesigned followup care | All participants | 4.5 | 1516 | 4.0 | NR | 2.0 | NR | NR | NR | 367 | 5.1 | NR | 4.1 | NR | NR | NR | NR

Abbreviations: BL = baseline; CG = control group; EPDS = Edinburgh Postnatal Depression Scale; F/U = followup; IG = intervention group; n = number; NR = not reported; SD = standard deviation.

The most applicable results come from a fair-quality trial of screening plus provider supports conducted in the United States.69 This trial found that 45 percent of intervention participants reported a 5-point or greater reduction in their PHQ-9 score compared to 34 percent with usual care (odds ratio [OR], 1.74 [95% CI, 1.05 to 5.86]; adjusted for depression history, marital status, income, education, age, and degree of parenting stress). This trial was rated as fair primarily because attrition was greater than 25% in both groups.

##### Other Beneficial Outcomes

A variety of additional outcomes were reported in some trials (Appendix D Tables 3–6). The Hong Kong-based screening trial that did not include extra provider supports or counseling found small statistically significant differences in only two of the nine quality of life or child/infant outcomes they reported, covering measures of marital satisfaction, parental stress, general distress, and baby's weight and health care use (doctor visits and hospitalizations).105 In both cases, these effects were only present at 4 months and disappeared at 16 months. In contrast, the U.K.-based study that assigned women to screening plus one of two counseling conditions showed improvements in most of the quality of life measures they included, such as state and trait anxiety measures, the 36-Item Short Form Health Survey (SF-36) mental component scale, parental stress, and a global clinical outcomes measure (Clinical Outcomes in Routine Evaluation Outcome Measure [CORE-OM]) at 5-month followup.100 No trials reported suicide-related outcomes.

### KQ 1b Does the Effect of Screening Vary By Population Characteristics?

We were unable to examine variability in benefit by our a priori population characteristics. The only subgroup analyses in the included studies examined this effect in the subgroup that screened positive for depression at baseline and are described above.

### KQ 2 What Is the Test Performance of the Most Commonly Used Primary Care Depression Screening Instruments in Pregnant and Postpartum Women?

#### Study Characteristics

We identified 23 studies100-102,108-127 (n=5,398) that examined the accuracy of the EPDS and three studies that examined the PHQ (n=777)128-130 relative to a diagnostic interview, which was generally a standardized interview such as the Structured Clinical Interview for DSM-IV Disorders (Table 9; Appendix D Table 7). Eight of the included studies used the English-language version of the EPDS (n=1,905).100,101,109,116,118,119,125,126 The remaining 15 EPDS studies explored translations into Chinese,114,117 French,108,115 Hungarian,121,122 Italian,110,113 Japanese,123 Lithuanian,111,112 Spanish,102,124 Maltese,127 and Taiwanese.120 All three PHQ studies were conducted using English-language versions of the instruments. We focused primarily on the studies of English-language instruments.

Table 9 Study Characteristics of Included Studies for KQ 2 (Pregnant and Postpartum Women)

Author, Year and Quality | N | Reference Standard | Pregnant or Postpartum | Weeks Postpartum | Country (Language) | Setting | % MDD Positive for Depression per Reference Standard
English EPDS
Tandon, 2012^119^ Fair | 95 | SCID-I/NP diagnosis of MDD | Both | Pregnant-26 weeks postpartum | United States | Other Community/ Home Visits | 28.4
Harris, 1989^116^ Fair | 126 | DSM-II criteria for MDD | Postpartum | 6 | United Kingdom | Other Clinical | 17.5
Clarke, 2008^126,270^ Fair | 103 | SCID for MDD | Postpartum | 4-52 | Canada | Other Clinical / Community | 16.5
Beck, 2001^109^ Fair | 150 | DSM-IV diagnosis of MDD | Postpartum | 2-12 | United States | Primary Care | 12.0
Morrell, 2009a100,269 Fair | 860 | SCAN interview diagnosis of mild, moderate, or severe depression | Postpartum | 6 | United Kingdom | Primary Care/ Home Visits | 15.6
Cox, 1996^101,271^ Fair | 272 | SPI interview criteria for MDD | Postpartum | 24 | United Kingdom | OB-GYN | 6.2
Murray, 1990a125 Fair | 100 | SPI using RDC criteria for MDD | Pregnant | 28-34 weeks gestation | United Kingdom | OB-GYN | 6
Leverton, 2000^118,272^ Fair | 199 | PSE interview and Bedford College diagnosis of case depression | Postpartum | 12 | United Kingdom | OB-GYN/ Home Visits | 1.5
Non-English EPDS
Lee, 2001^117^ Fair | 145 | SCID-NP diagnosis of major or minor depression | Postpartum | 6 | Hong Kong (Chinese) | OB-GYN | 11.7^*^
Chen, 2013^114^ Fair | 487 | DSM-IV-TR clinical interview diagnosis of any depression | Postpartum | 1-22 | Singapore (Chinese) | OB-GYN | 6.2^*^
Guedeney, 1998^115^ Fair | 87 | RDC diagnosis of major or minor depressive disorder | Postpartum | 16 | France (French) | Other Community | 51.7^*^
Adouard, 2005^108^ Fair | 60 | MINI DSM-IV criteria for MDD | Pregnant | 28-34 weeks gestation | France (French) | OB-GYN | 25
Toreki, 2013^121^ Good | 219 | SCID DSM-IV criteria for MDD | Pregnant | 12 weeks gestation | Hungary (Hungarian) | OB-GYN | 3.2
Toreki, 2014^122^ Fair | 266 | SCID diagnosis of MDD | Postpartum | 6 | Hungary (Hungarian) | OB-GYN | 3.0
Benvenuti, 1999^110^ Fair | 113 | MINI DSM-III-R criteria for any depression | Postpartum | 0.5 | Italy (Italian) | OB-GYN | 15.9
Carpiniello, 1997^113^ Fair | 61 | Clinically depressed by the PSE interview | Postpartum | 4-6 | Italy (Italian) | Other Community | 14.8
Yamashita, 2000^123^ Fair | 75 | SADS diagnostic interview for minor or major depression | Postpartum | 4 | Japan (Japanese) | Primary Care | 14.7^*^
Bunevicius, 2009a111 Fair | 94 | CIDI-SF diagnosis of depressive disorder | Postpartum | 2 | Lithuania (Lithuanian) | NR | 13.8^*^
Bunevicius, 2009b112 Fair | 230 | SCID-NP diagnosis of MDD | Pregnant | 1st trimester | Lithuania (Lithuanian) | OB-GYN | 5.2
Felice, 2006^127^ Fair | 223 | ICD-9 based on CIS-R interview for severe, moderate, or mild depression episode | Pregnant | Average 18.6 weeks gestation | Malta (Maltese) | OB-GYN | 14.3
Alvarado, 2014^124^ Fair | 111 | DSM-IV or ICD-9 diagnosis of MDD based on MINI interview | Pregnant | 28 weeks gestation | Chile (Spanish) | Primary Care | 34.2
Garcia-Esteve, 2003^102^ Fair | 1123 | SCID diagnosis of MDD | Postpartum | 6 | Spain (Spanish) | OB-GYN | 3.2
Teng, 2005^120^ Fair | 199 | MINI DSM-IV diagnosis of any depressive disorder | Postpartum | 6 | Taiwan (Taiwanese) | Other Community | 10.1^*^
English PHQ
Mann, 2012^129^ Fair | 126 | DSM-IV interview using guidance from SCID for major or minor depression | Pregnant | 26-28 weeks gestation | United Kingdom | Other Clinical | 13.5^*^
Smith, 2010^130^ Fair | 213 | CIDI for MDD | Pregnant | < 17 weeks gestation | United States | OB-GYN | 6.1
Gjerdingen, 2009b128 Fair | 438 | SCID for MDD | Postpartum | 4 | United States | Pediatrics | 4.6

* Includes major and minor depression or any depressive disorder (e.g., MDD, minor depression, and persistent depressive disorder), not limited to MDD

Abbreviations: CIDI = Composite International Diagnostic Interview; DSM = Diagnostic and Statistical Manual; EPDS = Edinburgh Postnatal Depression Scale; ICD = International Classification of Diseases; MDD = major depressive disorder; MINI = Mini International Neuropsychiatric Interview; NP = non-patient; OB-GYN = obstetrics and gynecology; PHQ = Patient Health Questionnaire; PSE = Present State Examination; RDC = Research Diagnostic Criteria; SADS = Schedule for Affective Disorder and Schizophrenia; SCAN = Schedules for Clinical Assessment in Neuropsychiatry; SCID = Structured Clinical Interview for DSM Disorder; SPI = Standardized Psychiatric Interview.

Assessments took place in obstetrics/gynecology or other primary care clinics,69,101,109,116,125,126, 129,130 in pediatrics,128 or as part of a home-visit program for new mothers.100,118,119 Almost all of the studies of EPDS translations were conducted in the context of primary care settings (including obstetrics/gynecology).

#### Populations

Most of the English-language studies assessed women between 4 and 12 weeks postpartum, although one EPDS125 study and two PHQ128,130 studies assessed pregnant women and one EPDS study assessed women at any point during pregnancy or up to 6 months postpartum119 (Table 10). Similarly, most of the non-English EPDS studies also focused on the early postpartum period, but four targeted pregnant women.108,112,121,127 The average age in most studies of the English-language EPDS was mid-20s, and late-20s in the PHQ studies. Except for one trial limited to African American women, racial/ethnic minority populations were either not well represented (≤30%) or a race/ethnicity breakdown was not reported in the EPDS studies.119 This single study, which only included African American women enrolled in a home visitation program in a low-income urban community, was the only study of the English-language EPDS that included pregnant as well as postpartum women. Representation of racial/ethnic minorities was better in the PHQ studies, where the percent of white participants ranged from 57 to 67 percent. Only three English-version EPDS studies and one PHQ study reported on depression history in their sample, with 15 to 30 percent of women in these studies identified as having a previous history of depression.69,100,109,129 A history of other mental health or medical conditions were sparsely reported. In studies of EPDS translations, the average age was generally around 30 years and racial/ethnic background was rarely reported.

Table 10 Population Characteristics of Included Studies for KQ 2 (Pregnant and Postpartum Women)

Author, Year and Quality | Mean Age and Range (years) | Race/Ethnicity (%) | SES | Depression History, n (%)
English EPDS
Tandon, 2012^119^ Fair | 24.4 (NR) | Black: 100 Hispanic: NR White: NR | Single, n (%): 83 (95) | NR
Harris, 1989^116^ Fair | 24.6 (17-40) | NR | NR | NR
Clarke, 2008^126^ Fair | 23.8 (18-42) | NR | Family income <$10k, n (%): 61 (59) | Previous history of depression: 53 (51.5%)
Beck, 2001^109^ Fair | 31 (18-46) | Black: 8 Hispanic: 3.3 White: 86.7 | No HS diploma, n (%): 3 (2) | Previous history of depression: 25 (16.7%)
Morrell, 2009a100 Fair | NR (≥ 18) | Black: NR Hispanic: NR White: 95.3 | Rent council or housing association, n (%): 547 (13.4) | Previous pregnancy w/postnatal depression: 617 (15.1%)
Cox, 1996^101^ Fair | 25.4 (NR) | NR | Partner unemployed, n (%): 24 (10.3) | NR
Murray, 1990a125 Fair | 24.6 (NR) | NR | Unemployed partner, n (%): 16 (16) | NR
Leverton, 2000^118^ Fair | NR | NR | NR | NR
Non-English EPDS
Lee, 2001^117^ Fair | 29 (16-42) | Black: 0 Hispanic: 0 White: 0 | Unemployed, n (%): 13 (6) | NR
Chen, 2013^114^ Fair | 30.4 (19-43) | Black: 0 Hispanic: 0 White: 0 | Live in public housing, n (%): 469 (96) | NR
Guedeney, 1998^115^ Fair | 30.4 (20-42) | NR | Poor SES, n (%): 8 (9.19) | NR
Adouard, 2005^108^ Fair | 31.5 (23-46) | NR | Unemployed, n (%): 9 (15) | Past MDD episode: 3 (5%)
Toreki, 2013^121^ Good | 30.0 (17-42) | NR | Single, n (%): 2 (0.9) | NR
Toreki, 2014^122^ Fair | 30.5 (18-42) | NR | NR | NR
Benvenuti, 1999^110^ Fair | 31.9 (NR) | NR | Single, n (%): 3 (2.7) | NR
Carpiniello, 1997^113^ Fair | 31.6 (22-43) | NR | NR | Previous depressive episode: 1 (1.6%)
Yamashita, 2000^123^ Fair | 31 (19-41) | NR | III, IV, and V manual or unemployed partner occupation classification, n (%): 20 (23) | NR
Bunevicius, 2009a111 Fair | 29 (20-43) | NR | Employed or in school, n (%): 94 (100) | History of depression: 8 (8.5%)
Bunevicius, 2009b112 Fair | 29 (18-43) | NR | Unemployed, n (%): 37 (16.1) | History of depression: 24 (10.4%)
Felice, 2006^127^ Fair | 27.1 (15-34) | NR | Full or part-time work, n (%): 115 (48.1) | NR
Alvarado, 2014^124^ Fair | 25 (18-43) | NR | Unstable job, n (%): 9 (8.1) | NR
Garcia-Esteve, 2003^102^ Fair | 30.2 (NR) | NR | NR | NR
Teng, 2005^120^ Fair | 29 (16-41) | NR | Annual income < $300k NT, n (%): 6 (3.4) | NR
English PHQ
Mann, 2012^129^ Fair | 27.4 (≥ 18) | Black: 3.9 Hispanic: NR White: 56.6 | Never employed, n (%): 24 (15.8) | Self-reported ≥ 1 diagnosed episode of depression: 24 (15.8%)
Smith, 2010^130^ Fair | 28.9 (≥ 17) | Black: 20.1 Hispanic: 9.8 White: 63.1 | Education 1-11 years, n (%): 36 (16.8) | NR
Gjerdingen, 2009b128 Fair | 29.1 (≥ 12) | Black: 17.6 Hispanic: 2.8 White: 67 | Total family income < $20k, n (%): 133 (27.3) | NR

Abbreviations: EPDS = Edinburgh Postnatal Depression Scale; HS = high school; MDD = major depressive disorder; NR = not reported; NT = New Taiwan; PHQ = Patient Health Questionnaire; SES = socioeconomic status.

#### Quality Assessment

We rated a single study as good quality121 and the remaining studies as fair quality. Studies were generally quite small; 72 percent of all 2×2 tables had five or fewer false negatives, which was usually the smallest cell of the 2×2 table of true positives, false positives, false negatives, and true negatives. Only 12 percent of all 2×2 tables had more than 10 false negatives. The screening instruments were administered as paper-and-pencil tests and the diagnostic interview usually occurred the same day. Two of the English-version studies, however, did not report the time between the EPDS and the interview.69,100 In one of these studies, the EPDS was likely not administered the same day, since the interviewers began scheduling the assessment after receiving notification that the EPDS was completed.100 While most studies conducted diagnostic interviews with all participants completing the EPDS, three studies only interviewed a random sample of those who scored below a certain cutoff on the EPDS,100-102 including two of the English-language EPDS studies.100,101 When studies did use a random sample, we extrapolated using the process described above in the Methods section. We did not use specificity data from one trial that did not report sufficient data to extrapolate.100 Only half of the studies described training of diagnostic interviewers, and fidelity or quality assurance procedures for the diagnostic interviews was rarely reported. Most studies completed the diagnostic interview after the EPDS, and most reported that the interviewer was blind to the EPDS results.

#### Findings

While most studies reported performance characteristics across a wide range of EPDS thresholds (Appendix D Table 8), we primarily focus our results on the cutoffs of 10 or greater and 13 or greater, which are most widely cited as the usual cutoffs and were among the most widely reported cutoffs in this body of literature. A cutoff of 13 would typically be used for identifying MDD, while the lower cutoff would be useful for picking up minor depression or other depressive disorders in addition to MDD. The sensitivities and specificities, including all cutoffs for any language version of the EPDS, are shown in Appendix D Figures 2–5 for MDD and separately for depressive disorders broadly, including major and minor depression, and may also include persistent depressive disorder, adjustment disorder with depressive features, and depression not otherwise specified.

##### EPDS Cutoff of 13 or Greater

Sensitivity and specificity of the English-language EPDS using the cutoff of 13 or greater are shown in Figure 5. For identifying MDD, sensitivity ranged from 0.67 (95% CI, 0.18 to 0.96)118 to 1.00 (95% CI, 0.67 to 1.00),125 with most falling between 0.75 and 0.82. Sensitivity for detecting MDD ranged from 0.78 to 0.81 in the two trials conducted in the United States,109,119 including the recently published study in low-income African American women.119 The largest study, from the United Kingdom, similarly reported sensitivity of 0.79 (95% CI, 0.72 to 0.85).100 In this study, sensitivity for MDD of any severity (0.79 [95% CI, 0.72 to 0.85]) was similar to that for moderate to severe MDD (0.85 [95% CI, 0.76 to 0.95]).100 Thus, our best estimate for average sensitivity in the United States with a cutoff of 13 is approximately 0.80.

Figure 5 Sensitivity and Specificity of the EPDS (KQ 2)

* Data are extrapolated from partial verification.

Abbreviations: EPDS = Edinburgh Postnatal Depression Scale; CI = confidence interval; FN = false negative; FP = false positive; MDD = major depressive disorder; PP = postpartum; preg = pregnant; Ref Std = reference standard; TN = true negative; TP = true positive.

This figure plots the sensitivity and specificity of the English-version Edinburgh Postnatal Depression Scale (EPDS) using a cutoff of 13 or greater for screening pregnant and postpartum women for major depressive disorder or major/minor depression.

Specificity ranged from 0.87 (95% CI, 0.79 to 0.93)125 to 0.99 (95% CI, 0.97 to 1.00)109 for MDD with the English-language EPDS. Specificities in the two largest trials ranged from 0.90^118^ to 0.93.^101^

For the English-language versions of the EPDS, we estimated the PPV for detecting MDD to be 47 percent in a population with an MDD prevalence of 10 percent (Table 11), assuming a sensitivity of 0.80 (consistent with the largest and U.S.-based studies) and specificity of 0.90 (approximate mid-range of all studies). PPV would be 59 percent in a population with MDD prevalence of 15 percent, under the same assumptions. NPV was estimated at 96 percent or greater under both scenarios shown in Table 11.

Table 11 Calculated Positive and Negative Predictive Values of Included Studies for KQ 2 (Pregnant and Postpartum Women), Based on Best Estimates of Sensitivity and Specificity of the English-Language EPDS

EPDS Cutoff | Sensitivity | Specificity | Prevalence^‡^ | PPV | NPV
13 (MDD)^*^ | 0.80 | 0.90 | 0.10 | 0.47 | 0.98
13 (MDD)^*^ | 0.80 | 0.90 | 0.15 | 0.59 | 0.96
10 ( depressive disorders)^†^ | 0.63 | 0.85 | 0.10 | 0.32 | 0.95
10 ( depressive disorders)^†^ | 0.84 | 0.85 | 0.10 | 0.38 | 0.98
10 ( depressive disorders)^†^ | 0.63 | 0.85 | 0.15 | 0.43 | 0.93
10 ( depressive disorders)^†^ | 0.84 | 0.85 | 0.15 | 0.50 | 0.97

* For a cutoff of ≥13 (MDD): a) sensitivity of 0.80 chosen based on three studies that include the largest study and the two conducted in the United States100,109,119; b) specificity chosen as estimated mid-range range across all studies of English-language versions, which ranged from 0.88 to 0.99, with most clustered between 0.88 and 0.93.

† For cutoff of ≥10 (depressive disorders): a) sensitivity estimates are highest and lowest reported among those used to detect depressive disorders, including major or minor depression; b) specificity chosen as mid-range of all studies, which ranged from 0.79 to 0.90 and was fairly evenly distributed.

‡ Lower prevalence estimate chosen based on MDD prevalence in 2004–2005 NESARC data in postpartum women, high estimate based on 50% increase from that.

Abbreviations: EPDS = Edinburgh Postnatal Depression Scale; MDD = major depressive disorder; NPV = negative predictive value; PPV = positive predictive value.

While sensitivity was wide-ranging for non-English versions of the EPDS, the Spanish version showed acceptable performance characteristics (Figure 5). The sensitivity in one study conducted in Spain was 0.86 (95% CI, 0.72 to 0.94),102 but was only 0.76 (95% CI, 0.61 to 0.88) in a smaller (n=111) study conducted in Chile with a very high depression prevalence (34%).124 The Hungarian, Italian, and Spanish versions all reported high specificity (usually ≥0.95) with the cutoff of 13 or greater.

##### EPDS Cutoff of 10 or Greater

Sensitivity and specificity of the English-language EPDS for detecting depressive disorders, including both major and minor depression, using the cutoff of 10 or greater are shown in Figure 5. Sensitivity ranged from 0.63 (95% CI, 0.44 to 0.79)101 to 0.84.^119,126^ Sensitivity from the trial conducted in the United States was 0.84 (95% CI, 0.69 to 0.94).119 Specificity ranged from 0.79 (95% CI, 0.64 to 0.90)119 to 0.90 (95% CI, 0.86 to 0.93).101 Using a cutoff of 10 or greater in the English-language version of the EPDS, PPV was 50 percent in only the higher-prevalence (15%) scenario if we assume an optimistic sensitivity of 0.84 (largest study, U.S.-based) and specificity of 0.85 (mid-range of all estimates) (Table 11).

While sensitivity was wide-ranging across non-English translations at a cutoff of 10, the Spanish version performed well in Spain with a sensitivity of 0.89 (95% CI, 0.82 to 0.94) and specificity of 0.93 (95% CI, 0.92 to 0.95).102 Specificity for these tools was above 0.90 for five of the seven non-English versions reporting this comparison.

##### PHQ Instruments

The PHQ studies covered three different versions of the PHQ (PHQ-2, PHQ-8, and PHQ-9) and three different scoring methods for the PHQ-2, shown in Figure 6. Two studies used MDD as the comparator128,130 and the third assessed the accuracy of the PHQ-2 (with “yes/no” response categories) for detecting major or minor depression.129

Figure 6 Sensitivity and Specificity of the PHQ Instruments (KQ 2)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; MDD = major depressive disorder N = number; PHQ = Patient Health Questionnaire; PP = postpartum; preg = pregnant; Ref Std = reference standard; TN = true negative; TP = true positive..

This figure plots the sensitivity and specificity of the English-version Edinburgh Postnatal Depression Scale (EPDS) using a cutoff of 10 or greater for screening pregnant and postpartum women for major depressive disorder or major/minor depression.

One study reported sensitivity of 0.77 (95% CI, 0.50 to 0.93) and specificity of 0.62 to 0.68 for the PHQ-8 at two different cutoffs in pregnant women up to 17 weeks' gestation.130 Sensitivity of the PHQ-9 in women who were 4 weeks postpartum was similar in another study (0.75 [95% CI, 0.54 to 0.90]), but specificity was better (0.91 [95% CI, 0.88 to 0.93]).128 The PHQ-8 is identical to the PHQ-9 except that it does not include the item related to suicide.

For the PHQ-2, both studies using MDD as the reference standard used Likert-type response categories that ranged from 0 (not at all) to 3 (nearly every day), similar to the PHQ-8 and PHQ-9. From this, the study of pregnant women summed scores in typical fashion and reported sensitivity and specificity at cutoffs of 3 and 4.^130^ Sensitivities were 0.77 (95% CI, 0.50 to 0.93; cutoff of 3) and 0.62 (95% CI, 0.35 to 0.84; cutoff of 4). Specificities were 0.59 (95% CI, 0.52 to 0.66; cutoff of 3) and 0.79 (95% CI, 0.73 to 0.84; cutoff of 4). The study in postpartum women reported scores for two alternate “yes/no” approaches: one where a response of 2 (more than half the days) or 3 (nearly every day) was consider “yes,” and a second approach where participants were simply asked to respond “yes” or “no.”128 Sensitivities were 0.75 (95% CI, 0.54 to 0.90; Likert response categories) and 1.00 (95% CI, 0.88 to 1.00; “yes/no” response categories) and specificities were 0.88 (95% CI, 0.85 to 0.91; Likert response categories) and 0.62 (95% CI, 0.57 to 0.67; “yes/no” response categories). Relative to major or minor depression, a third study reported sensitivity of 1.00 (95% CI, 0.86 to 1.00) and specificity of 0.68 (95% CI, 0.59 to 0.76) in pregnant women at 26 to 28 weeks' gestation.129

### KQ 2a Do the Test Performance Characteristics of the Screening Instruments Vary By Population Characteristics?

We found no studies that reported performance characteristics separately for subgroups based on age, race/ethnicity, comorbid conditions, or new-onset versus recurrent depression.

### KQ 3 What Are the Harms Associated With Primary Care Depression Screening Programs in Pregnant and Postpartum Women?

Among the trials addressing benefits of screening, the trial that focused most narrowly on the effects of screening alone reported that there were no adverse effects of screening in postpartum women.105 In addition, none of the KQ 1 or 1a trials showed paradoxical effects of concern. We found no additional trials addressing harms of screening beyond those included for benefits of treatment.

### KQ 3a Do the Harms Vary By Population Characteristics?

We found no evidence on harms of screening, so we could not evaluate variability in harms by population characteristics (e.g., sex, age, race/ethnicity, comorbid conditions, new-onset vs. recurrent depression).

### KQ 4 Does Treatment Result in Improved Health Outcomes in Pregnant and Postpartum Women Who Screen Positive for Depression in Primary Care?

#### Study Characteristics

We identified 18 trials that examined the benefits of interventions in pregnant or postpartum women who had screened positive for depression in primary care or community settings (Table 12), usually compared with usual care. These trials were published between 1989 and 2014. Seven of these trials were conducted in North America,131,136,141,147,156,157,160 seven were conducted in Europe,133,135,139,140,145,154,155 three were conducted in Australia,148,149,153 and one was conducted in Taiwan.138 The total number of women randomized across all studies was 1,638. There was only one large trial (n=1,762 randomized).145 This study, however, combined treatment in women with depression and prevention in women without depression. We only included results related to the subgroup with depression (n=324). The remaining trials were small or moderately sized (<50 per group, often <30 per group). The EPDS was the most common instrument used for screening, with cutoff scores used for eligibility ranging from 9 to 13. The proportion of women screening positive for depression at recruitment varied from 6 to 30 percent. Followup periods also varied widely, from 6 weeks138,154 to 18 months.135 Further, trials varied in time between end of treatment and followup assessment, with seven trials conducting followup assessment within 2 weeks of when treatment ended,133,136,141,148,149,154,160 while the remaining had at least one assessment with a lag of 1 to 7 months between end of treatment and followup assessment.

Table 12 Study Characteristics of Included Studies for KQ 4 (Pregnant and Postpartum Women)

Author, Year Quality | Design | N | Intervention | Weeks Postpartum at Baseline | Followup (mo) | Country | Setting | Invited to Screen (% Screened) | % Screened Positive for Depression | Definition of Screened Positive
CBT or Related Interventions
McGregor, 2013^147^ Fair | CCT | 42 | CBT | 22 weeks gestation | 4, 6 | Canada | Primary Care | 153 (96.1%) | 30.6 | EPDS > 9
Milgrom, 2011b149 Fair | RCT | 68 | CBT | 16 | 2 | Australia | Primary Care + Psychology Clinic | NR | 9.4 | EPDS ≥ 13
Cooper, 2003^135,273^ Good | RCT | 193 | CBT or psychodynamic or non-directive counseling | 0 | 4, 9, 18 | United Kingdom | Other Community | NR | 6.4 | EPDS ≥12 and systematically assessed as depressed
Prendergast, 2001^153^ Fair | RCT | 37 | CBT | 10 | 1.5, 8 | Australia | Primary Care | NR | NR | EPDS >12 and meeting DSM-IV major and minor depression criteria
O'Mahen, 2013^160^ Fair | RCT | 55 | CBT | 31 weeks gestation | 4 | United States | OB-GYN/Home-based | 2382 (51.3%) | 16.5 | EPDS ≥ 12
Kozinzky, 2012^145^ Good | RCT | 324 | CBT - Related | 27 weeks gestation | 4.75 | Hungary | Primary Care | 2160 (81.6%) | 18.4 | Leverton Questionnaire score ≥11/12
Ammerman, 2013^131,274-277^ Fair | RCT | 93 | CBT - Related | 12 | 4.75, 7.75 | United States | Other Community | 1768 (70.1%) | 24.7 | EPDS ≥11
Honey, 2002^140^ Fair | RCT | 45 | CBT - Related | 22 | 2, 8 | United Kingdom | Primary Care | NR | NR | EPDS >12
Milgrom, 2005^148^ Fair | RCT | 192 | CBT (Coping with Depression Course) or CBT - Related | 12 | 12 | Australia | Other Community | NR | 12.8 | EPDS ≥12
Wiklund, 2010^155^ Fair | RCT | 67 | CBT | 0 | 2.75 | Sweden | Primary Care | 437 (67.3%) | 22.8 | EPDS ≥12 at 4 weeks postpartum
Other Behaviorally-Based Interventions
Holden, 1989^139^ Fair | RCT | 55 | Non-directive counseling | 10 | 3.25 | United Kingdom | Primary Care | NR | 8.2 | EPDS >12/13 6 weeks after delivery and met diagnostic criteria about 12 weeks after delivery
Wickberg, 1996^154^ Fair | RCT | 41 | Non-directive counseling | 12 | 1.5 | Sweden | Primary Care | 1874 (88.3%) | 5.7 | EPDS ≥12 twice (2 and 3 months postpartum)
Segre, 2014^156^ Fair | RCT | 66 | Non-directive counseling | NR | 2 | United States | Primary Care/Home Visits | NR | NR | EPDS score ≥12
Goodman, 2014^157^ Fair | RCT | 42 | Perinatal dyadic psychotherapy | 5 | 3, 6 | United States | Home Visits | NR | 7.3 | EPDS score 10-19 at 4-6 weeks postpartum
Heh, 2003^138^ Fair | RCT | 70 | Information support | 6 | 1.5 | Taiwan | Primary Care | 500 (81.4%) | 20 | EPDS ≥10
Horowitz, 2001^141^ Fair | RCT | 122 | Interaction coaching | 6 | 1.5, 2.5 | United States | Other Community | NR | 10.0 | EPDS ≥10 at 2-4 weeks postpartum
Stepped Care
Gjerdingen, 2009^136^ Fair | RCT | 39 | Stepped care | 0 | 9 | United States | Primary Care | 1556 (32.5%) | 8.9 | SCID within 2 weeks of the 0-1 month survey; either a positive 2-question depression screen or 9-item PHQ-9 at a later interval; SCID-positive 0-6 months postpartum
Antidepressants
Appleby, 1997^133^ Fair | RCT | 87 | Fluoxetine + CBT | 7 | 3 | United Kingdom | Other Community | 2978 (80.4%) | 21 | EPDS ≥10

Abbreviations: CBT = cognitive behavioral therapy; DSM = Diagnostic and Statistical Manual; EPDS = Edinburgh Postnatal Depression Scale; MADRS = Montgomery Asberg Depression Rating Scale; PHQ = Patient Health Questionnaire; RCT = randomized controlled trial; SCID = Structured Clinical Interview.

#### Populations

Fifteen of the 18 included studies recruited women during the postpartum period, usually 6 to 12 weeks postpartum. Only three studies recruited women during pregnancy.145,147,160 All studies reported outcomes during the postpartum period. All but two of the studies reported mean maternal age, which ranged from 22 to 32 years (Table 13). Only five studies reported race/ethnicity data, and 31 to 69 percent of the participants in these studies were white.131,141,156, 157,160 Fewer than half of the studies described the participants' depression history, and the type of information on depression history they provided varied considerably across studies. For example, reports of prior history of depression or major depression ranged from 30 to 76 percent, history of recurrent or chronic depression ranged from 21 to 74 percent, and prior treatment for depression ranged from 16 to 46 percent. Three studies described history of anxiety disorders, which was reported in 11 to 48 percent of the study population.131,157,160 None of the studies reported other medical conditions or substance abuse history. Many treatment studies excluded women with the most severe depression, such as those with a history of psychosis, current suicidal ideation, or need for crisis management.131,133,140,147-149,155-157,160 Two trials also excluded women who were taking psychotropic medications,131,147 and four excluded patients with substance abuse disorders.131,133,156,160 In addition, a few studies were limited to women with no perinatal complications, preterm birth, or major congenital fetal abnormalities.

Table 13 Population Characteristics of Included Studies for KQ 4 (Pregnant and Postpartum Women)

Author, Year Quality | Mean Age and Range (years) | Race/Ethnicity (%) | SES | Depression History including Medication Use, n (%)
CBT or Related Interventions
McGregor, 2013^147^ Fair | NR (≥ 16) | NR | Annual household income $0-$19,999, n (%): 3 (7.1) | Past depression: 18 (42.9%) Current use of antidepressants: 0 (0%)
Milgrom, 2011b149 Fair | 31.5 (NR) | NR | Income < $40k, n (%): 13 (19.1) | NR
Cooper, 2003^135^ Good | 27.7 (17-42) | NR | High social disadvantage, n (%): 47 (24.7) | NR
Prendergast, 2001^153^ Fair | 32.2 (NR) | NR | Married, n (%): 34 (92) | Past treatment (had some form of counseling): 17 (45.9%) SSRI (not specified) use: 1 (2.7%)
O'Mahen, 2013^160^ Fair | 27.0 (18-43) | Black: 58.2 Hispanic: NR White: 30.9 | Income < $10k, n (%): 8 (15.7) | Currently receiving depression treatment: 0 (0%)
Kozinzky, 2012^145^ Good | 27.3 (NR) | NR | Primary education, n (%): 230 (13.1) | NR
Ammerman, 2013^131^ Fair | 21.9 (16-37) | Black: 32.2 Hispanic: 7.5 White: 62.4 | Income < $10k, n (%): 52 (55.9) | Recurrent depression: 69 (74.2%)
Honey, 2002^140^ Fair | 27.9 (NR) | NR | Married/cohabiting, n (%): 35 (77.8) | NR
Milgrom, 2005^148^ Fair | 29.7 (NR) | NR | Family income, mean (SD): 41400 (20500) | NR
Wiklund, 2010^155^ Fair | NR | NR | Married, n (%): 64 (95.5) | Treatment for depression (not specified): 11 (16.4%)
Other Behaviorally- Based Interventions
Holden, 1989^139^ Fair | 26.2 (NR) | NR | Single, n (%): 3 (6) | Previous depression: 21 (42%)
Wickberg, 1996^154^ Fair | 28.4 (NR) | NR | Educational level on Hollingshead Scale, mean: 3.5 | Previous depression: 15 (36.6%)
Segre, 2014^156^ Fair | 26.3 (≥ 14) | Black: 33.3 Hispanic: 40.9 White: 33.3 | Annual income < $5k, n (%): 10 (15.1) | MDD diagnosis: 20 (30.3%) Medication use for mood management: 11 (16.7%)
Goodman, 2014^157^ Fair | 30.7 (NR) | Black: NR Hispanic: 23.8 White: 59.5 | Income < $40k, n (%): 5 (11.9) | Major or minor depression, n (%): 13 (31%) Depression treatment, n (%): 0 (0%)
Heh, 2003^138^ Fair | 27.1 (20-35) | NR | Monthly family income $30,000-$60,000, n (%): 9 (12.9) | NR
Horowitz, 2001^141^ Fair | 31 (17-41) | Black: 7.4 Hispanic: 7.4 White: 68.9 | Annual household income < $50k, n (%): 35 (29) | NR
Stepped Care
Gjerdingen, 2009^136^ Fair | 27.6 (≥ 16) | NR | Total family income < $40,000, n (%): 29 (74.4) | NR
Antidepressants
Appleby, 1997^133^ Fair | 25.3 (NR) | NR | Unemployed, n (%): 66 (75.9) | History of postnatal depression: 30 (34.5%)

Abbreviations: CBT = cognitive behavior therapy; NR = not reported; SD = standard deviation; SES = socioeconomic status.

#### Depression Interventions

The included trials utilized several different types of behavioral interventions (Appendix D Table 9), and two trials tested multiple approaches in different intervention arms.135,148 The most commonly studied approach was CBT or related interventions that included traditional CBT components, such as stress management, goal setting, and problem solving. The trials conducted with pregnant women investigated CBT147,160 and CBT-related145 interventions. Other approaches to psychotherapy included nondirective counseling135,139,154,156 and psychodynamic therapy.135,136 One intervention targeted mother-baby interactions with the goal of increasing a mother's responsiveness to her baby's cues.141 Another trial addressed mother-baby interactions while also providing psychotherapy to the mother.157 Behavioral interventions were between 1 and 3 months duration, except one intervention that lasted almost 5 months.131 One trial studied a stepped-care intervention that involved referral to the primary care provider, patient information, a care manager who had regular telephone contact with the participant, and, if needed, consultation with or referral to mental health providers, who utilized a variety of psychotherapeutic methods as would be found in typical community-based care, including psychiatry referral for evaluation or medication adjustment.136 Only one trial examined antidepressant medication, comparing fluoxetine with placebo, with adjunctive CBT in both treatment arms.133

Interventions were most often delivered by mental health providers (e.g., therapists, psychologists, psychiatrists, or social workers), medical providers (i.e., physicians, nurses, or midwives), or home health visitors. Treatment intensity, defined as the estimated total hours of exposure to active intervention, varied widely across studies and ranged from printed material only138 to 21 hours of individual or group contact.155 Within the general therapeutic approach (e.g., CBT or other behavioral-based interventions), treatment outcome tables and forest plots were organized in order of increasing treatment intensity to better elucidate the potential effects of treatment intensity on outcomes. Fewer than half of the studies reported treatment adherence data. Using the most stringent definition (i.e., completion of all planned sessions), adherence ranged from 23.3 to 100 percent in the studies reporting those data, with fewer participants achieving perfect attendance as the number of sessions increased.131,135,136,139,140,147,149,153,160

#### Quality Assessment

We rated 16 of the trials as fair quality and two as good quality.135,145 Two of the fair-quality studies generally had good methods with adequate followup, but were small in size and had one or more concerns about randomization, baseline differences between groups, or differential attrition between groups.131,147 The remaining studies exhibited multiple methodological concerns, including small sample sizes, followup less than 90 percent, poorly described inclusion/exclusion criteria, inadequate allocation concealment or blinding of outcome assessment, intervention not manualized or well described, or inadequate intervention fidelity.

#### Findings

##### Depression Outcomes

Fifteen of the 18 trials reported an outcome similar to depression remission at followup ranging from 1.5 to 18 months (Appendix D Table 10). While most trials reported the proportion scoring below a specified cutoff on a depression symptom scale, two trials conducted diagnostic interviews to confirm clinical remission.131,135 We grouped these outcomes together and refer to them as “remission.” However, we were unable to truly estimate absolute remission rates. Figure 7 shows a forest plot of remission rates (according to the study's definition), ordered by increasing intensity (estimated hours) of the intervention and grouped by general therapeutic approach. Sixteen of the trials also reported a continuous score on a screening/symptom rating scale, including the EPDS, the PHQ-9, and Beck Depression Inventory (BDI) instruments (Appendix D Table 10); however, three of these did not report measures of dispersion that allowed us to calculate standardized effect sizes.135,154,155 Figure 8 shows a forest plot of mean differences between groups in symptom score changes from baseline. Studies missing measures of dispersion are shown as dots only.

Figure 7 Forest Plot of Depression Remission or Response in Pregnant and Postpartum Women (KQ 4)

* Pregnant women only.

Abbreviations: CBT = cognitive behavioral therapy; CG = control group; CI = confidence interval; est = estimated; IG = intervention group; RR = relative risk.

This figure displays a forest plot of depression remission or response in pregnant and postpartum women after depression treatment by cognitive behavioral or related therapy, non-directive counseling, psychodynamic therapy, other psychotherapy, information only or stepped care.

Figure 8 Forest Plot of Changes in Depression Scores in Pregnant and Postpartum Women (KQ 4)

Abbreviations: BDI = Beck Depression Inventory; BL = baseline; CBT = cognitive behavioral therapy; CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; est = estimated; IG = intervention group; PHQ = Patient Health Questionnaire; SD = standard deviation; SE = standard error; WMD = weighted mean difference.

This figure displays a forest plot of changes in depression symptom scores in pregnant and postpartum women after depression treatment by cognitive behavioral or related therapy, non-directive counseling, psychodynamic therapy, other psychotherapy, information only, stepped care, or antidepressant therapy.

Results for CBT. All 10 trials of CBT or related interventions showed an increased likelihood of remission with treatment in the short term, although not all results were statistically significant.131,135,140,145,147-149,153,155,160 Results were similar for pregnant and postpartum women. Most trials followed participants for only 7.8 months or less, and none showed a benefit beyond 7.8 months followup. Pooled results that used only the longest followup period within 1 year and selected the treatment arm that adhered most purely to CBT principles, if multiple treatment arms were tested, showed a 34 percent increase in the likelihood of remission with CBT (DerSimonian and Laird pooled RR, 1.34 [95% CI, 1.19 to 1.50]; k=10; I^2^=7.9%) compared to usual care. Results were almost identical in sensitivity analysis using a more conservative pooling method, with even lower statistical heterogeneity (restricted maximum likelihood with Knapp-Hartung modification pooled RR, 1.34 [95% CI, 1.17 to 1.53]; k=10; I^2^=0%). Although most evidence was in postpartum women, all three trials in pregnant women (shown with an asterisk in Figure 7) were consistent with the trials in postpartum women, with RRs of 1.25 or greater, although only one of these was statistically significant. While it appeared that increased hours of contact may have been associated with larger effect sizes, larger effect sizes were also generally observed in studies with lower control group remission rates and smaller sample sizes. In fact, control group remission rates, contact hours, sample size, and time to followup were all confounded with each other, and we could not draw conclusions about their relative importance. However, despite heterogeneity in important areas such as country, specific implementation of CBT, specific measures reported, and time between end of treatment and followup assessment, it is somewhat reassuring that effects were relatively consistent across studies. Visual inspection of the funnel plot for the 10 pooled trials did suggest an increased risk of small study bias, which suggests an increased risk of publication bias; however, the Egger test did not confirm this (p=0.27).

The two good-quality studies had the smallest135 and third smallest145 effects among the CBT intervention arms, although the latter, which was also the largest included study, showed a statistically significant benefit (RR, 1.36 [95% CI, 1.13 to 1.65]). Among the studies conducted in the United States, one was a recently published study in high-risk women (unmarried, low income, age ≤18 years, or inadequate prenatal care) who were part of a home visit program and met criteria for MDD at 3 months postpartum.131 These women also had high rates of comorbid mental health conditions. Women in the CBT arm had a 47 percent increased likelihood of remission (RR, 1.47 [95% CI, 1.10 to 1.95]) and showed greater improvement in depressive symptoms and global assessment of functioning at both 4.5 and 7.5 months followup. The other U.S.-based trial reported a smaller statistically nonsignificant effect on the probability of having a BDI score less than 14 at 4-month followup.160 Both of these studies showed greater reductions in depressive symptom scores at followup.

Results for the outcome of continuous symptom score showed a similar pattern (Figure 8), although only seven of the trials were available for pooling.131,140,147-149,153,160 All of the trials showed greater symptom reduction in the intervention groups. Results were not statistically significant in three trials;147,149,153 however, unadjusted mean differences were statistically significant in one of these, as shown in Figure 8.^153^ EPDS scores declined by an average of two to six points in usual care compared with five to 10 points in intervention groups. The pooled standardized mean difference in change between groups was -0.82 (95% CI, -1.10 to -0.54; k=7; I^2^=35.4%), which is consistent with a medium to large effect size according to Cohen's rules of thumb.168 Average baseline EPDS scores were generally at or above the cutoff of 13 (above the screening cutoff for identifying MDD), and at followup, most CBT group averages were below 10 (below the screening cutoff for identifying minor or major depressive disorder), which put them in the mild depressive symptom range, on average. Some studies also showed average EPDS scores below 10 at followup, with usual care treatment at followup as well,147,153 but others remained above 10 in contrast to intervention groups131,155 or showed mixed results over time.135 Other instruments showed comparable results.

Results for other approaches. NonCBT approaches were highly variable in their effects and limited by lack of replication of intervention approaches.133,135,136,138,139,141,154,157 We were unable to draw firm conclusions about other approaches based on included trials, including the trials of fluoxetine and the stepped-care intervention. Effect sizes in these trials also appeared to be related to intervention intensity, such that participants who received more hours of treatment demonstrated the greatest reduction in depression symptoms; however, again we were unable to disentangle the effects of intervention approach, contact hours, study size, and control group response rate (a likely indicator of underlying population risk).

The U.S.-based study of the stepped care intervention was highly applicable, but did not find beneficial results.136 Its intervention included biweekly phone followup with a care manager after treatment initiation, decision support for the provider, patient materials, and specialty care available if needed. Although a greater number of the stepped care participants received treatment, no differences were seen in depression symptoms, depression remission, general health and mental health ratings, or functioning. In fact, a greater proportion of the usual care participants no longer screened positive for depression at followup than stepped-care participants (56% remission with stepped care vs. 72% usual care; p=0.48). This was a very small study (n=34), with statistically nonsignificant but potentially important differences at baseline such that the intervention group was more likely to be low income (proportion with family income <$40,000 was 85% in the intervention group vs. 65% in the control group), on medical assistance (83% in the intervention group vs. 53% in the control group), and unmarried (74% in the intervention group vs. 60% in the control group).

Other beneficial outcomes. Several trials reported other outcomes, including measures of general psychological functioning or quality of life,131,156 anxiety,147,149,157 functional health,136 maternal and infant health care utilization,136 interpersonal support,131,148 and mother-infant interactions (Appendix D Tables 11–13).141,157 Of these, only two studies reported significant findings, although small sample sizes may have limited power to find group differences in the remaining studies.131,148 Women in the treatment groups demonstrated better scores on measures of psychological functioning, interpersonal support, and global assessment of functioning at followup (data not shown). Although these two studies were also higher in treatment intensity (15 to 18 hours) than most of the other studies, lack of complete reporting for outcomes across varying intensity among studies limits any interpretation from this observation.

### KQ 4a Do the Effects of the Interventions Vary By Population Characteristics?

We were unable to examine variability in benefit by our a priori population characteristics. No subgroup analyses were reported by age, race/ethnicity, comorbid conditions, or new-onset depression versus recurrent depression.

### KQ 5 What Are the Harms of Treatment in Pregnant and Postpartum Women Who Screen Positive for Depression in Primary Care?

#### Behavioral-Based Interventions

None of the trials addressing benefits of behavioral-based interventions reported on harms of treatment. In addition, none of the trials showed paradoxical effects of concern. We found no additional trials addressing harms of behavioral-based interventions beyond those included for benefits of treatment.

#### Antidepressants

We found only one trial of antidepressants conducted in postpartum women with screen-detected depression that reported adverse events.133 The remaining evidence was not limited to those whose depression was detected through screening and is discussed under KQ 5b. The trial in screen-detected women compared the short-term effects of fluoxetine plus CBT versus placebo plus CBT. At 12 weeks followup, one of the 43 (2.3%) women taking fluoxetine discontinued due to adverse effects compared to three of the 44 (6.8%) taking the placebo.

### KQ 5a Do the Harms Vary By Population Characteristics?

We were unable to examine variability in benefit by our a priori population characteristics. No subgroup analyses were reported by age, race/ethnicity, comorbid conditions, or new-onset depression versus recurrent depression.

### KQ 5b What Is the Prevalence of Other Selected Serious Harms of Treatment With Antidepressants in the General Population of Pregnant and Postpartum Women?

#### Study Characteristics

We identified one good-quality comprehensive AHRQ-sponsored systematic review91 that included studies published between 1996 and 2013, supplemented with 12 additional unique fair- to good-quality observational studies published between 2012 and 2014 that examined the harms of antidepressants in pregnant or postpartum women (Table 14).132,134,137,142-144,146,150-152,158,159 The AHRQ review examined the comparative effectiveness and safety of antidepressant treatment for depression in pregnant and postpartum women. This review found no RCTs of harms of antidepressants in pregnant women, but did include 15 observational studies that provided evidence of harms of antidepressants at unknown dosages in pregnant women with depression, considered “direct evidence” in the AHRQ review. The review included an additional 109 observational studies that provided evidence of harms of antidepressants in pregnant women whose depression status in either or both treatment arms was unknown, considered “indirect evidence.” The review did not find evidence related to harms in postpartum women. One third of studies in the AHRQ review were conducted in the United States.

Table 14 Study Characteristics of Included Observational Studies for KQ 5 (Pregnant Women)

Author, Year Quality | Study Design | N | Country | Pertinent Outcomes | Pertinent Agents | Exposure Groups | Exposure Group Description
Palmsten, 2013a151 Good | Cohort | 85,326 | United States | Preeclampsia | 2^nd^ generation AD | Exposed (n=26,107) | AD dispensing between gestational days 90-225
Palmsten, 2013a151 Good | Cohort | 85,326 | United States | Preeclampsia | 2^nd^ generation AD | Nonexposed (n=59,219) | No AD dispensed between LMP and gestational day 225, OR first preeclampsia diagnosis occurred before first AD dispensing
Palmsten, 2013b150 Good | Cohort | 102,722 | United States | Postpartum hemorrhage | 2^nd^ generation AD | Current exposure (n=14,205) | Women w/ a supply of antidepressants that overlapped w/ delivery date
Palmsten, 2013b150 Good | Cohort | 102,722 | United States | Postpartum hemorrhage | 2^nd^ generation AD | Recent exposure (n=6,925) | Women w/ a supply of AD on at least 1 day in the month before delivery date but not on a delivery date
Palmsten, 2013b150 Good | Cohort | 102,722 | United States | Postpartum hemorrhage | 2^nd^ generation AD | Past exposure (n=12,548) | Women w/ a supply of AD ending between 5 and 1 months before delivery
Palmsten, 2013b150 Good | Cohort | 102,722 | United States | Postpartum hemorrhage | 2^nd^ generation AD | Nonexposed (n=69,044) | Women who had no supply of AD in the 5 months before delivery
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Exposed (first trimester) (n=427) | Women who used SSRI or SNRI during first trimester
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Exposed (second trimester) (n=222) | Women who used SSRI or SNRI during second trimester
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Exposed (week 30 to birth) (n=123) | Women exposed to SSRI or SNRI from week 30 to childbirth
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Depressed- nonexposed (n=1,282) | Depressed women as assessed at both 17 and 30 weeks gestation with no AD use during any trimester of pregnancy
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Not depressed- nonexposed (n=55,411) | Women without diagnosed depression during pregnancy and no AD use during pregnancy
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Nonexposed (first trimester) (n=55,533) | Women with no AD use during the first trimester of pregnancy; may have had exposure in 2^nd^ and 3^rd^ trimesters
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Nonexposed (second trimester) (n=55,750) | Women with no AD use during the second trimester of pregnancy; may have had exposure during 1^st^ and 3^rd^ trimesters
Lupattelli, 2014^146^ Fair | Cohort | 57,220 | Norway | Postpartum hemorrhage, vaginal bleeding | 2^nd^ generation AD | Nonexposed (week 30 to birth) (n=55,862) | Women not exposed to AD from week 30 of pregnancy to childbirth
Andersen, 2014^132^ Good | Cohort | 1,279,840 | Denmark | Miscarriage | SSRI | Exposed (n=22,884) | Pregnant women exposed to any SSRI during the first 35 days of pregnancy and with continuous exposure pre-pregnancy.
Andersen, 2014^132^ Good | Cohort | 1,279,840 | Denmark | Miscarriage | SSRI | Nonexposed (n=1,256,956) | Pregnant women not exposed to SSRIs during the first 35 days of pregnancy
Andersen, 2014^132^ Good | Cohort | 1,279,840 | Denmark | Miscarriage | SSRI | Previous exposure (n=14,016) | Women exposed to SSRIs 3-12 months before pregnancy but not during pregnancy or 3 months pre-pregnancy
Kjaersgaard, 2013^144^ Good | Cohort | 1,005,319 | Denmark | Spontaneous abortion | 2^nd^ generation AD | Depressed- exposed (n=1,674) | AD prescription redeemed at any time from 30 days before conception to 1 day before end of pregnancy; depression diagnosis anytime between 6 months prior to conception and 1 day before end of pregnancy
Kjaersgaard, 2013^144^ Good | Cohort | 1,005,319 | Denmark | Spontaneous abortion | 2^nd^ generation AD | Not depressed- exposed (n=13,789) | AD prescription redeemed from 6 months before conception to 1 day before pregnancy; not depressed
Kjaersgaard, 2013^144^ Good | Cohort | 1,005,319 | Denmark | Spontaneous abortion | 2^nd^ generation AD | Exposed (n=15,463) | Combines depressed and non-depressed with AD prescriptions
Kjaersgaard, 2013^144^ Good | Cohort | 1,005,319 | Denmark | Spontaneous abortion | 2^nd^ generation AD | Depressed- nonexposed (n=820) | No AD prescription redeemed from 6 months before conception to 1 day before pregnancy end; depression diagnosis anytime between 6 months prior to conception and 1 day before end of pregnancy
Kjaersgaard, 2013^144^ Good | Cohort | 1,005,319 | Denmark | Spontaneous abortion | 2^nd^ generation AD | Not depressed- nonexposed (n=818,426) | No prescription redeemed from 6 months before conception up to 1 day before pregnancy end; not depressed
Kjaersgaard, 2013^144^ Good | Cohort | 1,005,319 | Denmark | Spontaneous abortion | 2^nd^ generation AD | Nonexposed (n=819,246) | Combines depressed and non-depressed with no AD prescriptions
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Depressed- Any prescriptions (n=16,896) | Depressed women w/ at least 1 prescription during pregnancy
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Depressed- 1 prescription (n=NR) | Depressed women w/ 1 prescription filled during pregnancy
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Depressed- 2 prescriptions (n=NR) | Depressed women w/ 2 prescriptions filled during pregnancy
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Depressed- ≥ 3 prescriptions (n=6,196) | Depressed women who filled at least 3 AD prescriptions during pregnancy
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Depressed- nonexposed (n=16,901) | Depressed women w/out AD prescriptions during pregnancy
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Not depressed- nonexposed (n=195,079) | Non-depressed women w/out AD prescriptions during pregnancy
Hayes, 2012^137^ Good | Cohort | 228,876 | United States | Gestational age, neonatal convulsions, respiratory distress | 2^nd^ generation AD | Nonexposed (n=NR) | All women, depressed and non-depressed, who did not have any AD prescriptions during pregnancy
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Depressed- exposed (n=166) | Women with diagnosis of depression during pregnancy and who used AD during pregnancy, but not pre-pregnancy
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Depressed- exposed (pre- and during pregnancy) (n=1,134) | Women w/ diagnosis of depression during pregnancy and who used AD both pre- and during pregnancy
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Exposed (n=8,511) | Cashed a prescription of AD during pregnancy, 1st trimester (n=7,510), 2nd trimester (n=3,837), and 3rd trimester (n=3,300)
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Exposed- SSRI (n=NR) | Filled a prescription for an SSRI during pregnancy
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Depressed- nonexposed (n=1,926) | Women diagnosed w/ depression during pregnancy but who did not use any AD during pregnancy, but who did use AD pre-pregnancy; risk group 6
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Depressed- nonexposed (pre- or during pregnancy) (n=740) | Women diagnosed w/ depression during pregnancy but who did not use any AD either pre- or during pregnancy; risk group 5
Jensen, 2013a143 Good | Cohort | 673,853 | Denmark | Small for gestational age | 2^nd^ generation AD | Not depressed- nonexposed (n=638,116) | All pregnancies where there was no maternal diagnosis of depression before pregnancy end and no AD use either pre- or during pregnancy, risk group 1
Ban, 2014^134^ Good | Cohort | 349,127 | United Kingdom | Major congenital malformations | SSRI | Depressed- exposed (n=7,683) | Women who were depressed and had an SSRI prescription recorded in their medical record between 4 weeks before and 12 weeks after the first day of the LMP (first trimester)
Ban, 2014^134^ Good | Cohort | 349,127 | United Kingdom | Major congenital malformations | SSRI | Depressed- nonexposed (n=13,432) | Women who had a diagnosis of depression but no documented prescriptions for AD in first trimester
Ban, 2014^134^ Good | Cohort | 349,127 | United Kingdom | Major congenital malformations | SSRI | Not depressed- nonexposed (n=325,294) | Women who had no depression diagnosis recorded and no AD prescriptions in first trimester
Polen, 2013^152^ Fair | Case-control | 27,045 | United States | Birth defects (anencephaly, cleft palate, gastroschisis, specified heart defects) | Venlafaxine | Cases (n=91) | Mothers w/ pregnancies affected by one of 30 selected birth defects
Polen, 2013^152^ Fair | Case-control | 27,045 | United States | Birth defects (anencephaly, cleft palate, gastroschisis, specified heart defects) | Venlafaxine | Cases (2003-2007) (n=69) | Mothers w/ pregnancies affected by one of 30 selected birth defects in years 2003-2007
Polen, 2013^152^ Fair | Case-control | 27,045 | United States | Birth defects (anencephaly, cleft palate, gastroschisis, specified heart defects) | Venlafaxine | Controls (n=26,954) | Mothers of babies w/out birth defects
Polen, 2013^152^ Fair | Case-control | 27,045 | United States | Birth defects (anencephaly, cleft palate, gastroschisis, specified heart defects) | Venlafaxine | Controls (2003-2007) (n=13,462) | Mothers of babies w/out birth defects in years 2003-2007
Yazdy, 2014^158^ | Case-control | 2,624 | United States | Clubfoot | SSRI | Cases- Depressed, Exposed > 30 days (n=33) | Depressed cases exposed to SSRI for more than 30 days during lunar months 2-3 of pregnancy
Yazdy, 2014^158^ | Case-control | 2,624 | United States | Clubfoot | SSRI | Cases- Not Depressed, Nonexposed (n=477) | Non-depressed cases, not exposed to SSRI during pregnancy
Yazdy, 2014^158^ | Case-control | 2,624 | United States | Clubfoot | SSRI | Controls- Depressed, Exposed > 30 days (n=58) | Depressed controls exposed to SSRI for more than 30 days during lunar months 2-3 of pregnancy
Yazdy, 2014^158^ | Case-control | 2,624 | United States | Clubfoot | SSRI | Controls- Not Depressed, Nonexposed (n=1,650) | Non-depressed controls, not exposed to SSRI during pregnancy
Louik, 2014^159^ Good | Case-control | 16,524 | United States | Cardiac malformations | SSRI | Cases- exposed (n=NR) | Among cases, any exposure with or without other antidepressants occurring between 28 days prior to LMP to the fourth lunar month
Louik, 2014^159^ Good | Case-control | 16,524 | United States | Cardiac malformations | SSRI | Cases- nonexposed (n=NR) | Among cases, women with no exposure to any antidepressant at any time from 56 days prior to LMP to the end of pregnancy
Louik, 2014^159^ Good | Case-control | 16,524 | United States | Cardiac malformations | SSRI | Controls- exposed (n=NR) | Among controls, any exposure with or without other antidepressants occurring between 28 days prior to LMP to the fourth lunar month which includes 39 exposed to bupropion, 290 to SSRIs, and 81 to other antidepressants
Louik, 2014^159^ Good | Case-control | 16,524 | United States | Cardiac malformations | SSRI | Controls- nonexposed (n=NR) | Among cases, women with no exposure to any antidepressant at any time from 56 days prior to LMP to the end of pregnancy
Huybrechts, 2014^142^ Good | Cohort | 931,259 | United States | Cardiac malformations | 2nd generation AD | Depressed- exposed (n=36,783) | Exposed from LMP through 90 days pregnancy (1st trimester); depressed patients using SSRIs.
Huybrechts, 2014^142^ Good | Cohort | 931,259 | United States | Cardiac malformations | 2nd generation AD | Exposed (n=46,144) | Exposed to SSRI from LMP through 90 days pregnancy (1st trimester)
Huybrechts, 2014^142^ Good | Cohort | 931,259 | United States | Cardiac malformations | 2nd generation AD | Depressed- nonexposed (n=180,561) | Depressed, No exposure to ADs during 1st trimester of pregnancy
Huybrechts, 2014^142^ Good | Cohort | 931,259 | United States | Cardiac malformations | 2nd generation AD | Nonexposed (n=885,115) | No exposure to ADs during 1st trimester

Abbreviations: AD = antidepressants; ICD = International Classification of Disease; LMP = last menstrual period; MoBa = Norwegian Mother and Child Cohort Study; NR = not reported; SNRI = selective norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitors; w/ = with.

We identified 12 additional large fair- to good-quality observational studies published since the AHRQ review (n=4,759,735). Seven of the 12 new studies were conducted in the United States137,142,150-152,158,159 and five were conducted in Europe.132,134,143,144,146 Most were cohort studies that used national register or administrative health data to examine exposures and outcomes retrospectively in pregnant women; three were case-control studies.152,158,159 Five studies provided evidence of outcomes in pregnant women with depression exposed to antidepressants compared to pregnant women with depression unexposed to antidepressants;134, 137,142,144,158 the remaining seven studies compared outcomes in exposed versus unexposed pregnant women with unknown depression status, although most of these studies either adjusted analyses for depressive symptom level146 or conducted some analyses that were restricted to women with depression.143,150,151 Most studies were very large and included hundreds of thousands of women.

#### Populations

The AHRQ review91 defined the population of interest as pregnant women and women during the first 12 months after delivery who had major depression or subthreshold depressive symptoms. Based on expert input, it also included studies of pregnant women who received antidepressants for unknown or mixed reasons. In addition, the conception period was included when studying teratogenicity of antidepressants.

All 12 studies identified since the AHRQ review involved women exposed to antidepressants during their pregnancy. Seven of the studies reported mean maternal age, ranging from 23 to 30 years (Table 15). Only five studies reported race/ethnicity data; in these studies, 40 to 67 percent of participants were white. Two studies reported a history of prepregnancy depression, ranging from 6 to 7 percent.

Table 15 Population Characteristics of Included Observational Studies for KQ 5 (Pregnant Women)

Author, Year Quality | Mean Age and Range (years) | Race/Ethnicity (%) | SES | Depression History, n (%) | Antidepressant Use, n (%)
Palmsten, 2013a151 Good | 23.7 (12-55) | Black: 22.5 Hispanic: 11.8 White: 58.9 | Medicaid, n (%): 85326 (100) | Inpatient depression diagnosis: 5598 (6.6%), Depression diagnosis: 85326 (100%) | Antidepressant: 26107 (30.6%)
Palmsten, 2013b150 Good | 23.5 (12-55) | Black: 19.2 Hispanic: 10.3 White: 63.9 | Medicaid enrollee, n (%): 102722 (100) | NR | Current antidepressant use: 14205 (13.8%)
Lupattelli, 2014^146^ Fair | NR (NR) | NR | Primary education, n (%): 1390 (2.4) | Lifetime history of depression: 18597 (32.5%) | AD use during pregnancy: 527 (0.9%)
Andersen, 2014^132^ Good | NR (NR) | NR | Income, Lowest quartile, n (%): 313747 (25) | NR | AD use during first 35 days of pregnancy: 22884 (1.8%)
Kjaersgaard, 2013^144^ Good | 30.2 (NR) | NR | Income 0-20%, n (%): 199318 (19.9) | NR | Use of AD: 22061 (2.2%)
Hayes, 2012^137^ Good | 23.2 (15-44) | Black: 41.7 Hispanic: NR White: 55.7 | Education < 12 years, n (%): 96170 (42.1) | Depression diagnosis pre-pregnancy: 13593 (5.9%) | Used AD on date of delivery through date of deliver + 90 days: 17773 (7.8%)
Jensen, 2013a143 Good | 29 (NR) | NR | NR | Documented diagnosis of depression: 3966 (0.6%) | AD use during pregnancy: 8511 (1.3%)
Ban, 2014^134^ Good | 30 (14-45) | NR | Townsend deprivation index (1- least deprived), n (%): 85160 (24.4) | NR | NR
Polen, 2013^152^ Fair | NR (NR) | Black: NR Hispanic: NR White: 58.6 | ≤ HS education, n (%): 11613 (42.9) | NR | Venlafaxine during pregnancy: 91 (0.3%)
Yazdy, 2014^158^ | NR (NR) | Black: 15.8 Hispanic: 11.9 White: 67 | Education < 12 years, n (%): 355 (13.5) | Self-reported depression 1 month pre- or during pregnancy: 497 (18.9%) | NR
Louik, 2014^159^ Good | NR (NR) | NR | NR | NR | NR
Huybrechts, 2014^142^ Good | 24.0 (NR) | Black: 34.2 Hispanic: 18.1 White: 40.1 | NR | Diagnosed depression: 217347 (23.3%) | NR

Abbreviations: AD = antidepressants; HS = high school; NR = not reported; SES = socioeconomic status.

#### Interventions and Exposure Definitions

Interventions included in the AHRQ review91 were commonly used antidepressants, including tricyclic antidepressants. For purposes of this review, we did not include data on tricyclic antidepressants when possible, as our focus was on second-generation antidepressants.

In the 12 observational studies identified since the AHRQ review, interventions included SSRIs, SNRIs, bupropion, mirtazapine, and trazodone. Timing of antidepressant medication exposure in these studies ranged from first trimester to third trimester, including date of delivery (Appendix D Table 14). Three studies examined exposure by defined groups of antidepressant doses (high vs. low in one study;132 high vs. medium vs. low in two studies150,151). One study137 examined exposure by number of antidepressant medications prescribed and one by duration of exposure.151 Most assessed exposure by using pharmacy dispensing records,132,137,142-144,150,151 although one study used only prescriptions134 and four others used patient report.146,152,158,159

#### Quality Assessment

We rated the quality of the AHRQ review91 as good using AMSTAR criteria: study design was determined a priori, and the authors performed a comprehensive literature search, including grey literature, provided lists of included and excluded studies, included sufficient detail about included studies, and assessed the quality of included studies using standard methods.

In addition, nine of the 12 studies identified since the AHRQ review were rated as good quality.132,134,137,142-144,150,151,159 These nine studies were all very large, population-based studies that used electronic data, generally with extensive adjustment for potentially confounding variables, such as maternal age, race/ethnicity, education, parity, depression history, smoking history, multiple gestation, previous miscarriages, nonantidepressant medication exposures, and year of delivery. Among the two fair-quality studies, one reported generally good methods (e.g., appropriate ascertainment of those who were exposed and nonexposed, adequately defined eligibility criteria, acceptable followup, and adjustment for confounders), but was rated fair for low survey response rate (43% for mailed questionnaire), unreported baseline characteristics, and self-reported outcomes.146 The other fair-quality study reported generally good methods (e.g., appropriate ascertainment of those who were exposed and nonexposed, adequately defined eligibility criteria, and acceptable followup), but was rated fair for changing the measure of exposure over the course of the study, not reporting blinding of interviewers identifying exposure, not adjusting for all potential confounders, and having an insufficient sample size to assess some outcomes.152 Although most of these added observational studies used good methods, conclusions are still somewhat limited, as it is impossible to avoid the issue of confounding by indication; despite extensive efforts to adjust for confounding variables, there may still be something fundamentally different about women who take antidepressants and women who do not for which the studies could not fully control.

#### Findings

Detailed results from the included observational studies are shown in Appendix D Table 15 and a summary of findings are in Tables 16 and 17.

Table 16 Summary of Adjusted^*^ Results of Maternal Harms With Second-Generation Antidepressant Use During Pregnancy for KQ 5 (Pregnant Women)

Outcome Conclusion | AHRQ Review91 | Included Observational Studies
Serotonin syndrome | Not addressed | Not addressed
Cardiac effects | Not addressed | Not addressed
Seizures (bupropion only) | Not addressed | Not addressed
Suicidality | Insufficient evidence | Not addressed
Gestational diabetes / metabolic effects | Weight gain: insufficient evidence Other metabolic outcomes: not addressed | Not addressed
Preeclampsia Conclusion: Possible association with venlafaxine | Not addressed | [underlined: Depressed Women] (Palmsten 2013a)151 Increased risk; - Venlafaxine (n=1,113): RR, 1.57 (95% CI, 1.29 to 1.91); No association: citalopram (n=1,680), escitalopram (n=1,936), fluoxetine (n=299), paroxetine (n=3,517), sertraline (n=7,143), duloxetine (n=NR), mirtazapine (n=253), trazodone (n=339)
Vaginal bleeding / postpartum hemorrhage Conclusion: Possible association with SSRIs and SNRIs | [underlined: Depressed Women:] No evidence [underlined: Unknown Depression Status] (k=1, n=26,403) Increased risk; - SSRIs; - 60-day exposure (n=423): OR, 1.40 (95% CI, 1.04 to 1.88); - 180-day exposure (n=626): OR, 1.32 (95% CI, 1.03 to 1.70); No association:; - SSRIs, 30-day exposure (n=310) or 90-day exposure (n=501); - Non-SSRIs, 30-day exposure (n=64), 60-day exposure (n=92), 90-day exposure (n=123), or 180-day exposure (n=167) | [underlined: Depressed Women] (Palmsten 2013b)150 Increased risk; - SSRI+venlafaxine, current (n=8,917): RR, 1.46 (95% CI, 1.29 to 1.65); - SSRI+venlafaxine, recent (n=4,344): RR, 1.28 (95% CI, 1.08 to 1.52); - Atypical antidepressant, current (n=1,012): RR, 1.52 (95% CI, 1.12 to 2.06); No association; - SSRI+venlafaxine, past (n=7,432); - Atypical antidepressant, recent (n=616); - Atypical antidepressant, past (n=1460); [underlined: All women Control Group, controlling for depression status] Increased risk (Palmsten 2013b)150; - Citalopram, current (n=891): RR, 1.48 (95% CI, 1.07 to 2.04); - Escitalopram, current (n=1,022): RR, 1.56 (95% CI, 1.16 to 2.09); - Fluoxetine, current (n=3,322): RR, 1.51 (95% CI, 1.27 to 1.79); - Paroxetine, current (n=2,055): RR, 1.36 (95% CI, 1.09 to 1.71); recent (n=962): adjusted RR, 1.52 (95% CI, 1.12 to 2.07); - Sertraline, current (n=4,526): RR, 1.31 (95% CI, 1.12 to 1.54); recent (n=2,266): RR, 1.27 (95% CI, 1.01 to 1.59); - Venlafaxine, current (n=763): RR, 2.24 (95% CI, 1.69 to 2.97); - Bupropion, past (n=1,666): RR, 1.33 (95% CI, 1.03 to 1.71); No association: (Lupatelli 2014;146 Palmsten 2013b150); - SSRI+SNRI, week 30 or later (n=122)146, second trimester (n=222)146, first trimester (n=427)146; - Mirtazapine, current (n=129) or past ( n=135)150; - Trazodone, current (n=139), recent (n=73), or past (n=226)150,150
Miscarriage/spontaneous abortion Conclusion: Possible association with SNRIs, SSRIs in 1^st^trimester, particularly paroxetine | [underlined: Depressed Women] (k=1, n=512,574) Increased risk; - SSRIs, first trimester (n=1,539): RR, 1.4 (99% CI, 1.2 to 1.7); [underlined: Unknown Depression Status] (k=1, n=5,124) Increased risk; - SSRIs (n=NR): OR, 1.60 (95% CI, 1.28 to 2.04); - Paroxetine (n=569): OR, 1.75 (95% CI, 1.31 to 2.34); - Venlafaxine (n=161): OR, 2.11 (95% CI, 1.34 to 3.30); No association: citalopram (k=1, n=NR), fluvoxamine (k=1, n=NR), fluoxetine (k=1, n=NR), sertraline (k=1, n=NR). | [underlined: Depression Women] (Kjaersgaard 2013)144 Increased risk; - Venlafaxine (n=NR): RR, 1.80^*^ (95% CI, 1.19 to 2.72); - Duloxetine (n=NR): RR, 3.12^*^ (95% CI, 1.55 to 6.31); - Mirtazapine (n=NR): RR, 2.23^*^ (95% CI, 1.34 to 3.70); No association (n=NR for all): fluoxetine, citalopram, escitalopram, paroxetine, sertraline, [underlined: Unknown Depression Status] (Andersen 2014)132 Increased risk (exposure during first 35 days of pregnancy); - Citalopram (n=9,927): HR, 1.29 (95% CI, 1.21 to 1.27); - Escitalopram (n=2,377): HR, 1.25 (95% CI, 1.09 to 1.42); - Fluoxetine (n=4,111): HR, 1.10 (95% CI, 1.01 to 1.21); - Paroxetine (n=2,739): HR, 1.27 (95% CI, 1.14 to 1.42); - Sertraline (n=4,453): HR, 1.45 (95% CI, 1.33 to 1.58); - For all SSRIs above, risk was also increased with use ≥3 months pre-pregnancy (and discontinued ≥3 months before pregnancy)

* Unadjusted results.

Abbreviations: AHRQ = Agency for Healthcare Research and Quality; CI = confidence interval; HR = hazard ratio; NR = not reported; OR = odds ratio; RR = relative risk; SNRI = selective norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitors.

Table 17 Summary of Adjusted^*^ Results of Infant Harms With Second-Generation Antidepressant Use During Pregnancy for KQ 5 (Pregnant Women)

Outcome Conclusion | AHRQ Review91 | Included Observational Studies
Perinatal death Conclusion: Possible association with SSRIs | [underlined: Unknown Depression Status] Increased risk Within first year of life (k=1, n=98,325):; - Escitalopram (n=NR): OR, 3.52 (95% CI, 1.30 to 9.49); - Fluvoxamine (n=NR): OR, 4.52 (95% CI, 1.44 to 14.24); - Paroxetine (n=NR): OR, 2.18 (95% CI, 1.03 to 4.61); Within 28 days of birth (k=1, n=920,620):; - Citalopram (n=1,800): OR, 2.49 [1.33 to 4.65]; No association:; - Within first year of life: citalopram (n=NR), fluoxetine (n=NR), sertraline (n=NR); - Within 28 days of birth escitalopram (n=NR), fluoxetine (n=NR), paroxetine (n=NR), sertraline (n=NR); 28-365 days after birth (k=2, n=NR): SSRIs as class | Not addressed
Pre-term birth / gestational age Conclusion: Possible association with SSRIs in first two trimesters and SNRIs | [underlined: Depressed Women] No association: SSRIs (k=2, n=NR): pooled OR^*^, 1.87 (95% CI, 0.89 to 3.89) [underlined: Unknown Depression Status] Increased risk:; - SSRIs (k=11, n=NR, OR NR); - SSRIs in 1^st^ trimester (k=1, n=NR): OR, 11.7 (95% CI, 2.2 to 60.70); - SSRIs in 3^rd^ trimester (k=1, n=NR): OR, 2.46 (95% CI, 1.75 to 3.50); - Citalopram (k=4, n=NR): OR, NR; - Escitalopram (k=4, n=NR): OR, NR; - SNRIs, bupropion (k=2, n=NR): pooled OR, 1.79 (95% CI, 1.46 to 2.19), I^2^=NR; No association: fluoxetine (k=4, n=NR), paroxetine (k=8, n=NR), sertraline (k=2,n=NR) | [underlined: Depressed Women:] (Hayes 2012)137 Increased risk:; - Any antidepressant (mostly SSRIs), % born gestational weeks 32-36:; - 1-2 prescriptions (n=10,700): OR 1.91^*^, (95% CI, 1.77 to 2.07); - 3+ prescriptions (n=6,196): OR 1.12^*^, 95% CI, 1.03 to 1.23); [underlined: Unknown Depression Status in Control Group] (Hayes 2012, N=228,876)137 Increased risk:; - SSRIs in 2^nd^ trimester (mean difference in days, n=NR for all, nulliparous women):; ■ 1 prescription: -2.6 (95% CI, -1.3 to -3.9); ■ 2 prescriptions: -5.8 (95% CI, -3.8 to -7.8); ■ 3+ prescriptions: -6.6 (95% CI, -4.6 to -8.6); Decreased risk:; - SSRIs in 3^rd^ trimester (mean difference in days, n=NR for all, nulliparous women):; ■ 1 prescription: 0.9 (95% CI, 0.3 to 1.6); ■ 2 prescriptions: 1.8 (95% CI, 0.9 to 2.7); ■ 3+ prescriptions: 6.4 (95% CI, 5.5 to 7.3)
Low birth weight / Small for gestational age (SGA) Conclusion: Possible association with SSRIs | [underlined: Depressed Women:] No evidence [underlined: Depressed Women vs. Not Depressed + No SSRI] Increased risk; - SSRIs: increased risk of smaller head circumference (k=1, n=5,502, n=NR): -5.9 mm (95% CI, -11.5 to -0.3); [underlined: Unknown Depression Status] No association with low birth weight: SSRIs:(k=5, n=NR) Insufficient evidence: SNRIs/NRIs | [underlined: Depressed Women:] No evidence [underlined: All Women, Controlling for Depression Status] (Jensen 2013)143 Increased risk; - SSRIs during pregnancy (n=NR): HR, 1.22 (95% CI, 1.13 to 1.32); - 2^nd^ generation non-SSRIs before pregnancy (n=NR): HR, 1.14 (95% CI, 1.05 to 1.24); No association:; - SSRIs before pregnancy (n=NR),; - 2^nd^ generation non-SSRIs during pregnancy (n=NR)
Seizures/convulsions Conclusion: Possible association with SSRIs | [underlined: Depressed Women] No association:; - SSRIs (k=1, n=NR): 0.14% exposed vs. 0.09%, risk difference 0.0005 (95% CI, -0.0015 to 0.0025); RR^*^, 1.56 (95% CI, NR); [underlined: Unknown Depression Status] Increased risk:; - SSRIs (k=7, n=NR): pooled OR^*^, 4.11 (95% CI, 1.78 to 9.48, I^2^=NR) | [underlined: Depressed Women:] (Hayes 2012)137 Increased risk:; - Any antidepressant (mostly SSRIs):; 3+ prescriptions (n=6,196): OR 2.39^*^, (95% CI, 1.57 to 3.64); No association: 1-2 prescriptions (n=10,700) [underlined: Unknown Depression Status in Control Group] (Hayes 2012, N=228,876)137 Increased risk:; - SSRIs 3^rd^ trimester:; - 2 prescriptions (n=NR): OR, 2.8 (95% CI, 1.4 to 5.5);; - 3+ prescriptions (n=NR): OR, 4.9 (95% CI, 2.6 to 9.5); No association; - SSRIs 3^rd^ trimester, 1 prescription (n=NR)
Serotonin withdrawal (discontinuation) syndrome Conclusion: Possible association with SSRIs and SNRIs | [underlined: Depressed Women:] No evidence [underlined: Unknown Depression Status] Increased risk:; - SSRI (k=1, n=120): increased risk of Finnegan severe score of ≥8 (13% vs. 0%, p=NR); increased risk of any symptoms of withdrawal (30% vs. 0%, p=NR); - Fluoxetine (k=1, n=482): increased risk of poor neonatal adaptation, RR, 8.7 (95% CI, 2.9 to 26.6); - SSRI or venlafaxine during 3^rd^ trimester (k=1, n=166): increased risk of neonatal behavioral signs, OR, 3.1 (95% CI, 1.3 to 7.1); - SSRI or SNRI (k=1, n=56): increased risk of elevated Finnegan neonatal abstinence score ( 2 vs. 0, p<0.05); No association: SSRIs as class (k=1, n=108)278 | Not addressed
Neonatal respiratory distress Conclusion: Possible association with SSRIs | [underlined: Depressed Women] Increased risk:; - SSRIs (k=3, n=NR): pooled OR^*^, 1.91 (95% CI, 1.63 to 2.24), I^2^=0%; [underlined: Unknown Depression Status] Increased risk:; - SSRIs (k=4, n=748,658): pooled OR, 1.79 (95% CI, 1.64 to 1.97), I^2^=0% | [underlined: Depressed Women:] (Hayes 2012)137 Increased risk:; - Any antidepressant (mostly SSRIs):; - 3+ prescriptions (n=6,196): OR 1.18^*^, (95% CI, 1.04 to 1.35); No association: 1-2 prescriptions (n=10,700) [underlined: Unknown Depression Status in Control Group] (Hayes 2012)137 Increased risk:; - SSRIs, 2^nd^ trimester:; - 2 prescriptions (n=NR): OR, 1.4 (95% CI, 1.1 to 1.8); 3+ prescriptions (n=NR): OR, 1.6 (95% CI, 1.2 to 2.0); Decreased risk:; - SSRIs, 3^rd^ trimester, 3+ prescriptions (n=NR): OR, 0.6 (95% CI, 0.5 to 0.8); No association:; - SSRIs, 2^nd^ trimester, 1 prescription (n=NR); 3^rd^ trimester, 1 or 2 prescriptions (n=NR)
Pulmonary hypertension Conclusion: Possible association with SSRIs, particularly late in pregnancy | [underlined: Unknown Depression Status] Increased risk:; - SSRIs; ○ Any time during pregnancy (k=3, n=NR): pooled OR, 2.41 (95% CI, 1.47 to 3.95), I^2^=14%; ○ Late exposure (generally ≥20 weeks) (k=3, n=NR): pooled OR, 2.72 (95% CI, 1.63 to 4.54), I^2^=14%; No association (but high heterogeneity in pooled estimate):; - SSRIs, early exposure (not defined) (k=4, n=NR) | Not addressed
Major Malformations Conclusion: Possible association with fluoxetine, paroxetine, and escitalopram | [underlined: Depressed Women] Insufficient evidence (k=3, n=NR) [underlined: Unknown Depression Status] Increased risk:; - Fluoxetine (k=7, n=NR): pooled OR, 1.14 (95% CI, 1.01 to 1.30), I^2^=0%; - Paroxetine (k=8, n=NR): pooled OR, 1.17 (95% CI, 1.02 to 1.35), I^2^=0%; No association: SSRIs (k=6, n=NR), citalopram or escitalopram (k=8, n=NR), fluvoxamine (k=2, n=NR), sertraline (k=7, n=NR) | [underlined: Depressed Women] (Ban 2014; Yazdy)134,158 Increased risk (Yazdy 2014; n=2,624):; - SSRIs: increased risk of SSRI use in the 2^nd^ or 3^rd^ month of pregnancy for mothers of infants born with clubfoot: adjusted OR, 1.8 (95% CI, 1.1 to 2.8).; - Escitalopram: increased risk of use in 2^nd^ or 3^rd^ month of pregnancy for mothers of infants born with clubfoot: adjusted OR, 2.9 (95% CI, 1.1 to 7.2); No association: citalopram (n=1,946), escitalopram (n=333), fluoxetine (n=3,189), paroxetine (n=1,200), sertraline (n=757)
Cardiac malformations Conclusion: Possible association with bupropion, paroxetine and venlafaxine | [underlined: Depressed Women:] No evidence [underlined: Unknown Depression Status] Increased risk:; - Paroxetine (k=5, n=NR): pooled OR, 1.45 (95% CI, 1.13 to 1.85),I^2^=0%; No association: SSRIs (k=5, n=NR), citalopram or escitalopram (k=6, n=NR), fluoxetine (k=5, n=NR), fluvoxamine (k=3, n=NR), sertraline (k=4, n=NR) | [underlined: Depressed Women] (Ban 2014;134 Huybrechts 2014^142^) Increased risk:; - Paroxetine in 1^st^ trimester (n=1,200): adjusted OR, 1.67 (95% CI, 1.00 to 2.80)134; No association: SSRIs (k=2; N=44,461), citalopram (n=1,946),134 escitalopram (n=333),134 fluoxetine (k=2; n=11,853),134 paroxetine (n=8,748),142 sertraline (k=2; n=11,813),142 SNRIs (n= 6,010),142 bupropion (n=8,748)142 [underlined: Unknown Depression Status] (Polen 2013; Louik 2014)152,159 Increased risk:; - Bupropion: Increased risk of bupropion use in 1^st^ trimester for mothers of infants with ventricular septal defects (n=16,524): adjusted OR, 2.5 (95% CI, 1.3 to 5.0)159; - Venlafaxine: Increased risk of venlafaxine use pre- and in early pregnancy for mothers of infants with atrial septal defects: adjusted OR, 3.1 (95% CI, 1.3 to 7.4)152

* Unadjusted results.

Abbreviations: AHRQ = Agency for Healthcare Research and Quality; CI = confidence interval; HR = hazard ratio; NR = not reported; OR = odds ratio; RR = relative risk; SNRI = selective norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitors.

##### Maternal Outcomes

None of the included studies, including the AHRQ review,91 addressed serotonin syndrome. Likewise, none assessed cardiac effects or seizures in pregnant or postpartum women exposed to antidepressants. Evidence for suicidality and metabolic effects was judged insufficient in the AHRQ review,91 and the included studies published since the AHRQ review did not address these outcomes.

Preeclampsia. One study that examined risks of preeclampsia in women with depression exposed to antidepressants in the second or third trimester, published since the AHRQ review, reported an increased risk in women exposed to venlafaxine (adjusted RR, 1.57 [95% CI, 1.29 to 1.91]).151 In this study, 8.9 percent of women exposed to venlafaxine developed preeclampsia compared to 5.4 percent of women with no exposure. There was no increased risk with SSRIs, mirtazapine, or trazodone.

Vaginal bleeding and postpartum hemorrhage. In an analysis limited to women with depression, one study published after the AHRQ review91 found an increased risk of postpartum hemorrhage for women taking antidepressants with high serotonin transporter affinity (93% of dispensings were SSRIs, the remaining were primarily venlafaxine).150 In this analysis, 4.0 percent of the women exposed to these medications experienced postpartum hemorrhage compared with 2.8 percent without exposure. Risk was also increased with the use of antidepressants with low serotonin transporter affinity (78% of dispensings were bupropion, the remaining were primarily mirtazapine and trazodone; 4.2% with postpartum hemorrhage with exposure vs. 2.8% without exposure).

The same study reported an increased risk for most agents in all women, controlling for number of mood or anxiety diagnoses—adjusted RRs ranged from 1.31 (95% CI, 1.12 to 1.54) for sertraline to 2.24 (95% CI, 1.69 to 2.97) for venlafaxine.150 Similarly, the AHRQ review91 identified one case-control study that addressed postpartum hemorrhage and found an increased likelihood of SSRI use in women with unknown depression status who experienced maternal postpartum hemorrhage, with similar results for 60 and 180 days of SSRI exposure. Another large observational study, however, found no association between use of second-generation antidepressants (SSRIs, SNRIs, mirtazapine, or trazodone) and postpartum hemorrhage or vaginal bleeding in women with unknown depression status.146

The strongest evidence for women with depression suggests an increased risk of harms for most second-generation antidepressants.

Miscarriage or spontaneous abortion. The AHRQ review91 included one very large study (n=512,574) limited to women with depression, in which 14.9 percent of those taking SSRIs during the first trimester had a miscarriage compared with 12.1 percent of women who did not take SSRIs (adjusted RR, 1.4 [95% CI, 1.2 to 1.7]).169 In contrast, one very large (n=1,005,319) study published after the AHRQ review found no increased risk of miscarriage with SSRI use in women with depression exposed at any point in pregnancy.144 It did, however, report increases in the risk of miscarriage with the SNRIs venlafaxine (unadjusted RR, 1.80 [95% CI, 1.19 to 2.72]) and duloxetine (unadjusted RR, 3.12 [95% CI, 1.55 to 6.31]), as well as mirtazapine (unadjusted RR, 2.23 [95% CI, 1.34 to 3.70]).

In women with unknown depression status, one study included in the AHRQ review found an increased risk of miscarriage in women exposed to SSRIs at any time during pregnancy (adjusted OR, 1.60 [95% CI, 1.28 to 2.04]) and an increased risk with exposure to venlafaxine (adjusted OR, 2.11 [95% CI, 1.34 to 3.30]).170 In another study published since the AHRQ review, women with unknown depression status had increases in the risk of miscarriage with SSRI use. This study's authors also found an increased risk with prior SSRI use (i.e., discontinued use more than 3 months before pregnancy and no pregnancy exposure), suggesting that the increased risk may be due to some other issue, perhaps depression-related, rather than specific to SSRI use.132 This study did not examine SNRIs.

Overall, the evidence suggests a possible increased risk of miscarriage or spontaneous abortion in women exposed to SSRIs and SNRIs in the first trimester.

##### Infant Outcomes

Perinatal death. The AHRQ review91 only included evidence for women of unknown depression status. There were no studies subsequent to the review that examined this outcome. In the AHRQ review, one study that addressed perinatal death within a year of birth found an increased risk for infants of women exposed to the SSRIs escitalopram, fluvoxamine, and paroxetine but not citalopram, fluoxetine, or sertraline. Four studies examined SSRI use and perinatal death within 28 days of birth. One study found an increased risk with citalopram (adjusted OR, 2.49 [95% CI, 1.33 to 4.65]; 0.83% of infants with exposure in utero died within 28 days of birth vs. 0.34% of unexposed infants). There were no other findings of increased perinatal death within 28 days for any other individual SSRI in any of the four studies. The two studies that also examined perinatal death between 28 and 365 days after birth did not find an increased risk with SSRIs as a class but did show increased risk for several SSRI agents (escitalopram, fluvoxamine, and paroxetine). In all, the evidence suggests a possible association between perinatal death and SSRI use.

Preterm birth. The AHRQ review91 included two observational studies limited to women with depression that compared infants of women treated with SSRIs during pregnancy to those of untreated women and did not find a statistically significant increased risk of preterm birth, although wide CIs suggest lack of precision (pooled OR, 1.87 [95% CI, 0.89 to 3.89]). One study published since the AHRQ review examined this outcome with SSRIs as a class and with any antidepressant use.137 In analysis limited to women with depression, a small increased risk of preterm birth was identified with any antidepressant use, largely representing SSRIs (12.7% of infants of mothers with ≥3 SSRI dispensings were born in weeks 32 through 36 vs. 11.5% of infants of mothers with no dispensings; unadjusted OR, 1.12 [95% CI, 1.03 to 1.23]).

This same study137 also examined a broader control group with unknown depression status but controlling for history of depression and other mental health diagnoses. These results varied by trimester of exposure: exposure in the second trimester was associated with preterm labor and delivery, while exposure in the third trimester was not. For each trimester, these associations were strongest in women who had the greatest exposure, as measured by number of prescriptions (Table 17). For second trimester SSRI exposure, gestational age was reduced by 2.6, 5.8, and 6.6 days for one, two, or three or more prescription fills, respectively. In the third trimester, gestational age was increased by 0.9, 1.8, and 6.4 days with one, two, or three or more SSRI prescription fills. Eleven studies of women with unknown depression status in the AHRQ review provided evidence of an increased risk of preterm birth in infants of women exposed to SSRIs as a class at any point in their pregnancy compared to unexposed women (pooled OR not reported), specifically with exposure to citalopram and escitalopram.91 Two studies included in the AHRQ review showed an increased risk of preterm birth for infants of mothers with unknown depression status exposed to SNRIs as a class at any point in their pregnancy (pooled adjusted OR, 1.79 [95% CI, 1.46 to 2.19]; Q=0.77). However, these results differ from findings in the more recent large cohort studies that showed differential risk by trimester.

Overall, results suggest an increased risk of preterm birth with SSRIs and perhaps SNRIs, but are not conclusive regarding timing of exposure. Similarly, dose-response relationships in these data are mixed and inconsistent.

Low birth weight or small for gestational age. No studies of this outcome reported analysis limited to women with depression. Five studies in the AHRQ review91 found no association between low birth weight and maternal exposure to SSRIs in infants of women of unknown depression status (pooled OR, 1.04 [95% CI, 0.64 to 1.69]; I^2^=30%). A sixth study showed an increased risk of smaller head circumference in infants of women with depression taking SSRIs compared to women without depression or SSRI exposure (-5.9 mm [95% CI, -11.5 to -0.3 mm]) but no difference between infants of women with and without depression not exposed to SSRIs, suggesting no independent association with depression. For SNRIs, there was insufficient evidence due to small sample sizes.

We found one additional very large retrospective Danish cohort study that examined SSRI use in all women, controlling for depression status. This study found an increased risk for being small for gestational age in infants born to women who used SSRIs during pregnancy (n=673,853; adjusted hazard ratio, 1.22 [95% CI, 1.13 to 1.32]).143 Absolute rates of low birth weight were not reported.

It is difficult to determine how strongly to weigh this more recent evidence against the five studies in the AHRQ review finding no association; the AHRQ review did not report the total sample size evaluated, so we cannot determine if the lack of association was due to low power. However, the OR was very close to 1.0, suggesting no association. Given that the recent cohort study was very large, covered a well-defined population, and controlled for a number of important confounders (including depression diagnosis in medical or mental health records), we conclude that an association with SSRIs is possible.

Seizures. Two studies examined this outcome in women with depression. One study in the AHRQ review91 found no increased risk of neonatal seizures with SSRI use. In contrast, a large retrospective cohort study published since the AHRQ review did report more than a doubling of seizure occurrence in infants of women with depression and exposure to three or more prescription fills of antidepressants of any kind, primarily SSRIs (unadjusted OR, 2.39 [95% CI, 1.57 to 3.64]; 0.66% of exposed infants vs. 0.28% of unexposed infants).137 There was no similar association in women with one or two prescription fills.

Seven studies in the AHRQ review examined this outcome in women with unknown depression status and demonstrated an increased risk of seizures in infants of women exposed to SSRIs (k=7; pooled OR, 4.11 [95% CI, 1.78 to 9.48]; I^2^=not reported). In the aforementioned study published since the AHRQ review, there was an increased risk of neonatal seizures in infants of women who received two or three prescription fills of SSRIs in the third trimester (adjusted OR for two fills, 2.8 [95% CI, 1.4 to 5.5]), among women with unknown depression status but controlling for previous depression and other mental health disorders. However, the review found no association with SSRI use in the second trimester in this analysis.137

Overall, the evidence suggests that there may be an association with SSRIs and neonatal seizures.

Serotonin withdrawal syndrome. No evidence restricted to women with depression was available for this outcome. For women with unknown depression status, the AHRQ review91 identified five small cohort studies that provided evidence of increased risk of serotonin withdrawal syndrome in infants of women with unknown depression status exposed to SSRIs as a class; the authors were unable to pool these results. Outcomes examined included ratings of neonatal symptoms of withdrawal, such as central nervous system symptoms (e.g., reflexes, tremor, muscle tone, and crying) and other indications (e.g., hyperthermia, respiratory rate, yawning, and gastrointestinal disturbance). Neonatal seizures, hypertension, and respiratory distress were considered separately. In the largest cohort study that adjusted for multiple confounders in the AHRQ review, there was an increased risk of serotonin withdrawal syndrome in infants of women exposed to fluoxetine during the first trimester (adjusted RR, 8.7 [95% CI, 2.9 to 26.6]), while in another cohort study, infants of women exposed to an SSRI or to venlafaxine in the third trimester had an increased risk of this outcome (adjusted OR, 3.1 [95% CI, 1.3 to 7.1]). Two of the remaining small studies found increased risks with SSRIs and SNRIs, while a third found no associated risk with SSRIs. None of the studies published subsequent to the AHRQ review examined this outcome.

In sum, there is a possible association between SSRIs and SNRIs and neonatal serotonin withdrawal syndrome, although evidence limited to women with depression is lacking.

Respiratory distress. Three studies included in the AHRQ review91 and one published subsequently provide evidence regarding this outcome in women with depression. In the AHRQ review, three studies found evidence of an increased risk of respiratory distress in infants born to women exposed to SSRIs during pregnancy (pooled OR, 1.91 [95% CI, 1.63 to 2.24]; I^2^=0%). The largest of these studies reported that 7.8 percent of infants not exposed to SSRIs in utero experienced neonatal respiratory distress compared with 13.9 percent of exposed infants.

Additionally, one large cohort study (n=228,876) published since the AHRQ review137 showed an increased risk of neonatal respiratory distress in infants of women with depression exposed to antidepressants (primarily SSRIs) when three or more prescriptions were filled (5.4% of exposed infants vs. 4.6% of unexposed infants).

Among women with unknown depression status, four studies included in the AHRQ review found evidence of an increased risk of respiratory distress in infants of exposed women (pooled adjusted OR, 1.79 [95% CI, 1.64 to 1.97]; I^2^=0%). In the previously mentioned study published since the AHRQ review, when the unexposed group was not limited to women with depression, but controlling for depression history, there was an increase in risk in infants of women exposed to SSRIs in the second trimester.137 Consistent with this study's findings for other harmful outcomes, timing of exposure affected risk, with increased risk with three or more prescriptions in women exposed in the second trimester compared to similar exposure in the third trimester. Timing and dose/duration of exposure (represented by number of prescriptions) cannot be separated across all studies, and thus these data are not definitive.

Overall, these finding suggest a possible association between maternal SSRI use and neonatal respiratory distress.

Pulmonary hypertension. The only evidence available for this outcome was in women with unknown depression status, and was limited to the findings included in the AHRQ review.91 Therein, three studies found an increased risk of pulmonary hypertension in infants of mothers who had exposure to SSRIs at any point in their pregnancy (pooled adjusted OR, 2.41 [95% CI, 1.47 to 3.95]; I^2^=14%). For maternal exposure to SSRIs early in pregnancy, significant heterogeneity prevented the authors from pooling data from the four studies that examined this outcome. For women exposed to SSRIs late in pregnancy, generally defined as 20 weeks' gestation or later, three studies found an increased risk of pulmonary hypertension in the newborn (pooled adjusted OR, 2.72 [95% CI, 1.63 to 4.54]; I^2^=14%).

The evidence suggests a possible association of pulmonary hypertension with maternal exposure to SSRIs, particularly late in pregnancy.

Major malformations. Two studies published since the AHRQ review examined this outcome in studies of women with depression. The first was a large (n=349,127) retrospective cohort study of women with depression that found no increased risk of major malformations with any SSRI.134 The second was a case-control study of 622 infants with clubfoot and 2002 infants with malformations, all born to women with depression.158 There was an increased risk of SSRI exposure in the second or third month of pregnancy for mothers of infants born with clubfoot (adjusted OR, 1.8 [95% CI, 1.1 to 2.8]); however, this result appeared to be primarily driven by the positive association with escitalopram exposure (adjusted OR, 2.9 [95% CI, 1.1 to 7.2]). Evidence suggested a possible increased risk of sertraline (adjusted OR, 1.6 [95% CI, 0.8 to 3.2]) and paroxetine exposure (adjusted OR, 9.2 [95% CI, 0.7 to 484.6]) as well, but CIs were wide for these two antidepressants due to the small number of exposed cases.

Data from the AHRQ review in populations with unknown depression status suggested a small increased risk of major malformations with exposure to fluoxetine (pooled adjusted OR, 1.14 [95% CI, 1.01 to 1.30]; k=7; I^2^=0%) and paroxetine (pooled adjusted OR, 1.17 [95% CI, 1.02 to 1.35]; k=8; I^2^=0%), but not other SSRIs. Raw rates of major malformations were not reported.

These findings indicate a possible association of major malformations with maternal use of fluoxetine, paroxetine, and escitalopram during pregnancy.

Cardiac malformations. Evidence on this outcome in women with known depression was found in two large retrospective cohort studies (combined n=1,280,386) published since the AHRQ review.134,142 These studies found no increased risk of neonatal cardiac malformations in infants of women exposed to classes of SSRIs or SNRIs or to individual antidepressants, including bupropion, with the possible exception of paroxetine, for which there were mixed findings: one study identified an increased risk in infants of women exposed to paroxetine in the first trimester (adjusted OR, 1.67 [95% CI, 1.00 to 2.80]; 3.0% in exposed infants vs. 2.8% in unexposed infants);134 the other found no increased risk associated with maternal paroxetine exposure at any point during pregnancy (adjusted OR, 0.9 [95% CI, 0.7 to 1.2]).142

For women with unknown depression status, five studies in the AHRQ review found no increased risk of cardiac malformations in infants of women who took SSRIs as a class during pregnancy.91 However, five studies in the AHRQ review did find that paroxetine increases the risk of infant cardiac malformations (pooled OR, 1.45 [95% CI, 1.13 to 1.85]; I^2^=0%). Additionally, a large (n=27,045) case-control study published since the AHRQ review found an increased risk of venlafaxine exposure at any point from 1 month preconception through the third month of pregnancy for mothers of infants born with an atrial septal defect (adjusted OR, 3.1 [95% CI, 1.4 to 7.4]).152 A second large (n=16,524) case-control study published since the AHRQ review found an increased risk of bupropion exposure in the first trimester for mothers of infants born with a ventricular septal defect (adjusted OR, 2.5 [95% CI, 1.3 to 5.0]).159 Neither of these case-control studies was limited to women with depression, and it is recognized that case-control methodology may overestimate RRs compared with cohort designs.

Overall, the evidence regarding infant cardiac malformations suggests a possible association with maternal use of bupropion, paroxetine, and venlafaxine.

## Results of Included Studies in General and Older Adults

### KQ 1 Do Primary Care Depression Screening Programs in the General Adult Population, Including Older Adults, Result in Improved Health Outcomes?

### KQ 1a Does Sending Depression Screening Test Results to Providers (With or Without Additional Care Management Supports) Result in Improved Health Outcomes?

#### Study Characteristics

We found nine trials addressing benefits of screening (n=3,814);72,73,161-167 five in general adult populations72,73,162,163,165 and four targeting older adults (Table 18).161,164,166,167 All studies except one in older adults were available for our previous systematic review. As in that review, only one study met criteria for KQ 1, comparing screening with usual care case-finding.162 The remaining studies met criteria for KQ 1a, in which all patients in both groups were screened for depression, patients screening positive were enrolled in the study, but results were returned only to providers in the intervention group.72,73,161,163-167 Additional treatment components were included along with screening results feedback in these studies, ranging from brief education about the screening test72 to an extensive quality improvement program.163

Table 18 Study Characteristics of Included Studies for KQs 1 and 2 (General and Older Adults)

Author, Year and Quality | KQ1 | Study Design | N | Intervention | Followup (mo) | Country | Setting | Invited to Screen (% Screened) | % Screened Positive for Depression | Definition of Screened Positive
General Adults
Williams, 1999^162^ Fair | KQ1 | RCT | 969 | Case-finding (20-item or 1 item) | 3 | United States | Primary Care | NR | 37.1 | “Yes” on single-item screen or CES-D ≥ 16
Bergus, 2005^72^ Fair | KQ1a | RCT | 59 | Screening results to provider | 2, 6 | United States | Primary Care | 951 (90.5%) | 13.8 | Positive on either of first 2 items of PHQ-9
Jarjoura, 2004^165^ Fair | KQ1a | RCT | 61 | Screening results + treatment protocol | 12 | United States | Primary Care | NR | 45.4 | Positive response on either of two PRIME-MD depression items
Rost, 2001^73,279,280^ Good | KQ1a | Cluster RCT | 479 | Screening results + provider training & supports | 6, 12, 24 | United States | Primary Care | 11006 (84.4%) | 5.9 | WHO-CIDI-positive and IDD ≥ 5
Wells, 2000^163,281,282^ Fair | KQ1a | RCT | 1356 | Screening results, provider training & support, CBT or medication support | 6, 12, 24, 57 | United States | Primary Care | 33932 (80.5%) | 14.3 | Positive on WHO CIDI-2
Older Adults
van der Weele, 2012^166^ Good | KQ1a | Cluster RCT | 239 | Screening results + referral for stepped care | 6, 12 | Netherlands | Primary Care/Home-based Screening | 10681 (52.8%) | 9.4 | GDS-15 ≥ 5
Whooley, 2000^164^ Fair | KQ1a | Cluster RCT | 331 | Screening results + provider training + psycho-education course | 24 | United States | Primary Care | 2896 (81.0%) | 14.1 | GDS ≥ 6
Bijl, 2003^167,283^ Fair | KQ1a | Cluster RCT | 145 | Screening results + provider training | 6, 12 | Netherlands | Primary Care | NR | 17.2 | GDS ≥ 5
Callahan, 1994^161^ Fair | KQ1a | Cluster RCT | 175 | Screening results + provider support | 6, 9 | United States | Primary Care | 4413 (85.4%) | 16.2 | CES-D ≥ 16 + HAM-D ≥ 15

Abbreviations: CBT = cognitive behavioral therapy; CES-D: Center for Epidemiologic Studies Depression; CIDI = Composite International Diagnostic Interview GDS = Geriatric Depression Scale; HAM-D: Hamilton Depression Rating Scale; IDD = Inventory to Diagnose Depression; KQ = Key Question; NR = not reported; RCT = randomized controlled trial; PHQ = Patient Health Questionnaire; PRIME-MD: Primary Care Evaluation of Mental Disorders; WHO = World Health Organization.

The single KQ 1 trial, by Williams and colleagues, randomized participants to screening or usual care and retained participants who screened negative as well as positive in the analysis, comparable to a typical primary care population.162 All included participants, however, completed a diagnostic interview via phone, so none were truly naïve to being asked about depressive symptoms. In addition, followup for depression outcomes was limited to one of the two study sites and further to only those who met criteria for MDD at the diagnostic interview, with a subset of those who did not meet MDD criteria, oversampling those with depression symptoms. For all remaining (KQ 1a) trials, samples were limited to patients with depressive symptomatology. Some studies included patients who screened positive on a single depression screening instrument while others required either an additional screening instrument or a confirmed diagnosis of depression after a diagnostic interview.

Most of the trials were cluster randomized, at the level of the provider or clinic rather than the individual, and three were individually randomized trials, including the KQ 1 study.72,162,165 Followup ranged from 3 months to almost 5 years.

Two studies were conducted in the Netherlands166,167 and the remainder were conducted in the United States, all in primary care settings. This is an older body of literature; the most recent trial was published within the past 5 years,166 but the rest were published in the 1990s through early 2000s.

Studies used a variety of screening instruments. Most of the trials targeting older adults used the GDS, and others used the Center for Epidemiologic Studies Depression, various forms of the PHQ or the Primary Care Evaluation of Mental Disorder, and the WHO Composite International Diagnostic Interview. In most cases, screening occurred in conjunction with a primary care clinic visit; however, one of the studies conducted in the Netherlands either invited participants to complete a home-based screening or sent the screening instrument by mail, with just more than 50 percent completing the screening in both cases. Where reported, screening was completed by 53 to 90 percent of those invited to be screened.

#### Populations

Population characteristics are presented in Table 19. Five trials (n=2,924) included general adult populations with wide age ranges (i.e., ≥18 years), and average ages were generally in the mid- 40s.72,73,162,163,165 Four trials targeted older adults,161,164,166,167 including both trials from the Netherlands; minimum age ranged from 55 to 75 years. In all cases, women outnumbered men; across the entire body of evidence, 72 percent of participants were women. Only four of the trials reported substantial racial/ethnic minority representation, all conducted in the 1990s. Most trials included a substantial number of participants who had recently been treated for depression or had depression previously documented. Two trials (one in general adults and one in older adults), however, specifically targeted persons with untreated depression who were not seeking treatment for mental health issues;165,166 another trial in 145 older adults excluded persons already taking antidepressants;167 and a fourth trial in general adults made the a priori decision to report results separately for those with newly-identified depression versus previously known depression, and reported some results only for those with newly-identified depression.73

Table 19 Population Characteristics of Included Studies for KQs 1 and 2 (General and Older Adults)

Author, Year and Quality | Mean Age and Range (years) | % Female | Race/Ethnicity (%) | SES | Depression History including Treatment, n (%)
General Adults
Williams, 1999^162^ Fair | 58 (≥ 18) | 71 | Black: 10.4 Hispanic: 59.3 White: 29 | Annual income < $7,200, n (%): 339 (39.3) | Known depressed at BL: 115 (13.3%)
Bergus, 2005^72^ Fair | 41.0 (NR) | 66.7 | Black: NR Hispanic: NR White: 94.1 | Some college, n (%): 26 (51.0) | Prior treatment for depression: 31 (60.8%) Current medication for depression or anxiety: 17 (33.3%)
Jarjoura, 2004^165^ Fair | 45 (24-67) | 68.9 | NR | Medicaid or uninsured + below poverty line, n (%): 61 (100) | Treated for depression or other MH issue at BL: 0 (0%)
Rost, 2001^73^ Good | 42.6 (> 18) | 83.9 | Black: NR Hispanic: NR White: 84.3 | Income, mean: 10408 | Recently treated: 243 (50.7%) On antidepressants in the month preceding index visit: 177 (56%)
Wells, 2000^163^ Fair | 43.7 (> 18) | 72.3 | Black: 6.9 Hispanic: 29.2 White: 57.4 | < HS education, n (%): 220 (16.2) | Lifetime depressive disorder status: 1093 (80.6%) Antidepressant use at BL: 372 (27.4%)
Older Adults
van der Weele, 2012^166^ Good | 80 (≥ 75) | 72.4 | NR | Income only social security, n (%): 40 (16.7) | Treated for depression: 0 (0%)
Whooley, 2000^164^ Fair | 75.8 (≥ 65) | 60.7 | Black: 32.6 Hispanic: 4.5 White: 43.9 | HS graduate, n (%): 167 (81.3) | Antidepressant use past 12 months: 66 (19.9%)
Bijl, 2003^167^ Fair | 65.6 (≥ 55) | 57.2 | NR | Education none-low, n (%): 90 (62) | Lifetime depression: 120 (82.8%) Current use of antidepressants: 0 (0%)
Callahan, 1994^161^ Fair | 65.3 (≥ 60) | 76 | Black: 51.4 Hispanic: NR White: NR | Education (years), mean: 8.8 | Previous depression diagnosisin medical record: 36 (20.6%) On antidepressant: 20 (11.4%)

Abbreviations: BL = baseline; DSM=Diagnostic and Statistical Manual; HS = high school; MH = mental health; NR = not reported; SES = socioeconomic status.

Although there was a wide range of screening positivity rates (Table 18), in most trials, between 14 and 17 percent of the sample screened positive for depression. The screen positive rate was lowest (5.9%) in one large multisite trial that included a mixture of urban and rural clinics,73 and highest (45%) in a trial of persons with Medicaid or who were living below the federal poverty line and without health insurance.165

#### Interventions

Interventions were extremely variable, with no apparent replication across trials. Detailed descriptions of the interventions are available in Appendix D Table 16, and a compiled list of selected components offered in each intervention is shown in Table 20, roughly ordered by increasing intensity of the intervention within the two age-based strata. At the low end, one trial in general adults tested screening versus usual case-finding,162 while another in the same population offered very little beyond feedback of screening test results.72 Two trials primarily focused on making specialist treatment more easily available without extensive training or support directly to the provider.164,166 Three trials attempted to help improve the primary care clinician's depression care by providing training167 or a standardized treatment protocol with every patient screening positive,161,165 along with patient handouts and patient-specific evaluation of current medications, in one case.161 The final two trials provided quite extensive training to primary care providers, and had dedicated staff to help with referrals as well as patient followup for symptom and medication monitoring.73,163 The trial with the most extensive intervention beyond screening results feedback included day-long or multiday training of “leader” primary care providers, nurses, and mental health providers at each site; treatment manuals, monthly lectures, and academic detailing for other site providers; printed materials for patients and providers; and either extra support for mediation adherence or low-cost CBT with specially trained mental health clinicians.163

Table 20 Intervention Characteristics of Included Studies for KQs 1 and 2 (General and Older Adults)

Author, Year Quality | Intervention | Train PCP in Screening | Train PCP in Depression Diagnosis | Train PCP in Depression Treatment | Treatment Guidance Provided | Patient Materials Provided | Patient-specific Treatment Recommendations | Referral Support for PCP | Symptom Monitoring by Support Staff | Treatment Adherence Monitoring by Support Staff | Counseling to Support Adherence | Behavioral Counseling Approach | Estimated Hours of Behavioral Counseling | Target Provider
General Adults
Williams, 1999^162^ Fair | Case-finding (1 item or 20-item) | | | | | | | | | | | NA | NA | Physician
Bergus, 2005^72^ Fair | Screening results to provider | ✓ | | | | | | | | | | NA | NA | Medical provider
Jarjoura, 2004^165^ Fair | Screening results + treatment protocol | | | ✓ | ✓ | ✓ | | ✓ | | | | NA | NA | Resident physicians
Rost, 2001^73^ Good | Screening results + provider training & supports | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | NA | NA | Physician, nurse
Wells, 2000^163^ Fair | Screening results, provider training & support, CBT or medication support | | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | CBT or related or medication management | NR | Psycho-therapist, nurse specialist, physician
Older Adults
van der Weele, 2012^166^ Good | Screening results + referral for stepped care | | | | | | | | | | ✓ | CBT or related | NR | General practitioner, mental health professional
Whooley, 2000^164^ Fair | Screening results + provider training + psychoeducation course | | ✓ | ✓ | | | | | | | | General education | 7 | Primary care physician, psychiatric nurse
Bijl, 2003^167^ Fair | Screening results + provider training | ✓ | ✓ | ✓ | | | | | | | | NA | NA | General practitioner
Callahan, 1994^161^ Fair | Screening results + provider support | | | | ✓ | ✓ | ✓ | | | | | NA | NA | Physicians

Abbreviations: CBT = cognitive behavior therapy; NA = not applicable; PCP = primary care physician.

#### Quality

We rated only two of the studies as good quality,73,166 but one of these had higher attrition after the initial 6-month followup, which is more consistent with a fair rating at longer followup.73 Most trials reported followup of between 80 and 90 percent. Most trials did not explicitly report allocation concealment and few provided information about intervention fidelity. Several studies reported generally good methods (all or most of the following: adequate randomization methods, baseline comparability between groups, blinding of outcomes assessment, conservative handling of missing data, acceptable statistical methods, and no apparent selective reporting of outcomes), but were graded as fair primarily due to the small sample size165 or attrition.163,164

#### Findings

##### Depression Outcomes

All but two of the trials reported the proportion of the population with depressive symptoms at baseline who were below some prespecified level of symptomatology at followup, such as no depressive symptoms or below a certain threshold on a screening instrument (Appendix D Table 17). We refer to these as remission outcomes.72,73,161-164,167 Both trials that failed to report remission did report the proportion whose symptoms scores were reduced by a specific amount, to indicate treatment response.165,166 Figure 9 shows a forest plot of remission and response (where remission was not reported), ordered by increasing level of provider support beyond screening or results feedback, with general adult populations shown separately from trials targeting older adults.

Figure 9 Forest Plot of Depression Remission or Response in General and Older Adults (KQ 1)

* Response rather than remission reported.

† Subgroup with newly diagnosed depression only; results not reported for entire sample or for subgroup with previously known depression.

Abbreviations: BDI = Beck Depression Inventory; CES-D=Center for Epidemiologic Studies Depression; CG = control group; CI = confidence interval; CIDI = Composite International Diagnostic Interview; DSM = Diagnostic and Statistical Manual; GDS = Geriatric Depression Scale; HAM-D = Hamilton Depression Rating Scale; IG = intervention group; MADRS = Montgomery Asberg Depression Rating Scale; PHQ = Patient Health Questionnaire; PRIME-MD = Primary Care Evaluation of Mental Disorders; pt = point; RR = relative risk.

This figure is a forest plot of depression remission in general and older adults after screening.

General adult populations. Screening programs generally increased the likelihood of remission and treatment response in general adult populations experiencing depressive symptoms. All studies showed greater remission or response in the intervention groups, but results were statistically significant only in the two studies with greatest additional supports beyond simple screening or results feedback.73,163 However, these studies were also the two largest in this population. One of these only found a benefit for those with newly-identified depression, and did not provide data for the whole sample or the complementary subgroup with previously-known depression.73 This trial reported 47 percent remission in the intervention group after 12 months compared with 28 percent in the control group, among those with newly-identified depression (RR, 1.71 [95% CI, 1.13 to 2.57]), with a very similar effect size at 24 months.73 The largest study, with an extensive quality improvement program in a mixed population of persons with newly- and previously-identified depression, reported 58 percent remission in the intervention group compared with 49 percent in the control group at 12 months (RR, 1.19 [95% CI, 1.06 to 1.34]).163 This single study provided repeated followup over 5 years. Group differences were diminished at 24- and 57-month followup, although results were statistically significant at 57-month followup. Although the effect in this study was relatively small, this could be considered an effectiveness trial of a relatively comprehensive depression screening and care support system, conducted in naturalistic managed care settings, with minimal participant exclusion criteria, and free choice of treatment by patients and providers.

Other studies were smaller and underpowered for statistical significance of even fairly large group differences (e.g., 48% remission in intervention group vs. 27% in control group; RR, 1.79 [95% CI, 0.94 to 3.41]).162 Three studies in general adult populations also reported depression symptom measures, although data were insufficient for creating forest plots, so are presented in tabular form only (Table 21). Statistically significant benefits on depression symptoms were found in one of the two smallest trials,72,165 and only in the subgroup with newly-identified depression in one of the larger trials.73

Table 21 Results of Included Studies for KQ 1 (General and Older Adults): Depressive Symptoms

Author, Year Quality | Subgroup | Instrument | Followup, months | IG N | IG Mean Change | IGSD | CG N | CG Mean Change | CG SD | Between Group Difference (p-value)
General Adults
Bergus, 2005^72^ Fair | All participants | PHQ-9 | 2 | 24 | -5.8 | NR | 27 | -5.8 | NR | NR
Bergus, 2005^72^ Fair | All participants | PHQ-9 | 6 | 24 | -5.7 | NR | 27 | -5.0 | NR | 0.45
Jarjoura, 2004^165^ Fair | All participants | BDI-II | 6 | 33 | NR | NR | 28 | NR | NR | NR
Jarjoura, 2004^165^ Fair | All participants | BDI-II | 12 | 33 | NR | NR | 33 | NR | NR | 0.05
Rost, 2001^73^ Good | New treatment episode | CES-D | 6 | 97 | -21.7 | NR | 92 | -13.7 | NR | 0.04
Rost, 2001^73^ Good | Recently treated | CES-D | 6 | NR | -14.5 | NR | NR | -11.0 | NR | NS
Older Adults
van der Weele, 2012^166^ Good | All participants | MADRS | 6 | 107 | -1.1 | 6.1 | 103 | -2.9 | 6.3 | 0.056
van der Weele, 2012^166^ Good | All participants | MADRS | 12 | 101 | -3.1 | 6.7 | 93 | -4.6 | 7.0 | 0.088
Whooley, 2000^164^ Fair | All participants | GDS | 24 | 76 | -1.8 | 5.1 | 97 | -2.2 | 5.2 | 0.41
Bijl, 2003^167^ Fair | All participants | MADRS | 2 | 70 | -2.1 | 26.1 | 75 | -1.4 | 26.9 | NR
Bijl, 2003^167^ Fair | All participants | MADRS | 6 | 70 | -12.4 | 23.8 | 75 | -9.5 | 21.7 | <0.05
Bijl, 2003^167^ Fair | All participants | MADRS | 12 | 70 | -10.9 | 23.9 | 75 | -10.9 | 21.6 | NR
Callahan, 1994^161^ Fair | All participants | HAM-D | 6 | 76 | -4.2 | NR | 60 | -4.9 | NR | NS
Callahan, 1994^161^ Fair | All participants | HAM-D | 9 | 76 | -6.1 | NR | 60 | -7.0 | NR | NS

Abbreviations: BDI = Beck Depression Inventory; CES-D = Center for Epidemiologic Studies Depression; CG = control group; GDS = Geriatric Depression Scale; HAM-D = Hamilton Rating Scale for Depression; IG = intervention group; MADRS = Montgomery Asberg Depression Rating Scale; NR = not reported; NS = not statistically significant; PHQ = Patient Health Questionnaire; SD = standard deviation.

Older adult populations. Screening programs were not successful in reducing depression in older adults, and even had a clinically significant (but not statistically significant) paradoxically negative effect in one new study for this body of evidence conducted in the Netherlands. As discussed below, issues specific to the Dutch health care system and the study design could be factors explaining these results. Evidence specific to the United States was limited to two trials, neither of which showed a benefit of screening programs, and neither had substantial added provider supports beyond screening results feedback.

##### Other Beneficial Outcomes

A few studies reported additional beneficial outcomes, such as improved quality of life163,165,167 or functioning (Appendix D Tables 18 and 19).161 The large trial in general adult populations reported improvement in the mental component scale of the SF-36 but not the physical component, while others generally showed no greater improvement in intervention participants on various other beneficial outcomes. None of the trials reported suicide-related outcomes.

### KQ 1b Does the Effect of Screening Vary By Population Characteristics?

Two studies (one in general and one in older adults) were limited to persons with untreated, presumably newly-identified depression,165,166 and one reported results separately for general adults with newly-identified and previously-known depression, which was planned a priori.73 In this study, the intervention was only beneficial for those with newly-identified depression. Neither of the studies that were entirely limited to those with untreated depression showed a statistically significant benefit or harm, but point estimates were widely discrepant between these two studies, suggesting a large potential benefit in general adults (RR, 1.87 [95% CI, 0.74 to 4.73])165 and a large potential detrimental effect in older adults (RR, 0.62 [95% CI, 0.39 to 1.01]); complicating interpretation, these studies also varied in screening and intervention approaches and population characteristics.166 For example, the Dutch study showing a potential detrimental effect had fewer low-income individuals (<20%) than the U.S. study showing large potential benefit (100% below poverty line), but almost half (44%) of the population in the Dutch study had a DSM-IV diagnosis, although none were being treated for depression. Finally, as discussed next, studies conducted in the Netherlands appear to differ qualitatively from the rest of the body of evidence, and results may reflect a different health care system.

One study reported effects in separate subgroups by age166 and one study did so by race/ethnicity.163 There was some suggestion that benefits were greater in African American and Latino populations than in European Americans; however, data were limited to a single study. Evidence was even more limited or completely absent to evaluate differential effects on age, sex, and comorbid conditions.

### KQ 2 What Are the Harms Associated With Primary Care Depression Screening Programs in the General Adult Population, Including Older Adults?

One KQ 1a trial reported that no adverse events were attributable to the intervention; however, this was only reported for the subset with newly-identified depression.73 None of the other KQ 1/KQ 1a trials reported on harms, and we found no additional studies addressing harms of screening beyond the trials included for KQ 1 and KQ 1a.

Control groups showed greater likelihood of remission in both of the trials conducted in older adults in the Netherlands. Results were not statistically significant in either study, but differences were fairly large in one of the studies.166 The recent good-quality trial by van der Weele and colleagues reported that 33 percent of the control participants showed a 50 percent or greater decrease on the Montgomery-Asberg Depression Rating Scale (MADRS) compared with 21 percent in the intervention group. This study was limited to adults age 75 years and older who were not already being treated for depression. Study investigators conducted home-based screening for half of the sample, and the other half were screened by mail or phone followup to the mailed questionnaire. Those who screened positive were referred to a community mental health clinic, which offered individual counseling and a 10-week course about coping with depression. While most of the participants who were referred “accepted” the referral (it is unclear what “accepted” meant), only 19 percent participated in the 10-week course, and only 70 percent of those completed the course. The authors of this study point out that in the Dutch health care system, primary care providers often have longstanding, close relationships with their older patients, and continuity of care is the norm. They speculated that while their aim was to improve depression care with minimal extra burden to the provider, perhaps “the marginal role of the [general practitioner in the study design] gave a breach in continuity of care that was not beneficial.” In addition, control group participants in this study had more than twice the mortality rate of intervention participants (5.8% vs. 14.4%), suggesting probable group differences in baseline frailty or health status or differential reasons for attrition that could have biased results.

### KQ 2a Do the Harms Vary By Population Characteristics?

We found no data addressing variability in harms by population characteristics.