# Methods

## Scope and Purpose

This targeted update review examined the evidence for depression screening in general adult populations (including older adults) and also considered comprehensive evidence for benefits and harms of depression screening in pregnant and postpartum women. Studies in pregnant and postpartum women were excluded from the previous USPSTF review, so a more detailed analytic framework was developed for these populations, to capture questions previously addressed in general and older adult populations. The USPSTF will use this review to update its 2009 recommendation on depression screening in primary care in the United States.86

We developed separate analytic frameworks for general adult populations and pregnant women, with additional questions that addressed pregnant and postpartum women. In general adult populations, we examined studies that compared depression and other outcomes in persons who were screened versus not screened (Key Question [KQ] 1 for benefits, KQ 2 for harms), or whose providers received screening results versus did not receive screening results (KQ 1a for benefits, KQ 2 for harms). Evidence related to diagnostic accuracy of depression screening instruments and effectiveness of depression treatment was not included in the current review for general adult populations because they were considered established by the previous reviews. For pregnant and postpartum women, however, we examined direct evidence of benefits (KQ 1) and harms (KQ 3) of depression screening and the chain of indirect evidence, including the diagnostic accuracy of commonly used screening instruments (KQ 2), as well as the benefits (KQ 4) and harms (KQ 5) of treatment in women with screen-detected depression.

## Key Questions and Analytic Framework

We developed analytic frameworks and KQs in consultation with USPSTF members for pregnant and postpartum women (Figure 1) and the general adult population, including older adults (Figure 2). The KQs are listed below.

Figure 1 Analytic Framework: Pregnant and Postpartum Women

This figure is the analytic framework that depicts the five Key Questions (KQs) to be addressed by the systematic review. The figure illustrates how depression screening programs among pregnant and postpartum women may improve health outcomes (KQ1) and result in the identification of individuals with depression (KQ2) who may be intervened upon. Interventions may result in changes in health outcomes as well (KQ4). The analytic framework also depicts the possible adverse events occurring after screening (KQ3) or treatment (KQ5).

Figure 2 Analytic Framework: General and Older Adults

This figure is the analytic framework that depicts the two Key Questions (KQs) to be addressed by the systematic review. The figure illustrates how depression screening programs among the general adult population (including older adults) may improve health outcomes (KQ1) but may also have possible harms (KQ2).

### Pregnant and Postpartum Women

1. Do primary care depression screening programs in pregnant and postpartum women result in improved health outcomes (decreased depressive symptomatology; decreased suicide deaths, attempts, or ideation; improved functioning; improved quality of life; or improved health status)?
  a. Does sending depression screening test results to providers (with or without additional care management supports) result in improved health outcomes?
  b. Does the effect of screening vary by population characteristics^*^?
    * Population characteristics include sex, age, race/ethnicity, comorbid conditions, and new-onset depression versus recurrent depression.
2. What is the test performance of the most commonly used primary care depression screening instruments in pregnant and postpartum women?
  a. Do the test performance characteristics of the screening instruments vary by population characteristics^*^?
3. What are the harms associated with primary care depression screening programs in pregnant and postpartum women?
  a. Do the harms vary by population characteristics^*^?
4. Does treatment (psychotherapy, antidepressants, or collaborative care) result in improved health outcomes (decreased depressive symptomatology; decreased suicide deaths, attempts, or ideation; improved functioning; improved quality of life; or improved health status) in pregnant and postpartum women who screen positive for depression in primary care?
  a. Do the effects of the interventions vary by population characteristics^*^?
5. What are the harms of treatment in pregnant and postpartum women who screen positive for depression in primary care?
  a. Do the harms vary by population characteristics^*^?
  b. What is the prevalence of other selected serious harms of treatment with antidepressants in the general (i.e., not limited to primary care) population of pregnant and postpartum women?

### General Adult Population, Including Older Adults

1. Do primary care depression screening programs in the general adult population, including older adults, result in improved health outcomes (decreased depressive symptomatology; decreased suicide deaths, attempts, or ideation; improved functioning; improved quality of life; or improved health status)?
  a. Does sending depression screening test results to providers (with or without additional care management supports) result in improved health outcomes?
  b. Does the effect of screening vary by population characteristics^*^?
2. What are the harms associated with primary care depression screening programs in the general adult population, including older adults?
  a. Do the harms vary by population characteristics^*^?

## Data Sources and Searches

We conducted an initial search for existing synthesized literature and guidelines related to depression screening and treatment in MEDLINE/PubMed, the Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews, BMJ Clinical Evidence, the Institute of Medicine, the National Institute for Health and Clinical Excellence, PsycINFO, the Agency for Healthcare Research and Quality (AHRQ), the American Psychiatric Association, the American Psychological Association, the Campbell Collaboration, the Canadian Agency for Drugs and Technologies in Health, the National Health Services' Health Technology Assessment Programme, and the Centre for Reviews and Dissemination from 2008 through October 3, 2013. The search strategies are listed in Appendix B.

For pregnant and postpartum women, we systematically evaluated all relevant reviews through abstract and full-text review, and identified existing systematic reviews to use as foundational reviews for benefits and harms of screening and treatment, based on the approach outlined by Whitlock and colleagues.88 We identified three good-quality reviews that served as foundational reviews. We chose these reviews based on relevance (i.e., inclusion and exclusion criteria that were at least as inclusive as our review), having conducted a good-quality search, having reported good-quality article evaluation methods, and recency.89-91 For the question of harms of antidepressants (KQ 5), the foundational review was of sufficient quality and the evidence base was so extensive that we used this review directly as evidence in our report and did not re-evaluate individual studies included in this review.91 We used the other two foundational reviews as the starting point for study identification for other KQs related to pregnant and postpartum women, and then searched for additional original research published after the search windows of these foundational reviews. We evaluated all studies included in each of these foundational reviews against our a priori inclusion/exclusion criteria. Then we searched for newly published literature bridging from these foundational reviews. For general adult populations, we evaluated all included studies in the previous USPSTF review in addition to searching for newly published literature.

We searched for newly published literature in the following databases: MEDLINE/PubMed, PsycINFO, and the Cochrane Central Register of Controlled Trials through January 20, 2015 (Appendix B). In general adult populations, we searched from January 1, 2009, bridging from the previous USPSTF review. We began our bridge search for pregnant and postpartum women from January 1, 2012, since there was at least one foundational review with a search period for each KQ for pregnant and postpartum women that extended into 2012. We also reviewed reference lists of relevant studies and reviews to identify additional potentially relevant studies that were not identified by our literature searches or foundational reviews. We managed literature search results using the bibliographic management software program Reference Manager,® version 12.0 (Thomson Reuters, New York, NY).

## Study Selection

Two investigators independently reviewed titles and abstracts using an online platform (Abstrackr)92 against prespecified inclusion and exclusion criteria (Appendix B Tables 1 and 2). Full-text articles were reviewed by two investigators for a final inclusion/exclusion decision. Disagreements were resolved through discussion or consultation with the other investigators. A list of excluded studies after full-text review, including the reasons for exclusion, is available in Appendix C.

We included fair- and good-quality studies published in the English language that were conducted among adults age 18 years and older living in countries ranked as having “very high” human development according to WHO,93 including:

- Randomized, controlled trials (RCTs) and nonrandomized, controlled clinical trials (CCTs) examining benefits or harms of screening or treatment (psychotherapy, pharmacotherapy, or collaborative care) in pregnant and postpartum women.
- Studies of diagnostic accuracy of the PHQ or EPDS in pregnant and postpartum women.
- Systematic reviews, RCTs, CCTs, or large comparative observational studies that examined harms of antidepressants in pregnant or postpartum women.
- RCTs and CCTs examining benefits or harms of screening in general or older adult populations.

We defined postpartum women as those whose babies were younger than age 1 year at study enrollment. We required that studies assessing the benefits and harms of screening for either population be conducted in a primary care setting, including obstetrics/gynecology or pediatrics for postpartum depression screening. Studies limited to persons with other medical or mental health conditions were excluded; however, we did not exclude studies that included some persons with such conditions, as long as it was not a requirement of participation. We did not exclude screening studies that included participants who already had a chart diagnosis of depression or were being treated for depression. Studies of depression screening could also include additional treatment elements, as long as the screening test results were given to the primary care provider. We required that the control group participants either were not screened or did not have their screening test results sent to their provider.

Studies of psychotherapy (examined only for pregnant and postpartum women) could additionally take place in virtual (i.e., online or computer-based) or mental health clinic settings. We required that studies of depression treatment use population-based screening to identify eligible patients. We considered studies to include population-based screening if they attempted to recruit all or a consecutive or random subset of women in a specific setting or population during the study's recruitment window, with individual outreach to potential participants for depression screening as part of determination of study eligibility. Thus, we excluded studies in which recruitment was based on referral, from populations of patients with known or likely depression (e.g., persons identified as having depression in their medical charts), or from volunteers recruited through media or other advertising. Control groups in treatment studies could include usual care, no intervention, waitlist, attention control, or a minimal intervention (e.g., ≤15 minutes of information, not intended to be a therapeutic dose). We excluded comparative effectiveness studies.

We excluded trials exploring the efficacy of complementary and alternative therapies, such as yoga, exercise, transcranial stimulation, and dietary supplements such as St. John's wort, since they are not widely used in primary care settings. We also excluded trials focused on second-line treatments for severe depression when first-line treatments are not effective, such as polypharmacy and electroconvulsive therapy.

We required minimum followup of 6 weeks for studies of benefits or screening and treatment, and harms of psychotherapy or collaborative care interventions. We had no minimum followup for harms of antidepressants.

For diagnostic accuracy studies (examined only for pregnant and postpartum women), the time between the index and reference tests could not exceed 2 weeks on average. In addition, these studies must have had patients covering a wide spectrum of symptom severity, comparable to what would occur in typical primary care settings, including those without symptoms, those with subclinical symptomatology, and those with diagnostic-level symptomatology (i.e., case-control designs were excluded). A valid reference standard was a structured or semistructured diagnostic interview with a trained interviewer or a nonbrief (>5 minutes) unstructured interview with a mental health clinician. Studies that only gave the reference test to a subset of participants had to make appropriate adjustments to their analysis or provide sufficient data to allow us to adjust the analysis. Studies had to report sensitivity, specificity, positive predictive value (PPV) or negative predictive value (NPV), or the raw data to allow us to calculate diagnostic accuracy.

We included a variety of study designs in examination of harms of antidepressants in pregnant and postpartum women. Our primary data source was one of the foundational reviews that included extensive information on harms of antidepressant treatment.91 We focused on serious maternal or fetal/infant harms. Maternal harms included suicidality, serotonin syndrome, cardiac effects, seizures (bupropion only), bleeding, cardiometabolic effects, and preeclampsia. Infant harms included neonatal death, major malformations, small for gestational age/low birth weight, cardiopulmonary effects, and other serious events requiring medical attention. Comparative cohort studies had to be large (minimum of 10 cases in each exposure group) and include appropriate control group participants who were not taking antidepressants.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of included studies using criteria defined by the USPSTF94 and supplemented it with criteria from the Quality Assessment of Diagnostic Accuracy II95 and the Newcastle-Ottawa Scale96 for diagnostic accuracy and observational studies, respectively (Appendix B Table 3). We also used the Assessment of Multiple Systematic Reviews (AMSTAR)97 to assess the quality of the foundational evidence review used for harms of antidepressant treatment in pregnant and postpartum women.91 Each study was assigned a final quality rating of good, fair, or poor and disagreements were resolved through discussion.

We excluded studies rated as poor quality (i.e., attrition >40%, differential attrition of >20%, other “fatal flaws,” or the cumulative effects of multiple minor flaws and/or missing important information significant enough to limit our confidence in the validity of the results). Good-quality studies included all or most of the following: adequate randomization procedures, allocation concealment, blinding of outcome assessors, reliable outcome measures, comparable groups at baseline (with specified eligibility criteria), low attrition, acceptable statistical methods, and adequate and faithful adherence to the intervention. We rated studies as fair quality if they did not meet most of the good-quality criteria.

One investigator abstracted data from all included studies into a Microsoft Access® database (Microsoft Corporation, Redmond, WA) and a second investigator checked the data for accuracy. We abstracted study design characteristics, population demographics, baseline history of depression and other mental health conditions, screening and intervention details (if applicable), depression outcomes, other health outcomes (e.g., suicidality, mortality, quality of life, functioning, health status, child/infant outcomes, emergency department visits, or inpatient stays), adverse events, and diagnostic accuracy outcomes (if applicable).

## Data Synthesis and Analysis

We created summary tables for all KQs showing study, population, and intervention characteristics (if applicable) and outcomes for qualitative evidence synthesis. We used these tables and forest plots of results to examine data for consistency, precision, and relationship of effect size with key potential modifiers such as treatment contact time, control group recovery or response, and time to followup. We had sufficient data with acceptable comparability between studies to conduct meta-analysis only for trials examining the benefits of cognitive behavioral therapy (CBT) or related approaches to treat depression in pregnant and postpartum women compared to usual care or other control conditions. We ran a random-effects model using the DerSimonian and Laird pooled estimate, which we felt was acceptable given that our body of evidence for this outcome consisted of 10 studies, with low statistical heterogeneity and fairly comparable sample sizes.98 Because the number of studies was fairly small, we also ran a sensitivity analysis using a restricted maximum likelihood model with the Knapp-Hartung modification for small samples. We used Stata version 13.1 (StataCorp LP, College Station, TX) for all analyses. When we pooled 10 or more studies, we also examined forest plots and ran Egger's test to examine funnel plot asymmetry, which is an indicator of small study bias, sometimes related to publication bias.99

For the studies of instrument accuracy, we calculated sensitivity and specificity with Jeffrey's confidence intervals (CIs), using data from 2×2 tables that included true positives, false positives, false negatives, and true negatives. If these data were not reported directly, we created 2×2 tables based on the total sample size, number of persons with the diagnosis according to the reference standard, sensitivity, and specificity. Several studies only verified a negative screening result in a random sample of participants scoring below a predetermined threshold (which was lower than the typical cutoff for a positive result in all cases).100-102 For these studies, we applied the proportion with a depressive disorder according to the reference standard to the full sample of participants scoring below the threshold and calculated sensitivity and specificity based on these extrapolated results.103 In all cases, there were no false negatives, so sensitivity did not change, but specificity increased with extrapolation. Side-by-side plots of sensitivity and specificity were created in R, version 3.2.2. (The R Foundation, Vienna, Austria).

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF Web site for public comment from March 27 to April 23, 2014. The draft version of this report was reviewed by experts and USPSTF federal partners and posted for public comment on the USPSTF Web site from July 28 to August 25, 2015. Comments received during any period were reviewed, considered, and addressed, as appropriate. No new substantive issues were identified that were not previously considered and no major changes were made to the text in the final report.

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the USPSTF. We consulted with USPSTF liaisons at key points in the review, including the development of the research plan (i.e., KQs, analytic framework, and the inclusion/exclusion criteria), as well as finalizing the systematic review. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the review, and assisted with public comment on the research plan and draft review. The USPSTF and AHRQ had no role in the study selection, quality assessment, or the writing of the systematic review.