# Introduction

## Condition Definition

Depression is a term that encompasses many depressive disorders, including major depressive disorder (MDD), persistent depressive disorder (formerly called dysthymia), and minor depression.1 Individuals with depression often experience not only sadness, but a lack of interest or enjoyment in activities, decreased energy, insomnia, weight changes, feelings of loss and worthlessness, and recurrent thoughts of death or suicide. Postpartum depression describes depressive episodes that occur within 12 months of delivery.2

## Prevalence and Risk Factors for Depression

Depression is a common mental disorder in the United States. In 2009 to 2012, approximately 7 percent of the U.S. population met the criteria for a current depressive disorder, according to the National Survey on Drug Use and Health (NSDUH) and National Health and Nutrition Examination Survey.3,4 Depression rates are higher in women of reproductive age, at 10.9 percent according to the NSDUH (7.7% among pregnant women, 11.1% among nonpregnant women).5,6 Data from the 2004 to 2005 National Epidemiologic Survey on Alcohol and Related Conditions reported prevalence of 9.1 percent in pregnant women, 10.2 percent in postpartum women, and 13.1 percent in women of childbearing age who were not in the postpartum period.7 The only estimates of depression available in U.S. primary care settings come from rather outdated meta-analysis of eight studies published between 1987 and 2000, estimating a prevalence of 12.5 percent in primary care in the United States.8

In addition to varying by sex, prevalence rates among the general American adult population vary by age, race/ethnicity, education, geographic location, poverty level, and employment. Women, young and middle-aged adults, and nonwhite individuals had higher rates of depression compared to their counterparts, as did those who were undereducated and unemployed (Table 1).9

Table 1 Percentage of U.S. Adults With at Least One Major Depressive Episode in the Past Year, NSDUH 2013

Category | Characteristics | ≥1 Major Depression Episode in Past Year (%)
Age (years) | 18-25 | 8.7
Age (years) | 26-29 | 8.1
Age (years) | 30-34 | 7.8
Age (years) | 35-39 | 7.1
Age (years) | 40-44 | 7.5
Age (years) | 45-49 | 7.4
Age (years) | 50-54 | 7.9
Age (years) | 55-59 | 6.6
Age (years) | 50-65 | 6.1
Age (years) | ≥ 65 years | 2.6
Sex | Men | 5.1
Sex | Women | 8.1
Race/Ethnicity | White | 7.3
Race/Ethnicity | Black | 4.6
Race/Ethnicity | Hispanic | 5.8
Race/Ethnicity | American Indian or Native American | 8.9
Race/Ethnicity | Native Hawaiian or Other Pacific Islander | 1.6
Race/Ethnicity | Asian | 4.0
Race/Ethnicity | Multiracial | 11.4
Education | Less than high school | 6.3
Education | High school graduate | 6.0
Education | Some college | 7.8
Education | College graduate | 6.5
Poverty level | Less than 100% | 8.9
Poverty level | 100-199% | 7.9
Poverty level | ≥ 200% | 5.8
Employment status | Full-time | 5.3
Employment status | Part-time | 7.8
Employment status | Unemployed | 9.5
Employment status | Other (e.g., student, retired or disable) | 8.0

Abbreviation: NSDUH = National Survey on Drug Use and Health9.

Other groups at higher risk for developing depression include persons with chronic illnesses (e.g., cancer, cardiovascular disease),10,11 other mental health disorders (including substance misuse),12 and a family history of psychiatric disorders.13 A meta-analysis of 84 studies examining risk factors for postpartum depression, for example, identified 13 significant predictors: prenatal depression, poor self-esteem, childcare stress, prenatal anxiety, life stress, decreased social support, single/unpartnered relationship status, history of depression, difficult infant temperament, maternity blues, lower socioeconomic status, and unintended pregnancy.14 Among older adults, the risk factors for depression include disability and poor health status related to medical-illness-complicated grief, chronic sleep disturbance, loneliness, and a personal history of depression.15

## Burden of Depression

Globally, MDD is the leading cause of disability among adults in high-income countries. Depression also reaps a significant economic burden as it is associated with decreased work productivity and work absenteeism.16,17 Depression costs an estimated $23 billion in lost productivity to U.S. employers.18 In 2009, an estimated $22.8 billion was spent on depression treatment, with the largest portion (52.8%) being spent on prescription medications, followed by ambulatory care visits (35.8%).19

Depression is also associated with higher mortality20-23 and greater risk of cardiovascular events.23 In addition, depression may reduce the likelihood that persons with other health conditions comply with prescribed treatments or manage self-care effectively. This makes depression a particularly important issue within primary care settings, as the presence of depression could have an impact on the effectiveness of care that practitioners are providing for other conditions. A recent study of U.S. veterans, for example, showed patients with depression died younger (71 vs. 76 years) and had more years of potential life lost (13 vs. 10 years) than patients without depression.24 Depression is an important risk factor for suicide and suicide attempts.25,26

Depression has a major impact on quality of life for both the person with depression and his or her family members. The National Comorbidity Survey Replication (NCS-R) has documented substantial role impairments associated with MDD related to work, household responsibilities, social life, and personal relationships.27 In older adults, depressive disorders were the third-leading cause of loss of quality-adjusted life years in primary care patients older than age 65 years, behind only arthritis and heart disease.28 Family members of patients with depression also experience substantial burden and relational strain29 as well as more depressive and anxiety disorders than those without a family member with depression.30,31 Financial difficulties are the most commonly reported family problem in major depression due to lost productivity of the individual with depression (and caregiver) and costs of depression treatment.31 Children of parents with depression display more emotional and behavioral problems, poorer peer social competence, and poorer school adjustment than those with parents without depression.29,32,33

## Etiology and Natural History

While depression onset can occur at almost any age, the average age of onset among U.S. adults is 32 years.34 Depression is often a chronic disease characterized by periods of remissions and recurrences, although the course of depression varies widely from person to person. A meta-analysis of remission rates among untreated study participants with major depression estimated that 23, 32, and 53 percent would remit within 3, 6, and 12 months, respectively.35 Another systematic review of antidepressant studies with a followup of 10 or more years found 40 to 85 percent of participants experienced a recurrence after approximately 3 years.36 Among older adults, 8 to 10 percent of those with subthreshold depression developed major depression within a year and only 27 percent entered remission within another year later.37 While predicting recurrence is difficult, the number of previous episodes and residual symptoms are the strongest predictors for recurrence.38

The causes of depression are likely multifactorial and include both biological and environmental factors. While adverse life events increase the likelihood of depression, genetic factors may predispose persons to be affected by environmental factors, such as life events, to a greater or lesser degree.39 According to the cognitive model of depression, persons with depression have characteristic “depressogenic” ways of acquiring and processing information from their environment, which implies that the way individuals interpret their experiences directly influences the development of depression.40 Other factors come into play as well in psychological models of depression, such as social skills, pleasant activities, and other life skills such as problem solving.41

The neurobiology of MDD traditionally focuses on two monoamine neurotransmitters—serotonin and norepinephrine—which are likely to be low in individuals with depression.42 These neurotransmitters are known for regulating mood and functions such as appetite, sleep, and attention. Selective serotonin reuptake inhibitors (SSRIs), serotonin-norepinephrine reuptake inhibitors (SNRIs), and other second-generation antidepressants are commonly used pharmacotherapy for depression. The structure of the brain may also have a role in depression, as evidenced by a meta-analysis of 225 studies comparing brain images of individuals without depression and patients with MDD that found significant differences, including smaller volume of the frontal lobe and limbic system in those with depression.43 Similar findings are also seen in older adults.44 These structures are responsible for learning, memory, thought processing, and maintaining emotional stability, and their malfunction is considered central to the pathophysiology of depression.42 It is unclear, however, the degree to which depression results from or causes structural changes in the brain.

Genetics also play a role in developing depression. Studies have shown that first-degree relatives of individuals diagnosed with MDD have a 2- to 3-fold greater risk of developing MDD than the general population. In particular, age at onset in the 30s or younger and recurrent episodes of MDD have been identified as genetic characteristics that predict the largest relative risk (RR) for first-degree relatives to develop MDD. Studies examining the association of MDD with polymorphisms have resulted in mixed evidence, largely due to lack of adequate power to test for genetic susceptibilities, as well as limited technological capacity. While studies of genetic association have historically been limited to populations of twins and adopted populations, whole-genome linkage studies have recently become feasible.45,46

## Current Clinical Practice

Researchers have developed a framework that shows how successful treatment of depression in primary care involves a number of steps, including recognition that a patient is depressed, initiation of treatment, and completion of an adequate course of treatment.47 Estimates of clinician recognition of depression in the United States are wide-ranging, from 21 to 76 percent of depression cases, with about half of the estimates falling above and half below the international pooled average of 47.3 percent.48 One study reported sensitivity of 49.2 percent and specificity of 81.1 percent for primary care providers in the United States in accurately identifying major depressive episodes.8 Accuracy may be lower for older adults (age ≥65 years) than for younger adults.49

If depression is likely to be missed in primary care, one might hypothesize that this would be due to relatively mild symptom severity in patients seen in primary care. However, symptom severity in patients seen in primary care settings was similar to that of patients seen in mental health specialty settings in earlier research.50 There were, however, sociodemographic differences in the cases seen in primary and specialty care clinics—patients with depression seen in primary care settings were more likely to be older, female, African American, or unemployed. Notably, suicidality was higher among patients being seen in specialty care settings, despite similar symptom severity.

In terms of typical screening methods, less is known about how often primary care providers use formal screening instruments to identify depression. While some health systems have implemented large-scale formal screening programs, depression screening in other settings may be very limited. The accuracy of screening methods that do not involve a formal screening measure is unknown and presumably quite variable. According to the 2010 U.S. National Ambulatory Medical Care Survey (NAMCS), depression screening was recorded for only 2.3 percent of visits, although this likely underestimates the true screening of patients over time, since patients may have been screened at other recent visits.51 These rates have not changed compared to other cross-sectional studies examining NAMCS data from the previous 5 years.52,53

Even among those who are appropriately screened and diagnosed, many patients do not receive treatment. Population-based surveys suggest that only about half of persons with MDD are treated in a given year.27,54 While most patients with major depressive episodes do eventually get treatment, data from the World Health Organization's (WHO's) World Mental Health Survey showed that only 35.4 percent of Americans with depression are treated within a year of depression onset, and the median time to treatment initiation is 4 years.55 Further, among Americans receiving treatment, only 37.5 percent of patients with MDD received a minimally adequate dose in a given year, according to NCS-R data.56 A minimally adequate dose was defined as a) 2 or more months of an appropriate medication plus five or more visits with a physician, or b) eight or more visits with a health care provider (including mental health specialists) or human services provider (e.g., social worker, religious/spiritual advisor) lasting an average of 30 minutes per visit.

While these data raise concerns that depression is frequently overlooked by primary care providers, there is also growing concern about overtreatment and misdiagnosis, particularly in light of rising rates of antidepressant use in the population.57 A recent study using data from the 2009 to 2010 NSDUH examined agreement between patient self-report of depression diagnosis from a medical professional in the past 12 months and the presence of Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) criteria for a major depressive episode in the past year based on a structured interview.58 This study found that only 38 percent of surveyed patients reporting a clinician-identified major depressive episode met the DSM-IV criteria, and this rate dropped to 18 percent for older adults (age ≥65 years).49 Forty-three percent of adults (of all ages) not meeting DSM-IV criteria, however, did meet the criteria for minor depression or lifetime minor or major depression. This suggests that some of these patients may have been in a prodromal or recovery phase in which they were symptomatic but did not meet full criteria for diagnosis, may have misremembered the timing of their depressive diagnosis, or may have been incompletely treated and potentially in need of treatment despite not meeting current MDD criteria. The use of antidepressant medications for the treatment of primary care clinician–diagnosed depression is high, and their use was reported by a majority of those receiving treatment, whether they met DSM-IV criteria (84%) or not (74%).58

We found no information on depression detection rates in postpartum women. One trial of depression treatment during pregnancy examined medical records of participants who volunteered to participate in the study, met DSM-IV criteria for MDD, and scored 14 or higher on the Hamilton Rating Scale for Depression (HAM-D).59 Women in this study were assessed by a wide variety of prenatal care providers and depression was noted in the charts of 56 percent of these pregnant women. Assuming this is typical of community care, identification of depression in pregnant women may be comparable to that in the general adult population, in which estimates average just under 50 percent, but are wide-ranging.

Physician surveys, however, suggest fairly high rates of depression screening in postpartum populations. For example, several surveys of obstetricians-gynecologists, family physicians, and pediatricians show that these providers consider that it is their responsibility, or that it is important, to identify postpartum depression.60-63 As such, approximately 70 percent of surveyed obstetricians-gynecologists and family physicians reported that they often or always screen patients for postpartum depression.64,65 Surveys also show that providers generally do not routinely use formal screening tools, but instead use their own clinical methods.60,64,66,67 For example, while 79 percent of physicians surveyed about postpartum screening practices reported that they are unlikely to use a formal screening tool, 43 percent were almost certain to ask whether women felt down, depressed, or hopeless, and 27 percent were almost certain to ask about women's interest in usual activities.67 Commonly reported barriers to postpartum depression screening included lack of knowledge or training and time constraints.62-65

We could find little information on how often treatment was generally recommended and accepted after depression is identified in pregnant and postpartum women.68 We identified one trial of a depression screening and treatment support intervention that found that 11 percent of postnatal women who were identified by their provider as depressed received counseling in usual care, 35 percent received antidepressants, and a total of 37 percent received either one.69 Treatment persistence in pregnant and postpartum women is unknown, although discontinuation may be high for antidepressants. This is evidenced by one observational cohort study of Medicaid claims data that identified pregnant women who received a diagnosis of depression and who filled at least two antidepressant prescriptions during pregnancy. The median time to discontinuation of antidepressants was 80 days, well below the generally recommended 6 to 9 months course recommended by the American Psychiatric Association.70 Only about 20 percent of the women in this study continued their antidepressants for 6 months.68

## Rationale for Screening for Depression

Screening in primary care may help identify those individuals with undiagnosed depression and could help shorten the typical 4-year lag between depression onset and treatment initiation, which could potentially prevent substantial suffering. Screening for depression is different from cancer screening in that patients are not asymptomatic, but rather their depression is not yet recognized by their provider. However, patients may also be unaware that what they are experiencing is depression. Given the episodic nature of depression, frequently fragmented nature of mental health care, and stigma associated with mental health conditions, screening programs may have a side benefit of helping to identify patients who have been treated but are still symptomatic and need more effective depression treatment, or whose depression has re-emerged after a remission. Indeed, previous studies involving population-based screening in primary care patients indicated that the majority of identified patients had a history of prior depressive episodes, in both general adult populations71-73 and older adults.74 Depression screening also presents an opportunity to identify patients who are suicidal among those screening positive. While the USPSTF has not recommended universal screening for suicide risk, it does note that “primary care clinicians should be aware of psychiatric problems in their patients and should consider asking these patients about suicidal ideation and referring them” for treatment.75 Depression screening may also create opportunities to discuss other issues or underlying causes of depression symptoms, such as intimate partner violence.

## Screening Instruments

The Patient Health Questionnaire (PHQ) is the most commonly used depression screening instrument in the United States.76 Other commonly used depression screening instruments include the Hospital Anxiety and Depression Scales (HADS) among adults, the Geriatric Depression Scale (GDS) among older adults, and the Edinburgh Postnatal Depression Scale (EPDS) among pregnant women. Table 2 provides more detailed descriptions of instruments that can be used for depression screening. Positive screening tests should be followed by a more detailed interview to determine the nature of the depression for diagnostic and treatment planning purposes, rather than assigning a diagnosis of depression based only on a positive screening test.

Table 2 Depression Symptom Rating Scales

Instrument | Number of Items | Scoring Range | Administration Time | Typical Cut-Points
Beck Depression Inventory (BDI/BDI-II) | 21 | 0-63 | 10 minutes | 11 = mild 17 = borderline clinical 21 = moderate 31 = severe 40 = extreme
Center for Epidemiologic Studies Depression Scale (CES-D) | 20 | 0-60 | 10 minutes | 16
Edinburgh Postnatal Depression Scale (EPDS) | 10 | 0-30 | 5 minutes | 0-9 = mild distress 10-12 = moderate distress 13 = high likelihood of diagnosis
Geriatric Depression Scale (GDS Long Form) | 30 | 0-30 | 5 minutes | 0-9 = normal 10-19 = mild 20-30 = severe
Geriatric Depression Scale, 15 item (GDS Short Form) | 15 | 0-15 | 5-7 minutes | ≥ 6
Hamilton Depression Rating Scale (HDRS/HAM-D) | 17 | 0-54 | 15 minutes | 7-17 = mild 18-24 = moderate ≥24 = severe
Hospital Anxiety and Depression Scale (HADS) | 14 (7 specific to depression) | 0-21 | 2-5 minutes | ≥ 8
Montgomery-Asberg Depression Rating Scale (MADRS) | 10 | 0-60 | 15 minutes | 15 = mild 25 = moderate 31 = severe 44 = very severe
Patient Health Questionnaire– Depression (PHQ-9) | 9 | 0-27 | 5-10 minutes | <5 = minimal 5-9 = mild 10-14 = moderate 15-19 = moderately severe 20-27 = severe

## Interventions to Treat Depression

There are many available treatments for depression, including psychotherapy and pharmacotherapy, both of which are widely available either directly in primary care or through referral from primary care. More than half of patients treated for MDD receive treatment in general medicine settings, with the remaining patients receiving care in mental health specialty settings.56

Antidepressant medications are the most commonly used treatment for depression (Table 3), with second-generation antidepressants accounting for approximately 90 percent of antidepressant utilization in 2009.^77^ Approximately one third of persons with severe symptoms of depression take antidepressant medication, and as much as 23 percent of all women in the United States ages 40 to 59 years take antidepressants, according to National Center for Health Statistics data from 2005 to 2008.^78^ While serious harms of psychotherapy have not been identified, antidepressants are associated with some serious adverse events, including increased suicidality in adolescents and younger adults, serotonin syndrome, and gastrointestinal bleeding. They are also frequently associated with more minor adverse effects, such as weight gain, sedation, and adverse sexual effects.79,80 Second-generation antidepressants have a “C” pregnancy rating, except for paroxetine, which has a “D” rating (Appendix A Table 1). A “C” rating means that animal studies at higher than human doses have been shown to harm the fetus, and a “D” rating means there is evidence of human fetal risk based on adverse events reported from investigational or marketing studies. The U.S. Food and Drug Administration (FDA) will soon be changing its pregnancy and lactation labeling information for prescription drugs, including antidepressants.81 Second-generation antidepressants are excreted into breast milk.82

Table 3 FDA-Approved Pharmacotherapy for Depression in Adults

Category | Drug Class | Generic Names (Brand Name)
First-Generation | Tricyclic Antidepressants (TCAs) | Amitriptyline Amoxapine Clomipramine Desipramine (Norpramin) Doxepin (Sinequan) Imipramine (Tofranil) Maprotiline Nirtriptyline Nortriptyline (Pamelor) Protriptyline (Vivactil) Trimipramine (Surmontil)
First-Generation | Monoamine Oxidase Inhibitors (MAOIs) | Isocarboxazid (Marplan) Phenelzine (Nardil) Selegiline (Emsam [transdermal patch]) Tranylcypromine (Parnate)
Second-Generation | Selective Serotonin Re-Uptake Inhibitors (SSRIs)^*^ | Citalopram (Celexa) Escitalopram (Lexapro) Fluoxetine (Prozac) Fluvoxamine Paroxetine^*^ (Paxil, Pexeva) Sertraline^*^ (Zoloft)
Second-Generation | Selective Serotonin/Norepinephrine Re-uptake Inhibitors (SNRIs) | Desvenlafaxine (Pristiq) Duloxetine (Cymbalta) Venlafaxine (Effexor)
Second-Generation | Dopamine Re-Uptake Inhibitors (DRIs) | Bupropion (Wellbutrin)
Second-Generation | 5-HT_2A_ Receptor Antagonists | Nefazodone
Second-Generation | Serotonin Re-Uptake Inhibitors (SRIs) | Trazadone
Second-Generation | Tetracyclic Antidepressants (TeCAs) | Mirtazapine

* SSRIs are the first-choice medicine for treating postpartum depression; sertraline and paroxetine are recommended for breast-feeding women.

Recent efforts to improve depression outcomes in primary care settings often include collaborative care interventions. These interventions apply a chronic disease care model to depression and utilize care or case managers to support the primary care clinician, facilitate patients' treatment engagement, and monitor symptoms. Care managers may provide patient education; arrange appointments with specialty providers; monitor treatment adherence, depressive symptoms, and adverse effects; notify providers when patients fail to improve or experience side effects; and provide supportive or psychotherapeutic counseling in some cases. Collaborative care interventions have been recommended by the Community Preventive Services Task Force.83

Complementary and alternative therapies include yoga, exercise, and dietary supplements such as St. John's wort, and some interventions are appropriate second-line treatments for severe depression when first-line treatments are not effective, such as polypharmacy, transcranial stimulation, and electroconvulsive therapy.

## Current U.S. Initiatives and Recommendations of Other Organizations

The Healthy People 2020 initiative84 has published 12 objectives related to mental health and mental disorders, including major depression, as listed below:

- MHMD-4: Reduce the proportion of persons who experience major depression episodes
- MHMD-10: Increase depression screening by primary care providers

The recommendations for depression screening in clinical practice from other health organizations are listed in Table 4.

Table 4 Recommendations of Other Organizations for Depression Screening in Adults

Organization, Year | Recommendation
American Academy of Family Physicians (AAFP), 2012 | The AAFP recommends screening adults for depression when staff-assisted depression care supports are in place to assure accurate diagnosis, effective treatment, and follow-up.262 The AAFP recommends against routinely screening adults for depression when staff-assisted depression care supports are not in place.262 These recommendations are based on the 2009 USPSTF recommendation.
American Academy of Pediatrics (AAP), 2010 | The AAP recommends that pediatricians screen mothers for postpartum depression at baby's one-, two- and four-month visits.263
American College of Physicians (ACP), 2009 | The ACP recommends that primary care providers should screen all adults for depression and that all primary care providers should have systems in place, either within the primary care setting itself or through collaborations with mental health professionals, to ensure the accurate diagnosis and treatment of this condition.264 The ACP supports the 2009 USPSTF recommendation.
American Congress of Obstetricians and Gynecologists (ACOG), 2010 | There is insufficient evidence to support a firm recommendation for universal antepartum or postpartum screening, screening for depression has the potential to benefit a woman and her family and should be strongly considered.265
Canadian Task Force on Preventive Health Care (CTFPHC), 2013 | The CTFPHC does not recommend routinely screening for depression in adults at average risk of depression or in adults in subgroups of the population who may be at an increased risk of depression.248
Institute for Clinical Systems Improvement, 2013 | Clinician should use a standardized instrument to screen for depression if it is suspected based on risk factors or presentation. Clinicians should use DSM-5 criteria to determine a diagnosis of major depression, persistent depressive disorder, and unspecified depressive disorder. Clinicians should assess and treat for depression in patients with some comorbidities. Clinicians should acknowledge the impact of culture and cultural differences on physician and mental health. When using pharmacotherapy in elderly patients, the clinician should carefully consider how the metabolism of the drug may be affected by physiologic changes, their comorbid illnesses and the medications used for them. Clinicians should screen and monitor depression in pregnant and post-partum women. A collaborative care approach is recommended for patients with depression in primary care. A written and mutually agreed-upon treatment plan engaging the patient and family is recommended. Clinicians should provide antidepressant medications and/or referral for psychotherapy as treatment for major depression. Clinicians should establish and maintain follow-up with patients.266
National Institute for Health and Care Excellence (NICE), 2013^247^ | The NICE recommends the first step in depression management is recognition, assessment and initial management. Case identification and recognition: Be alert to possible depression (particularly in people with a past history of depression or a chronic physical health problem with associated functional impairment) and consider asking people who may have depression two questions, specifically:; - During the last month, have you often been bothered by feeling down, depressed or hopeless?; - During the last month, have you often been bothered by having little interest or pleasure in doing things?; If a person answers ‘yes’ to either of the depression identification questions but the practitioner is not competent to perform a mental health assessment, they should refer the person to an appropriate professional. If this professional is not the person's GP, inform the GP of the referral. If a person answers ‘yes’ to either of the depression identification questions, a practitioner who is competent to perform a mental health assessment should review the person's mental state and associated functional, interpersonal and social difficulties. When assessing a person with suspected depression, consider using a validated measure (for example, for symptoms, functions and/or disability) to inform and evaluate treatment. For people with significant language or communication difficulties, for example people with sensory impairments or a learning disability, consider using the Distress Thermometer and/or asking a family member or carer about the person's symptoms to identify possible depression. If a significant level of distress is identified, investigate further.
Community Preventive Services Task Force (CPSTF), 2009 | The CPSTF recommends collaborative care for the management of depressive disorders based on strong evidence of effectiveness in improving depression symptoms, adherence to treatment, response to treatment, and remission and recovery from depression. This collaboration is designed to improve the routine screening and diagnosis of depressive disorders, as well as the management of diagnosed depression.267

Abbreviations: DSM = Diagnostic and Statistical Manual; USPSTF = U.S. Preventive Services Task Force.

In addition, some states have passed legislation to mandate screening in women who are pregnant (West Virginia), postpartum (New Jersey), or both (Illinois). Other states have passed legislation to guarantee reimbursement for screening, initiate programs to train providers, or raise awareness about depression in pregnant and postpartum women.85

## Previous USPSTF Recommendation

In 2009, the USPSTF concluded that there is at least moderate certainty that the net benefit of screening for depression is at least moderate for adults who receive care in clinical practices that have staff-assisted depression care supports in place. The USPTSF recommended screening adults for depression when staff-assisted depression care supports are in place to assure accurate diagnosis, effective treatment, and followup (B recommendation).86 The USPSTF also concluded that there is at least moderate certainty that the net benefit of screening adults for depression is small for adults who receive care in clinical practices without staff-assisted depression care support in place. The USPSTF recommended against routinely screening adults for depression when staff-assisted depression care supports are not in place; there may be considerations that support screening for depression in the individual patient (C recommendation).86 This recommendation was based on a combination of results from the 2002 USPSTF review87 and a targeted update published in 2009.^80^