# Ongoing Studies

Relevant Key Question | Study Country | Aim | Participants (number of participants) | Intervention | Comparator | Relevant Outcomes | Status
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Integrated Maternal Psychosocial Assessment to Care Trial (IMPACT)290 Canada | Evaluate an integrated process of online psychosocial assessment, referral, and CBT for pregnant women | Pregnant women aged ≥16 years (n=54) | Integrated process of online psychosocial assessment, referral, and CBT | Usual prenatal care (no formal screening or specialized care) | Self-reported prenatal depression | Estimated completion date, February 2015
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | PRegnancy Outcomes after a Maternity Intervention for Stressful EmotionS (PROMISES)291 Netherlands | Assess the effects of CBT in pregnant women with anxiety or depression symptoms | Pregnant women with at least moderate levels of anxiety or depression at the end of their first trimester (n=300) | CBT, 10-14 individual sessions during pregnancy and after delivery | Usual care | Depressive symptoms (EPDS) | Results to be published in 2015
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Dennis, 2012^292^ Canada | Evaluate the effect of telephone-based IPT in the treatment of postpartum depression | Postpartum women self-identified as depressed or referred by health professional based on EPDS score >12 (n=240) | Telephone-based IPT, 12 weekly 50-60 minute sessions | Usual care | Depression diagnosis and symptomatology | Completed, only protocol published
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Flanagan, 2011^293^ United States | Evaluate a multi-media, computer-based, skills-training psychotherapy treatment | Mothers experiencing postpartum depression (n=122) | Multi-media, computer-based, skills-training psychotherapy treatment, Mommy Emotion and Psychological Training Experience | Treatment as usual | Depression, quality of life | Published meeting abstract only
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Katz & Joseph, 2009 (DC-HOPE)294,295 United States | Evaluate the effectiveness of brief behavioral treatment of depression in prenatal care settings | Low-income pregnant African-American women (n=373) | CBT, 10 sessions | Usual care | Depression symptoms | Completed, publication with relevant outcomes not yet published
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Kammerer, 2014^296^ United Kingdom | Evaluate the efficacy of an internet-based CBT in women suffering from depression in pregnancy | Pregnant women aged 18-40 years with depressive symptoms (EPDS score 12-22) (n=120) | Online CBT, 10 40-minute sessions beginning during pregnancy and continuing after delivery | Usual care | Change in EPDS scores | Estimated completion, January 2016
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Lenze, 2014^297^ United States | Test the feasibility, acceptability, and effectiveness of IPT dyad | Pregnant women aged ≥18 years with an EPDS score ≥13 and depression diagnosis (n=40) | Dyadic IPT | Enhanced usual care | Change in EPDS scores | Estimated completion date, October 2015
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Monk, 2011^298^ United States | Evaluate effectiveness of group IPT for prevention of postpartum depression in depressed pregnant women | Pregnant women aged 18-40 years with an EPDS score ≥10 (n=116) | Group IPT, 12 weekly sessions | Usual care | Postpartum depression | Completed, no relevant publications
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | O'Mahen, 2013 (The Netmums Project)299 United Kingdom | Evaluate an internet-based behavioral activation treatment | Women screened positive for depression (n=1,261) | Postnatal electronic behavioral activation | Treatment as usual | Depression symtpoms, quality of life | Published meeting abstract only
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Postmontier, 2013^300^ United States | Evaluate feasibility, acceptability and safety of nurse midwife counseling telephone-administered interpersonal psychotherapy | Women with postpartum depression (n=100) | Telephone-administered interpersonal psychotherapy, 8 sessions | Wait list / treatment as usual | Depression symtpoms, quality of life | Published meeting abstract only
Depression treatment in pregnant and postpartum women (KQ 4 & 5) | Wisner, 2013^301^ United States | Evaluate the effectiveness of a telephone-based screening and care management program in treating depression in postpartum women | Postpartum women aged ≥18 years with an EPDS score ≥10 (n=628) | Telephone calls from depression care manager encouraging women to seek appropriate depression care | Usual care | Depressive symptoms | Completed, no relevant publications
Screening for depression in general and/or older adults (KQ 1 & 2) | Sadavoy, 2007^302^ Canada | Evaluate the acceptability of a mental health screening program | Chinese older adults aged 55-85 years | Received results of depression screening | Did not receive results of depression screening | Healthcare utilization | Unknown
Screening for depression in general and/or older adults (KQ 1 & 2) | Thombs, 2014^233^ Canada | Determine whether USPSTF depression screening guideline is supported by evidence | Adults | Depression screening tool with a defined cut-off score to make decisions regarding further assessment or treatment of depression | NR | Depression symptom outcomes | Published

Abbreviations: CBT = cognitive behavioral therapy; EPDS = Edinburgh Postnatal Depression Scale; IPT = interpersonal therapy.