# Screening Accuracy of the PHQ and GDS

We identified limited evidence within our body of included studies that utilized either the PHQ72 or GDS164,166,167 for depression screening; none of which assessed the accuracy of these instruments in comparison to reference standard diagnostic interviews.

The PHQ-9, as well as the briefer PHQ-2 and PHQ-8 versions, are commonly used and easy to administer.233 The PHQ-9 is a nine-item, three-page, self-administered version of the PRIME-MD, which has been previously validated.285 The exclusive focus of the PHQ-9 is on the nine diagnostic criteria for DSM-IV depressive disorders, thus it does not capture symptoms like loneliness and anxiety. The PHQ-9 score ranges from 0 to 27 and cut-points of 5, 10, 15, and 20 represent the thresholds for mild, moderate, moderately severe, and severe depression, respectively.286

A previous meta-analysis of the PHQ-9 by Manea and colleauges included 18 validation studies, including 7,180 participants, conducted in a range of clinical settings.232 The majority of included studies used the English version PHQ (k=10), and included studies were required to use a standardized diagnostic interview to make a diagnosis and have a sample size ≥ 250. There was significant between-study heterogeneity, for which the only predictive source was the reported blind application of a diagnostic gold standard. The authors concluded that the PHQ-9 had acceptable diagnostic properties for detecting major depressive disorder for cut-off scores between 8 and 11, with a pooled specificity from 0.83 (95% CI, 0.69 to 0.92) for a cut-off score of 8, to 0.89 (95% CI, 0.79 to 0.94) for a cut-off score of 11. Corresponding pooled sensitivity estimates ranged from 0.82 (95% CI, 0.66 to 0.92) for a cut-off score of 8, to 0.89 (95% CI, 0.75 to 0.96) for a cut-off score of 11. There were no significant differences in the diagnostic properties of the PHQ-9 for cut-off scores between 8 and 11. A cut-off score of 11 appeared to have the optimal trade-off between sensitivity and specificity, however the authors acknowledged this may vary according to clinical setting. The diagnostic OR was lower in hospital settings (diagnostic OR, 25.43 [95% CI, 11.35 to 57.00]) than in primary care settings (diagnostic OR, 65.26 [95% CI, 9.17 to 464.47]).

A more recent review of the PHQ questionnaires is underway by Thombs and colleagues,233 using an individual patient data (IPD) meta-analysis approach. Although not yet complete, a manuscript describing the methods for this review included a criticism of the meta-analysis conducted by Manea and colleagues232 described above, suggesting that the results were limited by selective reporting from the included studies. Other stated concerns were related to the inclusion of patients already being treated for depression.233,287 This concern was acknowledged by Manea and colleagues as a limitation to the meta-analysis.232

The GDS was originally developed as a 30-item (GDS-30) self-administered depression screening instrument specifically developed for the elderly, however the authors of the original GDS did not provide threshold cut-offs for depression diagnoses.288 Questions use a simple yes/no format, and are designed to assess the severity of depression in older adults, with recognition that other depression scales used in the general population may not be adequate for older adults. Due to concerns that the length of the GDS may contribute to fatigue or concentration and attention span difficulties, shorter versions have been developed, including the GDS (15, 10, 8, 5, and 4 items). The survey can be self-administered or interviewer-administered, however one study evaluating the influence of administration method on scores from GDS-15 found that when participants self-administered, scores were 0.7 points higher when self-administered, and 23 percent left items unanswered.59

One review of the GDS-15 and GDS-30, published in 2010, included a meta-analysis of 17 studies conducted in primary care settings.234 The principle inclusion criteria were studies that compared the diagnostic validity of the GDS to that of the semi-structured psychiatric interview for diagnosing late-life (aged 55 years or older) depression. Studies evaluating the GDS-15 (k=7) used cut-offs ranging from 3 to 7, resulting in an adjusted sensitivity of 81.3 percent (95% CI, 77.2 to 85.2) and a specificity of 78.4 percent (95% CI, 71.2 to 84.8). Studies evaluating the GDS-30 (k=10) used cut-offs ranging from 7 to 11, resulting in an adjusted sensitivity of 77.4% (95% CI, 66.3 to 86.8) and a specificity of 65.4 percent (95% CI, 44.2 to 83.8). In order to more fully examine the clinical utility of the GDS, the authors also evaluated general practitioners' ability to detect depression without a screening tool. Using data from six studies, the authors' reported a pooled sensitivity of 56.3 percent (95% CI, 40.0 to 72.0) and specificity of 73.6 percent (95% CI, 71.7 to 75.5). The authors concluded that the GDS-30 had modest diagnostic success, modest clinical utility, and limited benefit beyond the GP's unassisted clinical skills. The GDS-15, however, was believed to have adequate diagnostic value with significantly greater accuracy than the GDS-30 and, thus, good clinical utility. Furthermore, use of the GDS-15 by GP's has the potential to increase unassisted case detection by 8 percent.

Another systematic review of the GDS-15 and GDS-30, published in 2006, described the screening accuracy of the GDS, as well as a comparison of the validity indices of the GDS to other commonly used screening instruments.289 The review included 42 studies, including 6,314 participants, conducted in a range of clinical settings. In most studies (76%), the GDS was administered in the English language. All included studies compared GDS screening results with external case criterion, or gold standard, which could be a non-specified clinical psychiatric interview. Interviewers were known to be blinded in 26 out of 42 (62%) of included studies. Among studies using the GDS-30 (k=33), most used a cut-off of 10 or 11 (k=21), and among studies using the GDS-15 (k=21), most used a cut-off of 5 or 6 (k=13). Depression prevalence rates ranged from 6 to 51.5 percent. For the GDS-30, the mean sensitivity was 0.753 (range, 0.340 to 1.000), and the mean specificity was 0.770 (range, 0.629 to 0.964). For the GDS-15, the mean sensitivity was 0.805 (range, 0.600 to 0.940), and the mean specificity was 0.750 (range, 0.570 to 0.870). When compared to the CES-D instrument, the GDS showed similar criterion validity.

More recently, efforts to develop a new 10-item version of the GDS (termed GDS-R) in the Spanish language were reported as successful in retaining the diagnostic performance of the GDS-30, while increasing the sensitivity and predictive values relative to other shortened versions.288 Using an optimal cut-off score of 5, the GDS-R resulted in 100 percent sensitivity (95% CI, 66.2 to 100), and 97.9 percent specificity (95% CI, 93.7 to 99.7). In comparison, other shortened versions of the GDS (GDS-5, GDS-10, GDS-15) report sensitivities ranging from 66.7 to100 percent and specificities from 78.1 to 87.5 percent.