# Benefits of Depression Treatment in General and Older Adults With Screen-Detected Depression

We identified 18 randomized controlled trial or cluster controlled trials, published between 1983 and 2013 which examined the effectiveness of behavioral and/or pharmacologic treatments for depression in adults (k=13) and older adults (k=5) whose depression was identified through screening in primary care settings. Five trials were conducted in the United States,211-215 eleven in Europe,216-225,227 one in Australia, 228 and one in Asia.226 Follow up periods ranged from six weeks226 to 24 months.164,215 All but one study228 reported percentage of female participants, which varied from 53 to 89 percent. Mean age in studies of general adults ranged from 38 to 53 years; for studies of older adults, mean age ranged from 66 to 74 years. Most of the trials excluded participants who were currently receiving treatment or recently treated for depression.

Several different types of behavioral interventions were utilized including traditional psychological approaches (e.g., brief psychotherapy, interpersonal therapy, CBT, problem-solving treatment), provider training and/or patient psychoeducation, as well as one study that investigated a computer-tailored intervention which involved individualized feedback and a work-book for home study. Several studies utilized a stepped care and/or collaborative care treatment approach that typically involved multiple treatment components such as provider training, patient education and self-management of depression, antidepressant medication, care management, and referral for specialized mental health treatment if needed. Interventions were typically offered by mental health providers (psychiatrists, psychologists, therapists, or counselors), physicians, or nurses. Several of the collaborative care studies utilized a care manager to coordinate treatment. The number of sessions varied considerably (range 3 to 16 sessions) across studies. Interventions were primarily conducted in individual format, although a few studies conducted sessions in group format, online, or by telephone. One of the RCTs213 included an antidepressant treatment arm and five of the stepped/collaborative care studies215,218,220,221,225 included antidepressants as a component of treatment.

We found seven trials of collaborative care or other system-level approaches,212,215,220-222,225,229 and five of these showed beneficial results after 6 or more months, including both trials that were limited to older adults.215,225 For example, the PROSPECT study found greater declines in suicidal ideation, earlier treatment response, and higher depression remission rates at 24-month followup.215 These findings are consistent with a recent Community Guide systematic review and meta-analysis of 32 individual studies, which concluded that collaborative care treatments are more beneficial than usual care treatments in terms of multiple depression outcomes, including reduction of depression symptoms, adherence to prescribed treatment, response to treatment, remission or recovery, quality of life or functional status, and satisfaction with treatment.83

Eleven trials tested behavioral interventions in the general or older adult populations,211,213,214,216,217,219,223,227,228,230,231 and results were mixed. Some studies noted that participants with more severe depression symptoms at baseline showed greater treatment effects211,223 and that treatment effects tended to diminish over longer followup periods.220,225 One trial studied the effect of an antidepressant in a screened population, and reported a beneficial effect after 8 months of treatment.213

A systematic evidence review by Arroll and colleagues284 of 14 RCTs investigated the effectiveness of TCA and SSRIs antidepressants in primary care (although not necessarily screened in primary care settings). Important to note, studies with a majority (> 50%) of participants over age 65 were excluded from this review. This review concluded that both TCAs and SSRIs were superior to placebo with relative risks of 1.24 (95% CI, 1.11 to 1.38) and 1.28 (95% CI, 1.15 to 1.43), respectively. Adverse effects were more common with TCAs, although discontinuation rates due to adverse effects were similar for both classes of antidepressant medications.

Overall, the literature supports the effectiveness of both behavioral and pharmacological treatment of depression in adults and older adults who are screened in primary care settings, particularly in the short-term and with patients with more severe depression symptoms at baseline. Stepped care, collaborative care, and more intensive behavioral treatments seem particularly promising.

Appendix E Table 1 Depression Treatment in General and Older Adults With Screen-Detected Depression