# Evidence Tables

Appendix D Table 1 Detailed Intervention Characteristics of Included Studies for KQs 1 and 3 (Pregnant and Postpartum Women)

Appendix D Table 2 Results From Included Studies for KQ 1 (Pregnant and Postpartum Women): Depression

Appendix D Table 3 Results From Included Studies for KQ 1 (Pregnant and Postpartum Women): Maternal Outcomes

Appendix D Table 4 Results From Included Studies for KQ 1 (Pregnant and Postpartum Women): Child and Infant Outcomes

Appendix D Table 5 Results From Included Studies for KQ 1 (Pregnant and Postpartum Women): Quality of Life

Appendix D Table 6 Results From Included Studies for KQ 1 (Pregnant and Postpartum Women): Health Care Use

Appendix D Table 7 Index Tests and Reference Standards of Included Studies for KQ 2 (Pregnant and Postpartum Women)

Appendix D Table 8 Results of Included Studies for KQ 2 (Pregnant and Postpartum Women): Study-Reported Diagnostic Accuracy Fields

Appendix D Table 9 Detailed Intervention Characteristics for KQ 4 (Pregnant and Postpartum Women)

Appendix D Table 10 Results From Included Studies for KQ 4 (Pregnant and Postpartum Women): Depression

Appendix D Table 11 Results From Included Studies for KQ 4 (Pregnant and Postpartum Women): Child and Infant Outcomes

Appendix D Table 12 Results From Included Studies for KQ 4 (Pregnant and Postpartum Women): Quality of Life and Functioning

Appendix D Table 13 Results From Included Studies for KQ 4 (Pregnant and Postpartum Women): Health Care Use

Appendix D Table 14 Inclusion Criteria and Data Source Descriptions for KQ 5 (Pregnant Women)

Appendix D Table 15 Results From Included Studies for KQ 5 (Pregnant Women): Harms

Appendix D Table 16 Detailed Intervention Characteristics for KQ 1 (General and Older Adults)

Appendix D Table 17 Results From Included Studies for KQ 1 (General and Older Adults): Depression

Appendix D Table 18 Results From Included Studies for KQ 1 (General and Older Adults): Quality of Life and Functioning

Appendix D Table 19 Results From Included Studies for KQ 1 (General and Older Adults): Process Outcomes

Appendix D Figure 1 Forest Plot of Depression Prevalance and Remission/Response in Pregnant and Postpartum Women at All Available Followups (KQ 1)

Abbreviations: CBT = cognitive behavioral therapy; CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; IG = intervention group; RR = relative risk.

This figure is a forest plot of depression prevalence and remission/response in pregnant and postpartum women.

Appendix D Figure 2 Sensitivity of the EPDS for Identifying Major Depressive Disorder in KQ 2, by Cutoff (Pregnant and Postpartum Women)

Data are extrapolated from partial verification.

Abbreviation: CI = confidence interval.

This figure plots the sensitivity the Edinburgh Postnatal Depression Scale (EPDS) by various cut-offs when screening pregnant and postpartum women for major depressive disorder.

Appendix D Figure 3 Specificity of the EPDS for Identifying Major Depressive Disorder in KQ 2, by Cutoff (Pregnant and Postpartum Women)

* Data are extrapolated from partial verification.

Abbreviation: CI = confidence interval.

This figure plots the specificity the Edinburgh Postnatal Depression Scale (EPDS) by various cut-offs when screening pregnant and postpartum women for major depressive disorder.

Appendix D Figure 4 Sensitivity of the EPDS for Identifying Depressive Disorder in KQ 2, by Cutoff (Pregnant and Postpartum Women)

Abbreviation: CI = confidence interval

This figure plots the sensitivity the Edinburgh Postnatal Depression Scale (EPDS) by various cut-offs when screening pregnant and postpartum women for minor or major depressive disorders.

Appendix D Figure 5 Specificity of the EPDS for Identifying Depressive Disorder in KQ 2, by Cutoff (Pregnant and Postpartum Women)

Abbreviation: CI = confidence interval

This figure plots the specificity the Edinburgh Postnatal Depression Scale (EPDS) by various cut-offs when screening pregnant and postpartum women for minor or major depressive disorders.