# Excluded Studies

Reason for Exclusion
E1. Study relevance; a. Not a trial of depression screening, treatment, or a study of instrument accuracy; b. Other
E2. Setting (e.g., schools or classroom-based; inpatient; institutional/residential; workplace; churches; military; other closed social networks or institutional); a. Non-HDI country
E3. Comparative effectiveness
E4. KQ2: Screening instrument (or section of instrument) does not target depression specifically; a. Did not use the PHQ or EPDS
E5. No relevant outcomes
E6. Population; a. Limited to those with chronic psychotic disorder (e.g., schizophrenia); mental health condition other than depression, substance abuse, PTSD, bipolar, borderline personality disorder; medical condition; b. No data specific to the population of interest; c. For KQ4p: non-depressed population; d. For KQ4p: no population-based screening for recruitment
E7. Intervention; a. Not one of the specified interventions; b. Not primary care feasible or referable; c. Not a screening study; d. Only intervention group was screened
E8. Study design; For KQ2, includes >2 weeks between screening and reference test, or reference test not applied to full range of screening results, or could not adjust for partial verification
E9. Study quality; a. High or differential attrition; b. Other quality issue; c. Cohort/case-control studies of harms of antidepressants: Fewer than 10 cases among exposed or unexposed (or few than 10 with exposure among cases or controls)
E10. Non-English
E11. Instrument not brief (>15 min self-report instrument to complete in waiting room, >5 min to complete with clinician), or otherwise not feasible for primary-care-based screening
E12. Unable to locate article
E13. SER included in the McDonagh 2014 review
E14. Study included in the McDonagh 2014 review

Abbreviations: EPDS = Edinburgh Postnatal Depression Scale; HDI = human development index; KQ = Key Question; PHQ = Patient Health Questionnaire; PTSD = post-traumatic stress disorder; SER = systematic evidence review

1 Adouard F, Glangeaud-Freudenthal NM, Golse B. Validation of the Edinburgh postnatal depression scale (EPDS) in a sample of women with high-risk pregnancies in France. Arch Womens Ment Health. Jun. 2005;8(2):89-95. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 15883653].
2 Aguado J, Campbell A, Ascaso C, et al. Examining the factor structure and discriminant validity of the 12-item General Health Questionnaire (GHQ-12) among Spanish postpartum women. Assessment. Dec. 2012;19(4):517-25. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21075958].
3 Alexopoulos GS, Reynolds CF III, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. Aug. 2009;166(8):882-90. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 19528195].
4 Almeida OP, Pirkis J, Kerse N, et al. A randomized trial to reduce the prevalence of depression and self-harm behavior in older primary care patients. Ann Fam Med. Jul. 2012;10(4):347-56. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 22778123].
5 Altamura AC, De Gaspari IF, Rovera C, et al. Safety of SSRIs during pregnancy: a controlled study. Hum Psychopharmacol. Jan. 2013;28(1):25-8. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 23166037].
6 Alvarado-Esquivel C, Sifuentes-Alvarez A, Salas-Martinez C. Validation of the edinburgh postpartum depression scale in a population of adult pregnant women in Mexico. J Clin Med Res. Oct. 2014;6(5):374-8. KQ1gE6b, KQ2gE6b, KQ1pE2a, KQ2pE2a, KQ3pE2a, KQ4pE2a, KQ5pE2a. [pmid: 25110542].
7 Alvarado R, Jadresic E, Guajardo V, et al. First validation of a Spanish-translated version of the Edinburgh postnatal depression scale (EPDS) for use in pregnant women. A Chilean study. Arch Womens Ment Health. 2014. Oct. 11. KQ1gE6b, KQ2gE6b, KQ1pE5, KQ3pE5, KQ4pE7c, KQ5pE7c. [pmid: 25300676].
8 Alwan S, Reefhuis J, Rasmussen SA, et al. Use of selective serotonin-reuptake inhibitors in pregnancy and the risk of birth defects. N Engl J Med. Jun. 28. 2007;356(26):2684-92. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17596602].
9 Alwan S, Reefhuis J, Botto LD, et al. Maternal use of bupropion and risk for congenital heart defects. Am J Obstet Gynecol. Jul. 2010;203(1):52-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20417496].
10 Ammerman RT, Putnam FW, Altaye M, et al. Treatment of depressed mothers in home visiting: impact on psychological distress and social functioning. Child Abuse Negl. Aug. 2013;37(8):544-54. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 23623623].
11 Ammerman RT, Putnam FW, Altaye M, et al. A clinical trial of in-home CBT for depressed mothers in home visitation. Behav Ther. Sep. 2013;44(3):359-72. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 23768664].
12 Ammerman RT, Altaye M, Putnam FW, et al. Depression improvement and parenting in low-income mothers in home visiting. Arch Womens Ment Health. 2014. Nov. 5. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 25369906].
13 Ammerman RT, Peugh JL, Teeters AR, et al. Child maltreatment history and response to CBT treatment in depressed mothers participating in home visiting. J Interpers Violence. 2014. Nov. 13. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 25395221].
14 Ammerman RT, Putnam FW, Stevens J, et al. An open trial of in-home CBT for depressed mothers in home visitation. Matern Child Health J. 2011;15(8):1333-41. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE9a, KQ5pE9a. [pmid: 20936338].
15 Andersen JT, Andersen NL, Horwitz H, et al. Exposure to selective serotonin reuptake inhibitors in early pregnancy and the risk of miscarriage. Obstet Gynecol. Oct. 2014;124(4):655-61. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8. [pmid: 25198261].
16 Andrade C. Antidepressant use in pregnancy and risk of autism spectrum disorders: a critical examination of the evidence. J Clin Psychiatry. Sep. 2013;74(9):940-1. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 24107768].
17 Andrade C. Antenatal exposure to selective serotonin reuptake inhibitors and duration of gestation. J Clin Psychiatry. Jul. 2013;74(7):e633-e635. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23945457].
18 Andrade C. The safety of duloxetine during pregnancy and lactation. J Clin Psychiatry. Dec. 2014;75(12):e1423-e1427. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 25551238].
19 Andrade SE, McPhillips H, Loren D, et al. Antidepressant medication use and risk of persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf. Mar. 2009;18(3):246-52. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19148882].
20 Appleby L, Warner R, Whitton A, et al. A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ. Mar. 29. 1997;314(7085):932-6. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c. [pmid: 9099116].
21 Armstrong S, Small R. Screening for postnatal depression: not a simple task. Aust N Z J Public Health. Feb. 2007;31(1):57-61. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 17333610].
22 Ascaso TC, Garcia EL, Navarro P, et al. Prevalence of postpartum depression in Spanish mothers: comparison of estimation by mean of the structured clinical interview for DSM-IV with the Edinburgh Postnatal Depression Scale. Med Clin (Barc). Mar. 15. 2003;120(9):326-9. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10. [pmid: 12646107].
23 Austin MP, Hadzi-Pavlovic D, Priest SR, et al. Depressive and anxiety disorders in the postpartum period: how prevalent are they and can we improve their detection?. Arch Womens Ment Health. Oct. 2010;13(5):395-401. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20232218].
24 Austin MP, Karatas JC, Mishra P, et al. Infant neurodevelopment following in utero exposure to antidepressant medication. Acta Paediatr. Nov. 2013;102(11):1054-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 23927695].
25 Bagedahl-Strindlund M, Monsen BK. Postnatal depression: a hidden illness. Acta Psychiatr Scand. Oct. 1998;98(4):272-5. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 9821447].
26 Baker-Ericzen MJ, Connelly CD, Hazen AL, et al. A collaborative care telemedicine intervention to overcome treatment barriers for Latina women with depression during the perinatal period. Fam Syst Health. Sep. 2012;30(3):224-40. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE5, KQ5pE5. [pmid: 22709321].
27 Bakker MK, De Walle HE, Wilffert B, et al. Fluoxetine and infantile hypertrophic pylorus stenosis: a signal from a birth defects-drug exposure surveillance study. Pharmacoepidemiol Drug Saf. Aug. 2010;19(8):808-13. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20572024].
28 Bakker MK, Kerstjens-Frederikse WS, Buys CH, et al. First-trimester use of paroxetine and congenital heart defects: a population-based case-control study. Birth Defects Res A Clin Mol Teratol. Feb. 2010;88(2):94-100. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19937603].
29 Ban L, Tata LJ, West J, et al. Live and non-live pregnancy outcomes among women with depression and anxiety: a population-based study. PLOS ONE. 2012;7(8):e43462. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22937052].
30 Ban L, Gibson J, West J, et al. Maternal depression, antidepressant prescriptions, and congenital anomaly risk in offspring: a population-based cohort study. BJOG. 2014. Mar. 11. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8. [pmid: 24612301].
31 Barnes J, Senior R, MacPherson K. The utility of volunteer home-visiting support to prevent maternal depression in the first year of life. Child Care Health Dev. Nov. 2009;35(6):807-16. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE8, KQ3pE7c, KQ4pE7a, KQ5pE7a. [pmid: 19719770].
32 Barnett B, Matthey S, Gyaneshwar R. Screening for postnatal depression in women of non-English speaking background. Arch Womens Ment Health. 1999;2(2):67-74. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8.
33 Battle CL, Uebelacker LA, Magee SR. Patient-centered care for antenatal depression. Am J Obstet Gynecol. 2012;207(5):e10-e11. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22917485].
34 Beattie-Clarke P. Validation of two postpartum screening scales in a sample of Saskatchewan First Nations and Metis women. Regina, Canada. University of Regina. 2003. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8.
35 Beck CT, Gable RK. Further validation of the Postpartum Depression Screening Scale. Nurs Res. May. 2001;50(3):155-64. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 11393637].
36 Beck CT, Gable RK. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. Jul. 2001;50(4):242-50. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 11480533].
37 Beeber LS, Holditch-Davis D, Perreira K, et al. Short-term in-home intervention reduces depressive symptoms in Early Head Start Latina mothers of infants and toddlers. Res Nurs Health. Feb. 2010;33(1):60-76. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6b, KQ5pE6b. [pmid: 20043296].
38 Bellantuono C, Bozzi F, Orsolini L, et al. The safety of escitalopram during pregnancy and breastfeeding: a comprehensive review. Hum Psychopharmacol. Nov. 2012;27(6):534-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE13. [pmid: 23044635].
39 Bellantuono C, Marini A, Lucarelli C. Infant health and neurodevelopmental outcomes following prenatal exposure to duloxetine. Clin Drug Investig. Sep. 2013;33(9):685-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23873363].
40 Benvenuti P, Ferrara M, Niccolai C, et al. The Edinburgh Postnatal Depression Scale: validation for an Italian sample. J Affect Disord. May. 1999;53(2):137-41. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 10360408].
41 Berard A, Ramos E, Rey E, et al. First trimester exposure to paroxetine and risk of cardiac malformations in infants: the importance of dosage. Birth Defects Res B Dev Reprod Toxicol. Feb. 2007;80(1):18-27. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17187388].
42 Berard A, Chaabane S, Boukhris T. Antidepressant use in pregnancy and the risk of cardiac defects. N Engl J Med. Sep. 18. 2014;371(12):1167-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 25229934].
43 Berghofer A, Hartwich A, Bauer M, et al. Efficacy of a systematic depression management program in high utilizers of primary care: a randomized trial. BMC Health Serv Res. 2012;12:298. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 22943609].
44 Bergus GR, Hartz AJ, Noyes R Jr., et al. The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. J Rural Health. 2005;21(4):303-9. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 16294652].
45 Berle JO, Aarre TF, Mykletun A, et al. Screening for postnatal depression. Validation of the Norwegian version of the Edinburgh Postnatal Depression Scale, and assessment of risk factors for postnatal depression. J Affect Disord. Sep. 2003;76(1-3):151-6. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE9b, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 12943945].
46 Berle JO, Steen VM, Aamo TO, et al. Breastfeeding during maternal antidepressant treatment with serotonin reuptake inhibitors: infant exposure, clinical symptoms, and cytochrome p450 genotypes. J Clin Psychiatry. Sep. 2004;65(9):1228-34. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15367050].
47 Bijl D, van Marwijk HWJ, Ader HJ, et al. A randomised controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice - primary and secondary outcomes of the West Friesland Study. Diemen. College Voor Zortgverskeringen. 2003. PMID: None. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b.
48 Bijl D, van Marwijk HWJ, Ader HJ, et al. A randomised controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice - design, first results and feasibility of the West Friesland Study. Diemen. College Voor Zortgverskeringen. 2003. PMID: None. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b.
49 Birmingham MC, Chou KJ, Crain EF. Screening for postpartum depression in a pediatric emergency department. Pediatr Emerg Care. Sep. 2011;27(9):795-800. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21878826].
50 Bittner A, Richter J, Muller C, et al. Effects of a group programme on the early intervention of symptoms of stress, anxiety and depression during pregnancy. Geburtshilfe und Frauenheilkunde. 2009;69:162. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
51 Bittner A, Richter J, Junge HJ, et al. Effects of a cognitive-behavioral prevention program for pregnant women on maternal psychopathology, cognitive risk factors and perceived social support. Arch Womens Ment Health. 2011;14:S10-S11. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE9a, KQ2pE9a, KQ3pE9a, KQ4pE9a, KQ5pE9a.
52 Bittner A, Peukert J, Zimmermann C, et al. Early intervention in pregnant women with elevated anxiety and depressive symptoms: efficacy of a cognitive-behavioral group program. J Perinat Neonatal Nurs. Jul. 2014;28(3):185-95. KQ1gE6b, KQ2gE6b, KQ1pE9a, KQ2pE9a, KQ3pE9a, KQ4pE9a, KQ5pE9a. [pmid: 25062520].
53 Bland P. Tackling postnatal depression in primary care. Practitioner. Mar. 2009;253(1716):5. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19418697].
54 Bloch M, Meiboom H, Lorberblatt M, et al. The effect of sertraline add-on to brief dynamic psychotherapy for the treatment of postpartum depression: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Feb. 2012;73(2):235-41. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 22401479].
55 Bobo WV, Wollan P, Lewis G, et al. Depressive symptoms and access to mental health care in women screened for postpartum depression who lose health insurance coverage after delivery: findings from the Translating Research into Practice for Postpartum Depression (TRIPPD) effectiveness study. Mayo Clin Proc. Sep. 2014;89(9):1220-8. KQ1gE6b, KQ2gE6b, KQ2pE5, KQ3pE5, KQ4pE7d, KQ5pE7d. [pmid: 25091871].
56 Bogen DL, Hanusa BH, Moses-Kolko E, et al. Are maternal depression or symptom severity associated with breastfeeding intention or outcomes?. J Clin Psychiatry. Aug. 2010;71(8):1069-78. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20584521].
57 Bosmans J, de Bruijne M, van Hout H, et al. J Gen Intern Med. 2006;21(10):1020-6. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 16836625].
58 Boucher N, Bairam A, Beaulac-Baillargeon L. A new look at the neonate's clinical presentation after in utero exposure to antidepressants in late pregnancy. J Clin Psychopharmacol. Jun. 2008;28(3):334-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18480693].
59 Boyce P, Stubbs J, Todd A. The Edinburgh Postnatal Depression Scale: validation for an Australian sample. Aust N Z J Psychiatry. Sep. 1993;27(3):472-6. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE9b, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 8250792].
60 Boyce P. Is too much caution enough?. Aust N Z J Psychiatry. 2013;47(11):1081-2. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23969626].
61 Bracken MB, Holford TR. Exposure to prescribed drugs in pregnancy and association with congenital malformations. Obstet Gynecol. Sep. 1981;58(3):336-44. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 7266953].
62 Brown RL, Moberg PD, Allen JB, et al. A team approach to systematic behavioral screening and intervention. Am J Manag Care. 2014;20(4):e113-e121. KQ1gE8, KQ2gE8, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 24884956].
63 Budenholzer B. ACP Journal Club. Use of SSRIs during pregnancy was not associated with increased risk for stillbirth or neonatal mortality. Ann Intern Med. Jun. 18. 2013;158(12):JC12. KQ1gE8, KQ2gE8, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23778924].
64 Buist AE, Bilszta JLC, Rusydina ZN, et al. The use of video feedback in women with postnatal depression. Arch Womens Ment Health. 2011;14:S11-S12. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d.
65 Bunevicius A, Kusminskas L, Bunevicius R. Validation of the Lithuanian version of the Edinburgh Postnatal Depression Scale. Medicina (Kaunas, Lithuania). 2009;45(7):544-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19667749].
66 Bunevicius A, Kusminskas L, Pop VJ, et al. Screening for antenatal depression with the Edinburgh Depression Scale. J Psychosom Obstet Gynaecol. Dec. 2009;30(4):238-43. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19845492].
67 Burger H, Bockting CL, Beijers C, et al. Pregnancy Outcomes After a Maternity Intervention for Stressful Emotions (PROMISES): a randomised controlled trial. Adv Neurobiol. 2015;10:443-59. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE5, KQ5pE5. [pmid: 25287553].
68 Burns A, Mahen O, Baxter H, et al. A pilot randomised controlled trial of cognitive behavioural therapy for antenatal depression. BMC Psychiatry. Jan. 22. 2013;13(1):33. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 23339584].
69 Callahan CM, Hendrie HC, Dittus RS, et al. Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. Aug. 1994;42(8):839-46. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 8046193].
70 Campagne DM. Author's response: Antidepressants and anxiolytics in pregnancy: the facts stand. Eur J Obstet Gynecol Reprod Biol. Dec. 2013;171(2):e2-e3. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 24459709].
71 Caramlau I, Barlow J, Sembi S, et al. Mums 4 Mums: structured telephone peer-support for women experiencing postnatal depression. Pilot and exploratory RCT of its clinical and cost effectiveness. Trials. 2011;12:88. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE7a, KQ5pE7a. [pmid: 21439042].
72 Carpiniello B, Pariante CM, Serri F, et al. Validation of the Edinburgh Postnatal Depression Scale in Italy. J Psychosom Obstet Gynaecol. Dec. 1997;18(4):280-5. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 9443138].
73 Carroll AE, Biondich P, Anand V, et al. A randomized controlled trial of screening for maternal depression with a clinical decision support system. J Am Med Inform Assoc. Mar. 2013;20(2):311-6. KQ1gE6b, KQ2gE6b, KQ1pE3, KQ2pE8, KQ3pE3, KQ4pE7d, KQ5pE7d. [pmid: 22744960].
74 Casper RC, Fleisher BE, Lee-Ancajas JC, et al. Follow-up of children of depressed mothers exposed or not exposed to antidepressant drugs during pregnancy. J Pediatr. Apr. 2003;142(4):402-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12712058].
75 Chabrol H, Teissedre F, Saint-Jean M, et al. Prevention and treatment of post-partum depression: a controlled randomized study on women at risk. Psychol Med. Aug. 2002;32(6):1039-47. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE5a, KQ5pE5. [pmid: 12214785].
76 Chad L, Pupco A, Bozzo P, et al. Update on antidepressant use during breastfeeding. Can Fam Physician. Jun. 2013;59(6):633-4. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 23766044].
77 Chambers CD, Johnson KA, Dick LM, et al. Birth outcomes in pregnant women taking fluoxetine. N Engl J Med. Oct. 3. 1996;335(14):1010-5. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 8793924].
78 Chambers CD, Hernandez-Diaz S, Van Marter LJ, et al. Selective serotonin-reuptake inhibitors and risk of persistent pulmonary hypertension of the newborn. N Engl J Med. Feb. 9. 2006;354(6):579-87. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16467545].
79 Chaudron LH, Szilagyi PG, Tang W, et al. Accuracy of depression screening tools for identifying postpartum depression among urban mothers. Pediatrics. Mar. 2010;125(3):e609-e617. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE9a, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20156899].
80 Chen CH, Tseng YF, Chou FH, et al. Effects of support group intervention in postnatally distressed women. A controlled study in Taiwan. J Psychosom Res. Dec. 2000;49(6):395-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE9b, KQ5pE9b. [pmid: 11182431].
81 Chen H, Bautista D, Ch'ng YC, et al. Screening for postnatal depression in Chinese-speaking women using the Hong Kong translated version of the Edinburgh Postnatal Depression Scale. Asia Pac Psychiatry. Jun. 2013;5(2):E64-E72. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 23857814].
82 Cho HJ, Kwon JH, Lee JJ. Antenatal cognitive-behavioral therapy for prevention of postpartum depression: a pilot study. Yonsei Med J. Aug. 30. 2008;49(4):553-62. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5. [pmid: 18729297].
83 Choi SK, Kim JJ, Park YG, et al. The simplified Edinburgh Postnatal Depression Scale (EPDS) for antenatal depression: is it a valid measure for pre-screening?. International Journal of Medical Sciences. 2012;9(1):40-6. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22211088].
84 Chun-Fai-Chan B, Koren G, Fayez I, et al. Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol. Mar. 2005;192(3):932-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15746694].
85 Clark R, Tluczek A, Wenzel A. Psychotherapy for postpartum depression: a preliminary report. Am J Orthopsychiatry. Oct. 2003;73(4):441-54. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 14609406].
86 Clarke PJ. Validation of two postpartum depression screening scales with a sample of First Nations and Metis women. Can J Nurs Res. Mar. 2008;40(1):113-25. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 18459275].
87 Clements CC, Castro VM, Blumenthal SR, et al. Prenatal antidepressant exposure is associated with risk for attention-deficit hyperactivity disorder but not autism spectrum disorder in a large health system. Mol Psychiatry. 2014. Aug. 26. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 25155880].
88 Cohen LS, Viguera AC, Bouffard SM, et al. Venlafaxine in the treatment of postpartum depression. J Clin Psychiatry. Aug. 2001;62(8):592-6. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 11561929].
89 Cole JA, Ephross SA, Cosmatos IS, et al. Paroxetine in the first trimester and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf. Oct. 2007;16(10):1075-85. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17729379].
90 Cole JA, Modell JG, Haight BR, et al. Bupropion in pregnancy and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf. May. 2007;16(5):474-84. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16897811].
91 Colvin L, Slack-Smith L, Stanley FJ, et al. Linking a pharmaceutical claims database with a birth defects registry to investigate birth defect rates of suspected teratogens. Pharmacoepidemiol Drug Saf. Nov. 2010;19(11):1137-50. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20602344].
92 Colvin L, Slack-Smith L, Stanley FJ, et al. Dispensing patterns and pregnancy outcomes for women dispensed selective serotonin reuptake inhibitors in pregnancy. Birth Defects Res A Clin Mol Teratol. Mar. 2011;91(3):142-52. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21381184].
93 Colvin L, Slack-Smith L, Stanley FJ, et al. Early morbidity and mortality following in utero exposure to selective serotonin reuptake inhibitors: a population-based study in Western Australia. CNS Drugs. Jul. 1. 2012;26(7):e1-14. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22712699].
94 Cooper LA, Ghods Dinoso BK, Ford DE, et al. Comparative effectiveness of standard versus patient-centered collaborative care interventions for depression among African Americans in primary care settings: the BRIDGE Study. Health Serv Res. Feb. 2013;48(1):150-74. KQ1gE3, KQ2gE3, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 22716199].
95 Cooper PJ, Murray L, Wilson A, et al. Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression. I. Impact on maternal mood. Br J Psychiatry. May. 2003;182:412-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 12724244].
96 Costei AM, Kozer E, Ho T, et al. Perinatal outcome following third trimester exposure to paroxetine. Arch Pediatr Adolesc Med. Nov. 2002;156(11):1129-32. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12413342].
97 Cox JL, Holden JM, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale. Br J Psychiatry. Jun. 1. 1987;150(6):782-6. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE9b, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 3651732].
98 Cox JL, Murray D, Chapman G. A controlled study of the onset, duration and prevalence of postnatal depression. Br J Psychiatry. Jul. 1993;163:27-31. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 8353695].
99 Cox JL, Chapman G, Murray D, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. Jul. 29. 1996;39(3):185-9. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 8856422].
100 Craig E, Judd F, Hodgins G. Therapeutic group programme for women with postnatal depression in rural Victoria: a pilot study. Australas Psychiatry. Sep. 2005;13(3):291-5. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 16174204].
101 Croen LA, Grether JK, Yoshida CK, et al. Antidepressant use during pregnancy and childhood autism spectrum disorders. Arch Gen Psychiatry. Nov. 2011;68(11):1104-12. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21727247].
102 Crotty F, Sheehan J. Prevalence and detection of postnatal depression in an Irish commmunity sample. Ir J Psychol Med. 2004;21(4):117-21. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE5, KQ3pE8, KQ4pE1, KQ5pE1.
103 Danaher BG, Milgrom J, Seeley JR, et al. MomMoodBooster web-based intervention for postpartum depression: Feasibility trial results. J Med Internt Res. 2013;15(11):149-68. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 24191345].
104 Davidson S, Prokonov D, Taler M, et al. Effect of exposure to selective serotonin reuptake inhibitors in utero on fetal growth: potential role for the IGF-I and HPA axes. Pediatr Res. Feb. 2009;65(2):236-41. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19262294].
105 Davis K, Pearlstein T, Stuart S, et al. Analysis of brief screening tools for the detection of postpartum depression: comparisons of the PRAMS 6-item instrument, PHQ-9, and structured interviews. Archives of Women's Mental Health. Aug. 2013;16(4):271-7. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pe8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23579244].
106 Davis RL, Rubanowice D, McPhillips H, et al. Risks of congenital malformations and perinatal events among infants exposed to antidepressant medications during pregnancy. Pharmacoepidemiol Drug Saf. Oct. 2007;16(10):1086-94. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17729378].
107 De Vera MA, Berard A. Antidepressant use during pregnancy and the risk of pregnancy-induced hypertension. Br J Clin Pharmacol. Aug. 2012;74(2):362-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22435711].
108 de Vries NKS, van der Veere CN, Reijneveld SA, et al. Early neurological outcome of young infants exposed to selective serotonin reuptake inhibitors during pregnancy: Results from the observational SMOK study. PLOS ONE. 2013;8(5). KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 23785389].
109 Dennis CL, Hodnett E, Kenton L, et al. The effect of peer support on the prevention of post-partum depression among high-risk women: a multi-site randomised controlled trial. World Psychiatry. 2009;8:137. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE7b, KQ5pE7b.
110 Diav-Citrin O, Shechtman S, Weinbaum D, et al. Paroxetine and fluoxetine in pregnancy: a prospective, multicentre, controlled, observational study. Br J Clin Pharmacol. Nov. 2008;66(5):695-705. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18754846].
111 Dimidjian S, O'Hara MW. Pharmacotherapy or untreated antenatal depression: a false dichotomy. J Clin Psychiatry. Sep. 2009;70(9):1321-2. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19818255].
112 Dimidjian S, Goodman SH, Felder JN, et al. An open trial of mindfulness-based cognitive therapy for the prevention of perinatal depressive relapse/recurrence. Arch Womens Ment Health. 2014. Oct. 9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 25298253].
113 Djulus J, Koren G, Einarson TR, et al. Exposure to mirtazapine during pregnancy: a prospective, comparative study of birth outcomes. J Clin Psychiatry. Aug. 2006;67(8):1280-4. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16965209].
114 Dodge KA, Goodman WB, Murphy RA, et al. Implementation and randomized controlled trial evaluation of universal postnatal nurse home visiting. Am J Public Health. Feb. 2014;104. Suppl-43. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 24354833].
115 Dowrick C, Buchan I. Twelve month outcome of depression in general practice: does detection or disclosure make a difference?. BMJ. Nov. 11. 1995;311(7015):1274-6. KQ1gE6, KQ2gE6, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 7496238].
116 Dowrick C. Does testing for depression influence diagnosis or management by general practitioners?. Fam Pract. Dec. 1995;12(4):461-5. KQ1gE6, KQ2gE6, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 8826066].
117 Drake E, Howard E, Kinsey E. Online screening and referral for postpartum depression: An exploratory study. Community Ment Health J. 2014;50(3):305-11. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE7d, KQ5pE7d. [pmid: 23283485].
118 Du X, Ruan SP, Zhu JF. Influence of group psychological intervention on anxiety, depression and pregnancy outcomes in primiparous women. World Chinese Journal of Digestology. 2014;22:2069-72. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
119 Dubnov-Raz G, Juurlink DN, Fogelman R, et al. Antenatal use of selective serotonin-reuptake inhibitors and QT interval prolongation in newborns. Pediatrics. Sep. 2008;122(3):e710-e715. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18762507].
120 Dubnov-Raz G, Hemila H, Vurembrand Y, et al. Maternal use of selective serotonin reuptake inhibitors during pregnancy and neonatal bone density. Early Hum Dev. Mar. 2012;88(3):191-4. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21890289].
121 Dugravier R, Tubach F, Saias T, et al. Impact of a manualized multifocal perinatal home-visiting program using psychologists on postnatal depression: the CAPEDP randomized controlled trial. PLOS ONE. 2013;8(8):e72216. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5. [pmid: 23977257].
122 Eberhard-Gran M, Eskild A, Tambs K, et al. The Edinburgh Postnatal Depression Scale: validation in a Norwegian community sample. Nord J Psychiatry. 2001;55(2):113-7. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pe8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 11802908].
123 Einarson A, Bonari L, Voyer-Lavigne S, et al. A multicentre prospective controlled study to determine the safety of trazodone and nefazodone use during pregnancy. Can J Psychiatry. Mar. 2003;48(2):106-10. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12655908].
124 Einarson A, Choi J, Einarson TR, et al. Rates of spontaneous and therapeutic abortions following use of antidepressants in pregnancy: results from a large prospective database. J Obstet Gynaecol Can. May. 2009;31(5):452-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19604427].
125 Einarson A, Choi J, Einarson TR, et al. Incidence of major malformations in infants following antidepressant exposure in pregnancy: results of a large prospective cohort study. Can J Psychiatry. Apr. 2009;54(4):242-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19321030].
126 Einarson A, Choi J, Einarson TR, et al. Adverse effects of antidepressant use in pregnancy: an evaluation of fetal growth and preterm birth. Depress Anxiety. 2010;27(1):35-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19691030].
127 Einarson A, Choi J, Koren G, et al. Outcomes of infants exposed to multiple antidepressants during pregnancy: results of a cohort study. J Popul Ther Clin Pharmacol. 2011;18(2):e390-e396. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22071601].
128 Einarson A, Smart K, Vial T, et al. Rates of major malformations in infants following exposure to duloxetine during pregnancy: a preliminary report. J Clin Psychiatry. Nov. 2012;73(11):1471. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE9c. [pmid: 23218163].
129 Ekeroma AJ, Ikenasio-Thorpe B, Weeks S, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) as a screening tool for postnatal depression in Samoan and Tongan women living in New Zealand. N Z Med J. May. 25. 2012;125(1355):41-9. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22722214].
130 El Marroun H, Jaddoe VW, Hudziak JJ, et al. Maternal use of selective serotonin reuptake inhibitors, fetal growth, and risk of adverse birth outcomes. Arch Gen Psychiatry. Jul. 2012;69(7):706-14. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22393202].
131 El Marroun H, White TJ, van der Knaap NJ, et al. Prenatal exposure to selective serotonin reuptake inhibitors and social responsiveness symptoms of autism: population-based study of young children. Br J Psychiatry. Aug. 2014;205(2):95-102. KQ1gE1, KQ2gE1, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE5. [pmid: 25252317].
132 El Marroun H, White T, Verhulst FC, et al. Maternal use of antidepressant or anxiolytic medication during pregnancy and childhood neurodevelopmental outcomes: a systematic review. Eur Child Adolesc Psychiatry. 2014. May. 27. KQ1gE1, KQ2gE1, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE5. [pmid: 24863148].
133 Eleftheriou G, Butera R, Cotti CF, et al. Neonatal toxicity following maternal citalopram treatment. Fetal Pediatr Pathol. Oct. 2013;32(5):362-6. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 23438790].
134 Elliott SA, Leverton TJ, Sanjack M, et al. Promoting mental health after childbirth: a controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. Sep. 2000;39(Pt 3):223-41. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 11033746].
135 Engelstad HJ, Roghair RD, Calarge CA, et al. Perinatal outcomes of pregnancies complicated by maternal depression with or without selective serotonin reuptake inhibitor therapy. Neonatology. 2014;105(2):149-54. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE8, KQ5pE8. [pmid: 24356332].
136 Ericson A, Kallen B, Wiholm B. Delivery outcome after the use of antidepressants in early pregnancy. Eur J Clin Pharmacol. Sep. 1999;55(7):503-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 10501819].
137 Evins GG, Theofrastous JP, Galvin SL. Postpartum depression: a comparison of screening and routine clinical evaluation. Am J Obstet Gynecol. May. 2000;182(5):1080-2. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 10819833].
138 Felice E, Saliba J, Grech V, et al. Validation of the Maltese version of the Edinburgh Postnatal Depression Scale. Arch Womens Ment Health. Mar. 2006;9(2):75-80. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 16172837].
139 Ferreira E, Carceller AM, Agogue C, et al. Effects of selective serotonin reuptake inhibitors and venlafaxine during pregnancy in term and preterm neonates. Pediatrics. Jan. 2007;119(1):52-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17200271].
140 Figueroa R. Use of antidepressants during pregnancy and risk of attention-deficit/hyperactivity disorder in the offspring. J Dev Behav Pediatr. Oct. 2010;31(8):641-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20613624].
141 Flanagan T, Mosen S, White H, et al. Computerized skills-based psychotherapy for postpartum depression versus treatment as usual. Arch Womens Ment Health. 2011;14:S65-S66. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d.
142 Galbally M, Lewis AJ, Lum J, et al. Serotonin discontinuation syndrome following in utero exposure to antidepressant medication: prospective controlled study. Aust N Z J Psychiatry. Sep. 2009;43(9):846-54. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19670058].
143 Galbally M, Lewis AJ, Buist A. Developmental outcomes of children exposed to antidepressants in pregnancy. Aust N Z J Psychiatry. May. 2011;45(5):393-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21314237].
144 Garcia-Esteve L, Ascaso C, Ojuel J, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Spanish mothers. J Affect Disord. Jun. 2003;75(1):71-6. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 12781353].
145 Genung V. Psychopharmacology column: a review of psychotropic medication lactation risks for infants during breastfeeding. J Child Adolesc Psychiatr Nurs. Aug. 2013;26(3):214-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 23909944].
146 Georgiopoulos AM, Bryan TL, Wollan P, et al. Routine screening for postpartum depression. J Fam Pract. Feb. 2001;50(2):117-22. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 11219558].
147 Gjerdingen D, Crow S, McGovern P, et al. Stepped care treatment of postpartum depression: impact on treatment, health, and work outcomes. J Am Board Fam Med. Sep. 2009;22(5):473-82. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 19734392].
148 Gjerdingen D, Crow S, McGovern P, et al. Postpartum depression screening at well-child visits: validity of a 2-question screen and the PHQ-9. Ann Fam Med. Jan. 2009;7(1):63-70. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19139451].
149 Gjerdingen D, McGovern P, Center B. Problems with a diagnostic depression interview in a postpartum depression trial. J Am Board Fam Med. Mar. 2011;24(2):187-93. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21383219].
150 Glavin K, Smith L, Sorum R, et al. Redesigned community postpartum care to prevent and treat postpartum depression in women--a one-year follow-up study. J Clin Nurs. Nov. 2010;19(21-22):3051-62. KQ1gE6b, KQ2gE6b, KQ2pE1, KQ3pE5, KQ4pE7d, KQ5pE7d. [pmid: 20726926].
151 GlaxoSmithKline. Preliminary report on bupropion in pregnancy and the occurrence of cardiovascular and major congenital malformation. Middlesex. GSK. 2012. http://www.gsk-clinicalstudyregister.com/study/113694_2#rs. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE3.
152 Golzar AAK, Golizadeh Z, Sohrabi A, et al. Effectiveness of cognitive - Behavioral therapy in the treatment of postpartum depression and three dynamic conflicts of dependency, anger and motherhood in postpartum depressed mothers. Iranian Journal of Obstetrics, Gynecology and Infertility. 2013;16:8-17. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
153 Goodman JH, Tyer-Viola L. Detection, treatment, and referral of perinatal depression and anxiety by obstetrical providers. J Womens Health (Larchmt). Mar. 2010;19(3):477-90. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20156110].
154 Goodman JH, Prager J, Goldstein R, et al. Perinatal Dyadic Psychotherapy for postpartum depression: a randomized controlled pilot trial. Arch Womens Ment Health. 2014. Dec. 20. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 25522664].
155 Goodman SH, Broth MR, Hall CM, et al. Treatment of postpartum depression in mothers: Secondary benefits to the infants. Infant Ment Health J. Sep. 1. 2008;29(5):492-513. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE1.
156 Gorman JR, Kao K, Chambers CD. Breastfeeding among women exposed to antidepressants during pregnancy. J Hum Lact. May. 2012;28(2):181-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22344850].
157 Grigoriadis S, VonderPorten EH, Mamisashvili L, et al. Prenatal exposure to antidepressants and persistent pulmonary hypertension of the newborn: systematic review and meta-analysis. BMJ. 2014;348:f6932. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE13. [pmid: 24429387].
158 Grote NK, Swartz HA, Geibel SL, et al. A randomized controlled trial of culturally relevant, brief interpersonal psychotherapy for perinatal depression. Psychiatr Serv. Mar. 2009;60(3):313-21. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 19252043].
159 Grote NK, Swartz HA, Geibel S, et al. Culturally relevant psychotherapy for perinatal depression. Arch Womens Ment Health. 2011;14:S26. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d.
160 Grzeskowiak LE, Gilbert AL, Morrison JL. Neonatal outcomes after late-gestation exposure to selective serotonin reuptake inhibitors. J Clin Psychopharmacol. Oct. 2012;32(5):615-21. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22926594].
161 Grzeskowiak LE, Gilbert AL, Sorensen TI, et al. Prenatal exposure to selective serotonin reuptake inhibitors and childhood overweight at 7 years of age. Ann Epidemiol. Nov. 2013;23(11):681-7. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE5. [pmid: 24113367].
162 Grzeskowiak LE, Morrison JL. Long-term effects of prenatal SSRI exposure on child growth: weighing the evidence. Am J Psychiatry. Nov. 1. 2013;170(11):1364. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 24185243].
163 Guedeney N, Fermanian J. Validation study of the French version of the Edinburgh Postnatal Depression Scale (EPDS): new results about use and psychometric properties. Eur Psychiatry. 1998;13(2):83-9. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 19698604].
164 Gur TL, Kim DR, Epperson CN. Central nervous system effects of prenatal selective serotonin reuptake inhibitors: sensing the signal through the noise. Psychopharmacology. Jun. 2013;227(4):567-82. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE8. [pmid: 23681158].
165 Hale TW, Kendall-Tackett K, Cong Z, et al. Discontinuation syndrome in newborns whose mothers took antidepressants while pregnant or breastfeeding. Breastfeed Med. Dec. 2010;5(6):283-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20807106].
166 Hanley GE, Brain U, Oberlander TF. Infant developmental outcomes following prenatal exposure to antidepressants, and maternal depressed mood and positive affect. Early Hum Dev. Aug. 2013;89(8):519-24. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 23384962].
167 Hantsoo L, Ward-O'Brien D, Czarkowski KA, et al. A randomized, placebo-controlled, double-blind trial of sertraline for postpartum depression. Psychopharmacology. Mar. 2014;231(5):939-48. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 24173623].
168 Harrington RA, Lee LC, Crum RM, et al. Serotonin hypothesis of autism: implications for selective serotonin reuptake inhibitor use during pregnancy. Autism Res. Jun. 2013;6(3):149-68. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE8. [pmid: 23495208].
169 Harrington RA, Lee LC, Crum RM, et al. Prenatal SSRI use and offspring with autism spectrum disorder or developmental delay. Pediatrics. Apr. 14. 2014;133(5):e1241-e1248. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 24733881].
170 Harris B, Huckle P, Thomas R, et al. The use of rating scales to identify post-natal depression. Br J Psychiatry. Jun. 1989;154:813-7. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 2597888].
171 Hayden T, Perantie DC, Nix BD, et al. Treating prepartum depression to improve infant developmental outcomes: a study of diabetes in pregnancy. J Clin Psychol Med Settings. Sep. 2012;19(3):285-92. KQ1gE6b, KQ2gE6b, KQ1pE6a, KQ2pE6a, KQ3pE6a, KQ4pE6a, KQ5pE6a. [pmid: 22526914].
172 Hayes RM, Wu P, Shelton RC, et al. Maternal antidepressant use and adverse outcomes: a cohort study of 228,876 pregnancies. [Erratum appears in Am J Obstet Gynecol. 2013 Apr;208(4):326]. Am J Obstet Gynecol. Jul. 2012;207(1):49. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8. [pmid: 22727349].
173 Heh SS, Fu YY. Effectiveness of informational support in reducing the severity of postnatal depression in Taiwan. J Adv Nurs. Apr. 2003;42(1):30-6. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 12641809].
174 Heikkinen T, Ekblad U, Kero P, et al. Citalopram in pregnancy and lactation. Clin Pharmacol Ther. Aug. 2002;72(2):184-91. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12189365].
175 Hennings JM, Schaaf L, Fulda S. Glucose metabolism and antidepressant medication. Curr Pharm Des. 2012;18(36):5900-19. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE6b. [pmid: 22681169].
176 Hickie IB, Davenport TA, Luscombe GM, et al. Practitioner-supported delivery of internet-based cognitive behaviour therapy: evaluation of the feasibility of conducting a cluster randomised trial. Med J Aust. Jun. 7. 2010;192(11:Suppl). Suppl-5. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 20528705].
177 Ho SM, Heh SS, Jevitt CM, et al. Effectiveness of a discharge education program in reducing the severity of postpartum depression: a randomized controlled evaluation study. Patient Educ Couns. Oct. 2009;77(1):68-71. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 19376677].
178 Holcomb WL Jr., Stone LS, Lustman PJ, et al. Screening for depression in pregnancy: characteristics of the Beck Depression Inventory. Obstet Gynecol. Dec. 1996;88(6):1021-5. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE4a, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 8942846].
179 Holden JM, Sagovsky R, Cox JL. Counselling in a general practice setting: controlled study of health visitor intervention in treatment of postnatal depression. BMJ. Jan. 28. 1989;298(6668):223-6. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 2493868].
180 Holt WJ. The detection of postnatal depression in general practice using the Edinburgh postnatal depression scale. N Z Med J. Feb. 22. 1995;108(994):57-9. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 7885649].
181 Honey KL, Bennett P, Morgan M. A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol. Nov. 2002;41(Pt 4):405-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 12437794].
182 Horowitz JA, Bell M, Trybulski J, et al. Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 2001;33(4):323-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 11775301].
183 Horowitz JA, Murphy CA, Gregory KE, et al. Community-based postpartum depression screening: Results from the CARE study. Psychiatr Serv. 2009;60(11):1432-4. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE9b, KQ5pE9b. [pmid: 19880456].
184 Horowitz JA, Murphy CA, Gregory KE, et al. A community-based screening initiative to identify mothers at risk for postpartum depression. J Obstet Gynecol Neonatal Nurs. Jan. 2011;40(1):52-61. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE9b, KQ5pE9b. [pmid: 21121945].
185 Horowitz JA, Murphy CA, Gregory K, et al. Nurse home visits improve maternal/infant interaction and decrease severity of postpartum depression. J Obstet Gynecol Neonatal Nurs. May. 2013;42(3):287-300. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE9b, KQ5pE9b. [pmid: 23682696].
186 Hoseininasab D, Ahmadianheris S, Taghavi S. The effect of antenatal education on postpartum depression. Int J Gynaecol Obstet. 2009;107:S607-S608. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE2a, KQ2pE2a, KQ3pE2a, KQ4pE2a, KQ5pE2a.
187 Hou YM, Hu PC, Zhang YM, et al. Combined cognitive behavior therapy with systematic family therapy in patients with mild to moderate postpartum depression. Chinese Mental Health Journal. 2012;26:741-7. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
188 Howard L, Chew-Graham CA, Tylee A, et al. The RESPOND trial: A randomized evaluation of antidepressants and support for women with postnatal depression. Arch Womens Ment Health. 2011;14:S30. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE3, KQ2pE3, KQ3pE3, KQ4pE3, KQ5pE3.
189 Howard LM, Flach C, Mehay A, et al. The prevalence of suicidal ideation identified by the Edinburgh Postnatal Depression Scale in postpartum women in primary care: findings from the RESPOND trial. BMC Pregnancy Childbirth. 2011;11:57. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE5, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21812968].
190 Howell EA, Balbierz A, Jason W, et al. Mothers avoiding depression through empowerment intervention trial (made it). J Gen Intern Med. 2011;26:S222-S223. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE6c, KQ2pE6c, KQ3pE6c, KQ4pE6c, KQ5pE5.
191 Howell EA, Balbierz A, Wang J, et al. Reducing postpartum depressive symptoms among black and Latina mothers: a randomized controlled trial. Obstet Gynecol. May. 2012;119(5):942-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 22488220].
192 Howell EA, Bodnar-Deren S, Balbierz A, et al. An intervention to reduce postpartum depressive symptoms: a randomized controlled trial. Arch Womens Ment Health. Feb. 2014;17(1):57-63. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 24019052].
193 Huang H, Coleman S, Bridge JA, et al. A meta-analysis of the relationship between antidepressant use in pregnancy and the risk of preterm birth and low birth weight. Gen Hosp Psychiatry. Jan. 2014;36(1):13-8. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE13. [pmid: 24094568].
194 Hunter SK, Mendoza JH, D'Anna K, et al. Antidepressants may mitigate the effects of prenatal maternal anxiety on infant auditory sensory gating. Am J Psychiatry. Jun. 2012;169(6):616-24. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE5. [pmid: 22581104].
195 Husain N, Rahman A, Husain M, et al. Detecting Depression in Pregnancy: Validation of EPDS in British Pakistani Mothers. J Immigr Minor Health. 2014. Jan. 28. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE7d, KQ5pE7d. [pmid: 24469591].
196 Huybrechts KF, Palmsten K, Avorn J, et al. Antidepressant use in pregnancy and the risk of cardiac defects. N Engl J Med. Jun. 19. 2014;370(25):2397-407. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8. [pmid: 24941178].
197 Ingadottir E, Thome M. Evaluation of a web-based course for community nurses on postpartum emotional distress. Scand J Caring Sci. Mar. 2006;20(1):86-92. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE9b, KQ5pE9b. [pmid: 16489964].
198 Jadresic E, Araya R, Jara C. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Chilean postpartum women. J Psychosom Obstet Gynaecol. Dec. 1995;16(4):187-91. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE9b, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 8748993].
199 Jardri R, Pelta J, Maron M, et al. Predictive validation study of the Edinburgh Postnatal Depression Scale in the first week after delivery and risk analysis for postnatal depression. J Affect Disord. Jul. 2006;93(1-3):169-76. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 16644021].
200 Jarjoura D, Polen A, Baum E, et al. Effectiveness of screening and treatment for depression in ambulatory indigent patients. J Gen Intern Med. 2004;19(1):78-84. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 14748864].
201 Jensen HM, Gron R, Lidegaard O, et al. The effects of maternal depression and use of antidepressants during pregnancy on risk of a child small for gestational age. Psychopharmacology. Jul. 2013;228(2):199-205. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8. [pmid: 23455598].
202 Jensen HM, Gron R, Lidegaard O, et al. Maternal depression, antidepressant use in pregnancy and Apgar scores in infants. Br J Psychiatry. May. 2013;202(5):347-51. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 23429204].
203 Jerant A, Kravitz RL, Fernandez YG, et al. Potential antidepressant overtreatment associated with office use of brief depression symptom measures. J Am Board Fam Med. Sep. 2014;27(5):611-20. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 25201931].
204 Ji S, Long Q, Newport DJ, et al. Validity of depression rating scales during pregnancy and the postpartum period: impact of trimester and parity. J Psychiatr Res. Feb. 2011;45(2):213-9. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE6a, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20542520].
205 Jimenez-Solem E, Andersen JT, Petersen M, et al. Exposure to selective serotonin reuptake inhibitors and the risk of congenital malformations: a nationwide cohort study. BMJ Open. 2012;2(3). KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22710132].
206 Jimenez-Solem E, Andersen JT, Petersen M, et al. SSRI use during pregnancy and risk of stillbirth and neonatal mortality. Am J Psychiatry. Mar. 1. 2013;170(3):299-304. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 23361562].
207 Johnson KC, LaPrairie JL, Brennan PA, et al. Prenatal antipsychotic exposure and neuromotor performance during infancy. Arch Gen Psychiatry. Aug. 2012;69(8):787-94. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 22474072].
208 Jordan AE, Jackson GL, Deardorff D, et al. Serotonin reuptake inhibitor use in pregnancy and the neonatal behavioral syndrome. J Matern Fetal Neonatal Med. Oct. 2008;21(10):745-51. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19012191].
209 Joseph JG, El-Mohandes AA, Kiely M, et al. Reducing psychosocial and behavioral pregnancy risk factors: results of a randomized clinical trial among high-risk pregnant african american women. Am J Public Health. 2009;99:1053-61. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 19372532].
210 Kallen B. Neonate characteristics after maternal use of antidepressants in late pregnancy. Arch Pediatr Adolesc Med. Apr. 2004;158(4):312-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15066868].
211 Kallen B, Olausson PO. Maternal use of selective serotonin re-uptake inhibitors and persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf. Aug. 2008;17(8):801-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18314924].
212 Kallen B. Maternal use of antidepressant drugs and twin deliveries. Eur J Obstet Gynecol Reprod Biol. Oct. 2012;164(2):235. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE5. [pmid: 22770631].
213 Kallen BA, Otterblad OP. Maternal use of selective serotonin re-uptake inhibitors in early pregnancy and infant congenital malformations. Birth Defects Res A Clin Mol Teratol. Apr. 2007;79(4):301-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17216624].
214 Katon W, Russo J, Reed SD, et al. A randomized trial of collaborative depression care in obstetrics and gynecology clinics: socioeconomic disadvantage and treatment response. Am J Psychiatry. Jan. 1. 2015;172(1):32-40. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6b, KQ5pE6b. [pmid: 25157500].
215 Katz KS. Depression treatment for low income African American women in prenatal care: who fails to benefit?. Pediatric Academic Society. 2009. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE5, KQ5pE5.
216 Katz KS, Gantz M, Rodan M, et al. Depression reduction and adherence to treatment in pregnant African American women. Pediatric Academic Society. 2009. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE5, KQ5pE5.
217 Kellner CH, Pasculli RM, Briggs MC. Treatment of depression during pregnancy. J ECT. Sep. 2012;28(3):195-6. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22914631].
218 Kempny A, Swan L, Dimopoulos K. Antidepressant use in pregnancy and the risk of cardiac defects. N Engl J Med. Sep. 18. 2014;371(12):1167. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 25229933].
219 Kenyon S, Jolly K, Hemming K, et al. Effects of additional lay support for pregnant women with social risk factors on antenatal attendance and maternal psychological health: A randomised controlled trial (ELSIPS). Arch Dis Child Fetal Neonatal Ed. 2014;99:A18. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE7c, KQ5pE5.
220 Kersten-Alvarez LE, Hosman CM, Riksen-Walraven JM, et al. Long-term effects of a home-visiting intervention for depressed mothers and their infants. J Child Psychol Psychiatry. Oct. 2010;51(10):1160-70. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE1. [pmid: 20707826].
221 Kieffer EC, Caldwell CH, Welmerink DB, et al. Effect of the healthy MOMs lifestyle intervention on reducing depressive symptoms among pregnant Latinas. [Erratum appears in Am J Community Psychol. 2013 Mar;51(1-2):90]. Am J Community Psychol. Mar. 2013;51(1-2):76-89. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 22638902].
222 Kieler H, Artama M, Engeland A, et al. Selective serotonin reuptake inhibitors during pregnancy and risk of persistent pulmonary hypertension in the newborn: population based cohort study from the five Nordic countries. BMJ. 2012;344:d8012. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22240235].
223 Kitamura T, Shima S, Sugawara M, et al. Temporal variation of validity of self-rating questionnaires: repeated use of the General Health Questionnaire and Zung's Self-rating Depression Scale among women during antenatal and postnatal periods. Acta Psychiatr Scand. Dec. 1994;90(6):446-50. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE4a, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 7892778].
224 Kjaersgaard MI, Parner ET, Vestergaard M, et al. Prenatal antidepressant exposure and risk of spontaneous abortion - a population-based study. PLOS ONE. 2013;8(8):e72095. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8. [pmid: 24015208].
225 Klieger-Grossmann C, Weitzner B, Panchaud A, et al. Pregnancy outcomes following use of escitalopram: a prospective comparative cohort study. J Clin Pharmacol. May. 2012;52(5):766-70. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22075232].
226 Klier CM, Muzik M, Rosenblum KL, et al. Interpersonal psychotherapy adapted for the group setting in the treatment of postpartum depression. J Psychother Pract Res. 2001;10(2):124-31. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 11264336].
227 Klinger G, Frankenthal D, Merlob P, et al. Long-term outcome following selective serotonin reuptake inhibitor induced neonatal abstinence syndrome. J Perinatol. Sep. 2011;31(9):615-20. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21311497].
228 Knickmeyer RC, Meltzer-Brody S, Woolson S, et al. Rate of Chiari I Malformation in Children of Mothers with Depression with and without Prenatal SSRI Exposure. Neuropsychopharmacology. 2014. May. 20. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE9c. [pmid: 24837031].
229 Kordi M, Nasiri S, Gharavi MM, et al. Evaluating the effect of progressive muscle relaxation training with guided imagery on the severity of depressive symptoms in postpartum period. Iranian Journal of Obstetrics, Gynecology and Infertility. 2012;15:17-24. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
230 Koren G, Nordeng H. SSRIs and persistent pulmonary hypertension of the newborn. BMJ. 2012;344:d7642. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 22240234].
231 Koren G, Nordeng H. Antidepressant use during pregnancy: the benefit-risk ratio. Am J Obstet Gynecol. Sep. 2012;207(3):157-63. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 22425404].
232 Koren G, Nordeng HM. Selective serotonin reuptake inhibitors and malformations: case closed?. Semin Fetal Neonatal Med. Feb. 2013;18(1):19-22. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE8. [pmid: 23228547].
233 Kornum JB, Nielsen RB, Pedersen L, et al. Use of selective serotonin-reuptake inhibitors during early pregnancy and risk of congenital malformations: updated analysis. Clin Epidemiol. 2010;2:29-36. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20865100].
234 Kouros N. Warning of risk to foetus for mothers using SSRIs. Monash Bioeth Rev. Sep. 2013;31(2):22-3. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE8. [pmid: 24844071].
235 Kozhimannil KB, Adams AS, Soumerai SB, et al. New Jersey's efforts to improve postpartum depression care did not change treatment patterns for women on medicaid. Health Aff (Millwood). Feb. 2011;30(2):293-301. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21289351].
236 Kozinszky Z, Dudas RB, Devosa I, et al. Can a brief antepartum preventive group intervention help reduce postpartum depressive symptomatology?. Psychother Psychosom. 2012;81(2):98-107. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 22261988].
237 Kulin NA, Pastuszak A, Sage SR, et al. Pregnancy outcome following maternal use of the new selective serotonin reuptake inhibitors: a prospective controlled multicenter study. JAMA. Feb. 25. 1998;279(8):609-10. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 9486756].
238 Kung F, Lee I, Lee CP. Can midwife help in preventing depression in women at six weeks postpartum by early intervention?. Midwives and Women Working Together for the Family of the World. Vienna. International Confederation of Midwives. 2002. PMID: None. KQ1gE12, KQ2gE12, KQ1pE12, KQ2pE12, KQ3pE12, KQ4pE12, KQ5pE12.
239 Kung FYS. Is early intervention effective to reduce postnatal depression?. A randomised controlled study of Chinese women. ICM Conference. Hong Kong. 2014. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE5, KQ2pE1, KQ3pE5, KQ4pE7d, KQ5pE7d.
240 Kwong K, Chung H, Cheal K, et al. Depression care management for Chinese Americans in primary care: a feasibility pilot study. Community Ment Health J. Apr. 2013;49(2):157-65. KQ1gE3, KQ2gE3, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22015960].
241 Lagerberg D, Magnusson M, Sundelin C. New psychosocial methods in child health care: Can we make a difference under routine conditions?. Public Health Yearbook. Jerusalem. Nova Science Publishers. 2011:175-85. PMID: None. KQ1gE12, KQ2gE12, KQ1pE12, KQ2pE12, KQ3pE12, KQ4pE12, KQ5pE12.
242 Laine K, Heikkinen T, Ekblad U, et al. Effects of exposure to selective serotonin reuptake inhibitors during pregnancy on serotonergic symptoms in newborns and cord blood monoamine and prolactin concentrations. Arch Gen Psychiatry. Jul. 2003;60(7):720-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12860776].
243 Lanza di Scalea T, Hanusa BH, Wisner KL. Sexual function in postpartum women treated for depression: results from a randomized trial of nortriptyline versus sertraline. J Clin Psychiatry. Mar. 2009;70(3):423-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19284932].
244 Lara MA, Navarro C, Navarrete L, et al. Retention rates and potential predictors in a longitudinal randomized control trial to prevent postpartum depression. Salud Ment. 2010;33:429-36. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE2a, KQ2pE2a, KQ3pE2a, KQ4pE2a, KQ5pE2a.
245 Latendresse G, Ruiz RJ. Maternal corticotropin-releasing hormone and the use of selective serotonin reuptake inhibitors independently predict the occurrence of preterm birth. J Midwifery Womens Health. Mar. 2011;56(2):118-26. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21429075].
246 Lee DT, Yip AS, Chiu HF, et al. Screening for postnatal depression: are specific instruments mandatory?. J Affect Disord. Mar. 2001;63(1-3):233-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 11246101].
247 Lee DT, Yip AS, Chan SS, et al. Postdelivery screening for postpartum depression. Psychosom Med. May. 2003;65(3):357-61. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 12764207].
248 Lennestal R, Kallen B. Delivery outcome in relation to maternal use of some recently introduced antidepressants. J Clin Psychopharmacol. Dec. 2007;27(6):607-13. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18004128].
249 Leuchter AF, Hunter AM, Tartter M, et al. Role of pill-taking, expectation and therapeutic alliance in the placebo response in clinical trials for major depression. Br J Psychiatry. 2014. Sep. 11. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 25213159].
250 Leung SS, Leung C, Lam TH, et al. Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). Jun. 2011;33(2):292-301. KQ1gE6b, KQ2gE6b, KQ2pE1, KQ4pE7d, KQ5pE7d. [pmid: 20884642].
251 Leveille SG, Huang A, Tsai SB, et al. Health coaching via an internet portal for primary care patients with chronic conditions: a randomized controlled trial. Med Care. Jan. 2009;47(1):41-7. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 19106729].
252 Leverton TJ, Elliott SA. Is the EPDS a magic wand?: 1. A comparison of the Edinburgh Postnatal Depression Scale and health visitor report as predictors of diagnosis on the Present State Examination. J Reprod Infant Psychol. Nov. 1. 2000;18(4):279-96. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1.
253 Levinson-Castiel R, Merlob P, Linder N, et al. Neonatal abstinence syndrome after in utero exposure to selective serotonin reuptake inhibitors in term infants. Arch Pediatr Adolesc Med. Feb. 2006;160(2):173-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16461873].
254 Lewis AJ, Galbally M, Opie G, et al. Neonatal growth outcomes at birth and one month postpartum following in utero exposure to antidepressant medication. Aust N Z J Psychiatry. May. 2010;44(5):482-7. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20397792].
255 Lewis AJ, Bailey C, Galbally M. Antidepressant use during pregnancy in Australia: findings from the Longitudinal Study of Australian Children. Aust N Z J Public Health. Oct. 2012;36(5):487-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE5. [pmid: 23025373].
256 Lim K, Sanders A, Brain U, et al. Third trimester fetal pulmonary artery Doppler blood flow velocity characteristics following prenatal selective serotonin reuptake inhibitor (SSRI) exposure. Early Hum Dev. Aug. 2012;88(8):609-15. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE8, KQ5pE5. [pmid: 22305713].
257 Logsdon MC, Wisner K, Hanusa BH. Does maternal role functioning improve with antidepressant treatment in women with postpartum depression?. J Womens Health (Larchmt). Jan. 2009;18(1):85-90. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19132881].
258 Logsdon MC, Wisner K, Sit D, et al. Depression treatment and maternal functioning. Depress Anxiety. Nov. 2011;28(11):1020-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21898714].
259 Lopez-Yarto M, Ruiz-Mirazo E, Holloway AC, et al. Do psychiatric medications, especially antidepressants, adversely impact maternal metabolic outcomes?. J Affect Disord. Dec. 10. 2012;141(2-3):120-9. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE5, KQ5pE13. [pmid: 22370064].
260 Lorenzo L, Einarson A. Antidepressant use in pregnancy: an evaluation of adverse outcomes excluding malformation. Isr J Psychiatry Relat Sci. 2014;51(2):94-104. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE13. [pmid: 25372558].
261 Louik C, Lin AE, Werler MM, et al. First-trimester use of selective serotonin-reuptake inhibitors and the risk of birth defects. N Engl J Med. Jun. 28. 2007;356(26):2675-83. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17596601].
262 Louik C, Kerr S, Mitchell AA. First-trimester exposure to bupropion and risk of cardiac malformations. Pharmacoepidemiol Drug Saf. Oct. 2014;23(10):1066-75. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE8. [pmid: 24920293].
263 Lund N, Pedersen LH, Henriksen TB. Selective serotonin reuptake inhibitor exposure in utero and pregnancy outcomes. Arch Pediatr Adolesc Med. Oct. 2009;163(10):949-54. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19805715].
264 Lupattelli A, Spigset O, Kore G, et al. Risk of vaginal bleeding and postpartum hemorrhage after use of antidepressants in pregnancy: A study from the Norwegian Mother and Child Cohort Study. J Clin Psychopharmacol. 2014;34(1):143-8. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE8. [pmid: 24135843].
265 Lydsdottir LB, Howard LM, Olafsdottir H, et al. The mental health characteristics of pregnant women with depressive symptoms identified by the Edinburgh Postnatal Depression Scale. J Clin Psychiatry. Apr. 2014;75(4):393-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 24569071].
266 MacArthur C, Winter HR, Bick DE, et al. Effects of redesigned community postnatal care on womens' health 4 months after birth: a cluster randomised controlled trial. Lancet. Feb. 2. 2002;359(9304):378-85. KQ1gE6b, KQ2gE6b, KQ2pE1, KQ3pE5, KQ4pE7d, KQ5pE7d. [pmid: 11844507].
267 Malm H, Artama M, Gissler M, et al. Selective serotonin reuptake inhibitors and risk for major congenital anomalies. Obstet Gynecol. Jul. 2011;118(1):111-20. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21646927].
268 Malm H. Prenatal exposure to selective serotonin reuptake inhibitors and infant outcome. Ther Drug Monit. Dec. 2012;34(6):607-14. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE5, KQ5pE13. [pmid: 23042258].
269 Malm H, Artama M, Brown AS, et al. Inand childhood neurodevelopmental outcomes following prenatal exposure to selective serotonin reuptake inhibitors: overview and design of a Finnish Register-Based Study (FinESSI)fant. BMC Psychiatry. 2012;12:217. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 23206294].
270 Manakova E, Hubickova L. Antidepressant drug exposure during pregnancy. CZTIS small prospective study. Neuro Endocrinol Lett. Suppl 1. 2011;32:53-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22167208].
271 Mann R, Adamson J, Gilbody SM. Diagnostic accuracy of case-finding questions to identify perinatal depression. CMAJ. May. 15. 2012;184(8):E424-E430. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22451686].
272 Mao HJ, Li HJ, Chiu H, et al. Effectiveness of antenatal emotional self-management training program in prevention of postnatal depression in Chinese women. Perspect Psychiatr Care. Oct. 2012;48(4):218-24. KQ1gE2a, KQ2gE2a, KQ1pE2a, KQ2pE2a, KQ3pE2a, KQ4pE2a, KQ5pE2a. [pmid: 23005589].
273 Maschi S, Clavenna A, Campi R, et al. Neonatal outcome following pregnancy exposure to antidepressants: a prospective controlled cohort study. BJOG. Jan. 2008;115(2):283-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17903222].
274 Mauri M, Oppo A, Montagnani MS, et al. Beyond “postpartum depressions”: specific anxiety diagnoses during pregnancy predict different outcomes: results from PND-ReScU. J Affect Disord. Dec. 2010;127(1-3):177-84. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20554326].
275 McDonagh M, Matthews A, Phillipi C, et al. Treatment of depression during pregnancy and the postpartum period. Rockville, MD. Agency for Healthcare Research and Quality. 2013. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1.
276 McElhatton PR, Garbis HM, Elefant E, et al. The outcome of pregnancy in 689 women exposed to therapeutic doses of antidepressants. A collaborative study of the European Network of Teratology Information Services (ENTIS). Reprod Toxicol. Jul. 1996;10(4):285-94. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 8829251].
277 McFarland J, Salisbury AL, Battle CL, et al. Major depressive disorder during pregnancy and emotional attachment to the fetus. Arch Womens Ment Health. Oct. 2011;14(5):425-34. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21938509].
278 McGregor M, Coghlan M, Dennis CL. The effect of physician-based cognitive behavioural therapy among pregnant women with depressive symptomatology: a pilot quasi-experimental trial. Early Interv Psychiatry. Jul. 15. 2013;8(4):348-57. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ5pE5. [pmid: 23855406].
279 Meager I, Milgrom J. Group treatment for postpartum depression: a pilot study. Aust N Z J Psychiatry. Dec. 1996;30(6):852-60. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 9034477].
280 Melville JL, Reed SD, Russo J, et al. Improving care for depression in obstetrics and gynecology: a randomized controlled trial. Obstet Gynecol. Jun. 2014;123(6):1237-46. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE6b, KQ5pE6b. [pmid: 24807320].
281 Menchetti M, Sighinolfi C, Di M V, et al. Effectiveness of collaborative care for depression in Italy. A randomized controlled trial. Gen Hosp Psychiatry. Nov. 2013;35(6):579-86. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23969143].
282 Merlob P, Birk E, Sirota L, et al. Are selective serotonin reuptake inhibitors cardiac teratogens? Echocardiographic screening of newborns with persistent heart murmur. Birth Defects Res A Clin Mol Teratol. Oct. 2009;85(10):837-41. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19691085].
283 Meyers MA, Groh CJ, Binienda J. Depression screening and treatment in uninsured urban patients. J Am Board Fam Med. Jul. 2014;27(4):520-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE3, KQ5pE3. [pmid: 25002006].
284 Michielsen LA, van der Heijden FM, Janssen PK, et al. Effects of maternal psychotropic drug dosage on birth outcomes. Neuropsychiatr Dis Treat. 2014;10:13-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE7a. [pmid: 24376355].
285 Milgrom J, Ericksen J, Negri L, et al. Screening for postnatal depression in routine primary care: properties of the Edinburgh Postnatal Depression Scale in an Australian sample. Aust N Z J Psychiatry. Sep. 2005;39(9):833-9. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 16168042].
286 Milgrom J, Negri LM, Gemmill AW, et al. A randomized controlled trial of psychological interventions for postnatal depression. Br J Clin Psychol. Nov. 2005;44(Pt 4):529-42. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 16368032].
287 Milgrom J, Holt CJ, Gemmill AW, et al. Treating postnatal depressive symptoms in primary care: a randomised controlled trial of GP management, with and without adjunctive counselling. BMC Psychiatry. 2011;11:95. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 21615968].
288 Milgrom J, Schembri C, Ericksen J, et al. Towards parenthood: an antenatal intervention to reduce depression, anxiety and parenting difficulties. J Affect Disord. May. 2011;130(3):385-94. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE3, KQ5pE3. [pmid: 21112641].
289 Milgrom J, Gemmill A. Feasibility and efficacy of an internet treatment for postnatal depression utilising a behavioural activation approach. Evid Based Nurs. Mar. 5. 2014;17(4):102. KQ1gE1, KQ2gE1, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 24598825].
290 Misri S, Sivertz K. Tricyclic drugs in pregnancy and lactation: a preliminary report. Int J Psychiatry Med. 1991;21(2):157-71. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 1894455].
291 Misri S, Reebye P, Corral M, et al. The use of paroxetine and cognitive-behavioral therapy in postpartum depression and anxiety: a randomized controlled trial. J Clin Psychiatry. Sep. 2004;65(9):1236-41. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15367052].
292 Misri S, Reebye P, Kendrick K, et al. Internalizing behaviors in 4-year-old children exposed in utero to psychotropic medications. Am J Psychiatry. Jun. 2006;163(6):1026-32. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16741203].
293 Misri S, Kendrick K, Oberlander TF, et al. Antenatal depression and anxiety affect postpartum parenting stress: a longitudinal, prospective study. Can J Psychiatry. Apr. 2010;55(4):222-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20416145].
294 Misri S, Abizadeh J, Albert G, et al. Restoration of functionality in postpartum depressed mothers: an open-label study with escitalopram. J Clin Psychopharmacol. Oct. 2012;32(5):729-32. KQ1gE1, KQ2gE1, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 22926619].
295 Morrell CJ, Warner R, Slade P, et al. Psychological interventions for postnatal depression: cluster randomised trial and economic evaluation. The PONDER trial. Health Technol Assess. 2009;13(30):1-176. PMID: None. KQ1gE6b, KQ2gE6b, KQ3pE5, KQ4pE6d, KQ5pE6d. [pmid: 19624978].
296 Morrell CJ, Slade P, Warner R, et al. Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ. 2009;338:a3045. KQ1gE6b, KQ2gE6b, KQ3pE5, KQ4pE7d, KQ5pE7d. [pmid: 19147636].
297 Moss SB, Pierce J, Montoya CC, et al. Clinical inquiries. Can counseling prevent or treat postpartum depression?. J Fam Pract. Mar. 2009;58(3):152-4. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19284943].
298 Mulcahy R, Reay RE, Wilkinson RB, et al. A randomised control trial for the effectiveness of group Interpersonal Psychotherapy for postnatal depression. Arch Womens Ment Health. Apr. 2010;13(2):125-39. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 19697094].
299 Mulder EJ, Ververs FF, de HR, et al. Selective serotonin reuptake inhibitors affect neurobehavioral development in the human fetus. Neuropsychopharmacology. Sep. 2011;36(10):1961-71. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21525859].
300 Murray D, Cox JL. Screening for depression during pregnancy with the Edinburgh Depression Scale (EPDS). J Reprod Infant Psychol. 1990;8:99-107. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8.
301 Murray KE, Nyp SS. Postpartum depression. J Dev Behav Pediatr. 2011;32:175. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8.
302 Murray L, Carothers AD. The validation of the Edinburgh Post-natal Depression Scale on a community sample. Br J Psychiatry. Aug. 1990;157:288-90. KQ1gE6b, KQ2gE6b, KQ1pE6b, KQ2pE9b, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 2224383].
303 Murray L, Cooper PJ, Wilson A, et al. Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression: 2. Impact on the mother-child relationship and child outcome. Br J Psychiatry. May. 2003;182:420-7. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 12724245].
304 Muzik M, Klier CM, Rosenblum KL, et al. Are commonly used self-report inventories suitable for screening postpartum depression and anxiety disorders?. Acta Psychiatr Scand. Jul. 2000;102(1):71-3. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 10892613].
305 Nakhai-Pour HR, Broy P, Berard A. Use of antidepressants during pregnancy and the risk of spontaneous abortion. CMAJ. Jul. 13. 2010;182(10):1031-7. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20513781].
306 Navarro P, Ascaso C, Garcia-Esteve L, et al. Postnatal psychiatric morbidity: a validation study of the GHQ-12 and the EPDS as screening tools. Gen Hosp Psychiatry. Jan. 2007;29(1):1-7. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 17189737].
307 Nebhinani N, Soni S. Low Apgar scores in neonates with prenatal antidepressant exposure. Br J Psychiatry. Jun. 2013;202:464. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE5, KQ5pE5. [pmid: 23732937].
308 Newman R. Cognitive behavioural therapy best prevents postpartum depression. BJOG. 2014. May. 19. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 24835783].
309 Nijenhuis CM, ter Horst PG, van RN, et al. Disturbed development of the enteric nervous system after in utero exposure of selective serotonin re-uptake inhibitors and tricyclic antidepressants. Part 2: Testing the hypotheses. Br J Clin Pharmacol. Jan. 2012;73(1):126-34. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21848990].
310 Nordeng H, van Gelder MM, Spigset O, et al. Pregnancy outcome after exposure to antidepressants and the role of maternal depression: results from the Norwegian Mother and Child Cohort Study. J Clin Psychopharmacol. Apr. 2012;32(2):186-94. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22367660].
311 Nordeng H, Havnen GC, Spigset O. Drug use and breastfeeding. Tidsskr Nor Laegeforen. May. 15. 2012;132(9):1089-93. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10. [pmid: 22614307].
312 Nulman I, Rovet J, Stewart DE, et al. Neurodevelopment of children exposed in utero to antidepressant drugs. N Engl J Med. Jan. 23. 1997;336(4):258-62. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 8995088].
313 Nulman I, Rovet J, Stewart DE, et al. Child development following exposure to tricyclic antidepressants or fluoxetine throughout fetal life: a prospective, controlled study. Am J Psychiatry. Nov. 2002;159(11):1889-95. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12411224].
314 Nulman I, Koren G, Rovet J, et al. Neurodevelopment of children following prenatal exposure to venlafaxine, selective serotonin reuptake inhibitors, or untreated maternal depression. Am J Psychiatry. Nov. 1. 2012;169(11):1165-74. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 23128923].
315 O'Hara MW, Stuart S, Gorman LL, et al. Efficacy of interpersonal psychotherapy for postpartum depression. Arch Gen Psychiatry. Nov. 2000;57(11):1039-45. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6b, KQ5pE6b. [pmid: 11074869].
316 O'Mahen H, Wilkinson E, Woodford J, et al. The netmums project: A randomized controlled trial of online behavioural activation for postnatal depression. Arch Womens Ment Health. 2013;16:S64. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5.
317 O'Mahen H, Himle JA, Fedock G, et al. A pilot randomized controlled trial of cognitive behavioral therapy for perinatal depression adapted for women with low incomes. Depress Anxiety. Jul. 2013;30(7):679-87. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 23319454].
318 O'Mahen HA, Richards DA, Woodford J, et al. Netmums: a phase II randomized controlled trial of a guided Internet behavioural activation treatment for postpartum depression. Psychol Med. Oct. 2013;23:1-15. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 24148703].
319 O'Mahen HA, Woodford J, McGinley J, et al. Internet-based behavioral activation--treatment for postnatal depression (Netmums): a randomized controlled trial. J Affect Disord. Sep. 25. 2013;150(3):814-22. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 23602514].
320 Oberlander TF, Eckstein GR, Fitzgerald C, et al. Prolonged prenatal psychotropic medication exposure alters neonatal acute pain response. Pediatr Res. Apr. 2002;51(4):443-53. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 11919328].
321 Oberlander TF, Misri S, Fitzgerald CE, et al. Pharmacologic factors associated with transient neonatal symptoms following prenatal psychotropic medication exposure. J Clin Psychiatry. Feb. 2004;65(2):230-7. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15003078].
322 Oberlander TF, Warburton W, Misri S, et al. Neonatal outcomes after prenatal exposure to selective serotonin reuptake inhibitor antidepressants and maternal depression using population-based linked health data. Arch Gen Psychiatry. Aug. 2006;63(8):898-906. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16894066].
323 Oberlander TF, Reebye P, Misri S, et al. Externalizing and attentional behaviors in children of depressed mothers treated with a selective serotonin reuptake inhibitor antidepressant during pregnancy. Arch Pediatr Adolesc Med. Jan. 2007;161(1):22-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17199063].
324 Oberlander TF, Warburton W, Misri S, et al. Major congenital malformations following prenatal exposure to serotonin reuptake inhibitors and benzodiazepines using population-based health data. Birth Defects Res B Dev Reprod Toxicol. Feb. 2008;83(1):68-76. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18293409].
325 Oberlander TF, Bonaguro RJ, Misri S, et al. Infant serotonin transporter (SLC6A4) promoter genotype is associated with adverse neonatal outcomes after prenatal exposure to serotonin reuptake inhibitor medications. Mol Psychiatry. Jan. 2008;13(1):65-73. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17519929].
326 Oberlander TF, Warburton W, Misri S, et al. Effects of timing and duration of gestational exposure to serotonin reuptake inhibitor antidepressants: population-based study. Br J Psychiatry. May. 2008;192(5):338-43. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18450656].
327 Oberlander TF, Papsdorf M, Brain UM, et al. Prenatal effects of selective serotonin reuptake inhibitor antidepressants, serotonin transporter promoter genotype (SLC6A4), and maternal mood on child behavior at 3 years of age. Arch Pediatr Adolesc Med. May. 2010;164(5):444-51. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20439795].
328 Oberlander TF, Wisner KL. A tale of 2s: optimizing maternal-child health in the context of antenatal maternal depression and antidepressant use. Can J Psychiatry. Sep. 2012;57(9):519-22. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23073028].
329 Occhiogrosso M, Omran SS, Altemus M. Persistent pulmonary hypertension of the newborn and selective serotonin reuptake inhibitors: lessons from clinical and translational studies. Am J Psychiatry. Feb. 2012;169(2):134-40. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE13. [pmid: 22420034].
330 Okun ML, Kiewra K, Luther JF, et al. Sleep disturbances in depressed and nondepressed pregnant women. Depress Anxiety. Aug. 2011;28(8):676-85. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21608086].
331 Okun ML, Luther JF, Wisniewski SR, et al. Disturbed sleep, a novel risk factor for preterm birth?. J Womens Health (Larchmt). Jan. 2012;21(1):54-60. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21967121].
332 Olson AL, Dietrich AJ, Prazar G, et al. Brief maternal depression screening at well-child visits. Pediatrics. Jul. 2006;118(1):207-16. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 16818567].
333 Oosterbaan DB, Verbraak MJ, Terluin B, et al. Collaborative stepped care v. care as usual for common mental disorders: 8-month, cluster randomised controlled trial. Br J Psychiatry. 2013;203(2):132-9. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23787062].
334 Orsolini L, Bellantuono C. Serotonin reuptake inhibitors and breastfeeding: a systematic review. Hum Psychopharmacol. Jan. 2015;30(1):4-20. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE5. [pmid: 25572308].
335 Ortiz Collado MA, Saez M, Favrod J, et al. Antenatal psychosomatic programming to reduce postpartum depression risk and improve childbirth outcomes: a randomized controlled trial in Spain and France. BMC Pregnancy Childbirth. 2014;14:22. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE7a, KQ5pE7a. [pmid: 24422605].
336 Oyama H, Koida J, Sakashita T, et al. Community-based prevention for suicide in elderly by depression screening and follow-up. Community Ment Health J. Jun. 2004;40(3):249-63. KQ1gE7b, KQ2gE7b, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 15259630].
337 Oyama H, Goto M, Fujita M, et al. Preventing elderly suicide through primary care by community-based screening for depression in rural Japan. Crisis. 2006;27(2):58-65. KQ1gE7b, KQ2gE7b, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 16913326].
338 Oyama H, Fujita M, Goto M, et al. Outcomes of community-based screening for depression and suicide prevention among Japanese elders. Gerontologist. Dec. 2006;46(6):821-6. KQ1gE7b, KQ2gE7b, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 17169937].
339 Oyama H, Ono Y, Watanabe N, et al. Local community intervention through depression screening and group activity for elderly suicide prevention. Psychiatry Clin Neurosci. Feb. 2006;60(1):110-4. KQ1gE7b, KQ2gE7b, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 16472368].
340 Oyama H, Sakashita T, Hojo K, et al. A community-based survey and screening for depression in the elderly: the short-term effect on suicide risk in Japan. Crisis. 2010;31(2):100-8. KQ1gE7b, KQ2gE7b, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 20418216].
341 Oyama H, Sakashita T. Effects of universal screening for depression among middle-aged adults in a community with a high suicide rate. J Nerv Ment Dis. Apr. 2014;202(4):280-6. KQ1gE7b, KQ2gE7b, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 24647214].
342 Oyama H, Sakashita T. Differences in specific depressive symptoms among community-dwelling middle-aged Japanese adults before and after a universal screening intervention. Soc Psychiatry Psychiatr Epidemiol. Feb. 2014;49(2):251-8. KQ1gE7b, KQ2gE7b, KQ1pE8, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23824236].
343 Palmsten K, Setoguchi S, Margulis AV, et al. Elevated risk of preeclampsia in pregnant women with depression: depression or antidepressants?. Am J Epidemiol. May. 15. 2012;175(10):988-97. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22442287].
344 Palmsten K, Hernandez-Diaz S, Huybrechts KF, et al. Use of antidepressants near delivery and risk of postpartum hemorrhage: cohort study of low income women in the United States. BMJ. 2013;347:f4877. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE8. [pmid: 23965506].
345 Palmsten K, Huybrechts KF, Mogun H, et al. Harnessing the Medicaid Analytic eXtract (MAX) to evaluate medications in pregnancy: design considerations. PLOS ONE. 2013;8(6):e67405. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE8. [pmid: 23840692].
346 Palmsten K, Huybrechts KF, Michels KB, et al. Antidepressant use and risk for preeclampsia. Epidemiology. Sep. 2013;24(5):682-91. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE8. [pmid: 23873072].
347 Parry BL. To treat or not to treat perinatal depression with antidepressant medication: effects on infant growth. Am J Psychiatry. May. 1. 2013;170(5):453-4. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23511843].
348 Pastuszak A, Schick-Boschetto B, Zuber C, et al. Pregnancy outcome following first-trimester exposure to fluoxetine (Prozac). JAMA. May. 5. 1993;269(17):2246-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 8474204].
349 Pawluski JL, Galea LA, Brain U, et al. Neonatal S100B protein levels after prenatal exposure to selective serotonin reuptake inhibitors. Pediatrics. Oct. 2009;124(4):e662-e670. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19786426].
350 Pawluski JL. Perinatal selective serotonin reuptake inhibitor exposure: impact on brain development and neural plasticity. Neuroendocrinology. 2012;95(1):39-46. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21893935].
351 Payne JL. Use of antidepressants in the second trimester is associated with reduced pregnancy duration, and third trimester antidepressant use with infant convulsions. Evid Based Nurs. Jul. 2013;16(3):74-5. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23171571].
352 Pearlstein TB, Zlotnick C, Battle CL, et al. Patient choice of treatment for postpartum depression: a pilot study. Arch Womens Ment Health. Nov. 2006;9(6):303-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16932988].
353 Pearson KH, Nonacs RM, Viguera AC, et al. Birth outcomes following prenatal exposure to antidepressants. J Clin Psychiatry. Aug. 2007;68(8):1284-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17854255].
354 Pedersen LH, Henriksen TB, Vestergaard M, et al. Selective serotonin reuptake inhibitors in pregnancy and congenital malformations: population based cohort study. BMJ. 2009;339:b3569. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19776103].
355 Pedersen LH, Henriksen TB, Olsen J. Fetal exposure to antidepressants and normal milestone development at 6 and 19 months of age. Pediatrics. Mar. 2010;125(3):e600-e608. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20176667].
356 Pedersen LH, Henriksen TB, Bech BH, et al. Prenatal antidepressant exposure and behavioral problems in early childhood--a cohort study. Acta Psychiatr Scand. Feb. 2013;127(2):126-35. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 23126521].
357 Perez-Blasco J, Viguer P, Rodrigo MF. Effects of a mindfulness-based intervention on psychological distress, well-being, and maternal self-efficacy in breast-feeding mothers: results of a pilot study. Arch Womens Ment Health. Jun. 2013;16(3):227-36. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 23512648].
358 Phillips J, Charles M, Sharpe L, et al. Validation of the subscales of the Edinburgh Postnatal Depression Scale in a sample of women with unsettled infants. J Affect Disord. Nov. 2009;118(1-3):101-12. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE2, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19275960].
359 Polen KN, Rasmussen SA, Riehle-Colarusso T, et al. Association between reported venlafaxine use in early pregnancy and birth defects, national birth defects prevention study, 1997-2007. Birth Defects Res. Jan. 2013;97(1):28-35. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE7c, KQ4pE8. [pmid: 23281074].
360 Posmontier B, Stuart S, Neugebauer R, et al. Multidisciplinary model of nurse midwife administered psychotherapy for postpartum depression. Arch Womens Ment Health. 2013;16:S7. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6b, KQ5pE5.
361 Prendergast J, Austin MP. Early childhood nurse-delivered cognitive behavioural counselling for post-natal depression. Australas Psychiatry. 2001;9(3):255-9. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5.
362 Puckering C, McIntosh E. Mellow Babies: A group intervention for infants and mothers experiencing postnatal depression. Couns Psychol Rev. 2010;25(1):28-38. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE7b, KQ5pE7b.
363 Rai D, Lee BK, Dalman C, et al. Parental depression, maternal antidepressant use during pregnancy, and risk of autism spectrum disorders: population based case-control study. BMJ. 2013;346:f2059. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 23604083].
364 Ramos E, St-Andre M, Rey E, et al. Duration of antidepressant use during pregnancy and risk of major congenital malformations. Br J Psychiatry. May. 2008;192(5):344-50. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18450657].
365 Ramos E, St-Andre M, Berard A. Association between antidepressant use during pregnancy and infants born small for gestational age. Can J Psychiatry. Oct. 2010;55(10):643-52. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20964943].
366 Rampono J, Proud S, Hackett LP, et al. A pilot study of newer antidepressant concentrations in cord and maternal serum and possible effects in the neonate. Int J Neuropsychopharmacol. Sep. 2004;7(3):329-34. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15035694].
367 Rampono J, Simmer K, Ilett KF, et al. Placental transfer of SSRI and SNRI antidepressants and effects on the neonate. Pharmacopsychiatry. May. 2009;42(3):95-100. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19452377].
368 Reay R, Fisher Y, Robertson M, et al. Group interpersonal psychotherapy for postnatal depression: a pilot study. Arch Womens Ment Health. Jan. 2006;9(1):31-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 16222425].
369 Reay R, Matthey S, Ellwood D, et al. Long-term outcomes of participants in a perinatal depression early detection program. J Affect Disord. Mar. 2011;129(1-3):94-103. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE1, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20800898].
370 Reay RE, Owen C, Shadbolt B, et al. Trajectories of long-term outcomes for postnatally depressed mothers treated with group interpersonal psychotherapy. Arch Womens Ment Health. Jun. 2012;15(3):217-28. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE1, KQ3pE3, KQ4pE3, KQ5pE3. [pmid: 22532053].
371 Reebye PN, Morison SJ, Panikkar H, et al. Affect expression in prenatally psychotropic exposed and nonexposed mother/infant dyads. Infant Ment Health J. Jul. 1. 2002;23(4):403-16. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14.
372 Reis M, Kallen B. Delivery outcome after maternal use of antidepressant drugs in pregnancy: an update using Swedish data. Psychol Med. Oct. 2010;40(10):1723-33. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20047705].
373 Riggin L, Frankel Z, Moretti M, et al. The fetal safety of fluoxetine: a systematic review and meta-analysis. [Review] [Erratum appears in J Obstet Gynaecol Can. 2013 Aug;35(8):691]. J Obstet Gynaecol Can. Apr. 2013;35(4):362-9. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE13. [pmid: 23660045].
374 Roman LA, Gardiner JC, Lindsay JK, et al. Alleviating perinatal depressive symptoms and stress: a nurse-community health worker randomized trial. Arch Womens Ment Health. 2009;12:379-91. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 19551471].
375 Romera I, Montejo AL, Aragones E, et al. Systematic depression screening in high-risk patients attending primary care: a pragmatic cluster-randomized trial. BMC Psychiatry. 2013;13:83. KQ1gE8, KQ2gE8, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23497463].
376 Rost K, Nutting PA, Smith J, et al. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. Gen Hosp Psychiatry. 2000;22(2):66-77. KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 10822094].
377 Rost K, Nutting P, Smith J, et al. Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. Mar. 2001;16(3):143-9. KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 11318908].
378 Rost K, Nutting P, Smith JL, et al. Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. Oct. 26. 2002;325(7370):934. KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 12399343].
379 Rowan P, Greisinger A, Brehm B, et al. Outcomes from implementing systematic antepartum depression screening in obstetrics. Arch Womens Ment Health. Apr. 2012;15(2):115-20. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22382279].
380 Rowe HJ, Fisher JR, Loh WM. The Edinburgh Postnatal Depression Scale detects but does not distinguish anxiety disorders from depression in mothers of infants. Arch Womens Ment Health. Jun. 2008;11(2):103-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE2, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 18463939].
381 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 17302651].
382 Sahingoz M, Yuksel G, Karsidag C, et al. Birth weight and preterm birth in babies of pregnant women with major depression in relation to treatment with antidepressants. J Clin Psychopharmacol. Apr. 2014;34(2):226-9. KQ1gE6b, KQ2gE6b, KQ1pE2a, KQ2pE2a, KQ3pE2a, KQ4pE2a, KQ5pE2a. [pmid: 24525643].
383 Sahlen KG, Johansson H, Nyström L, et al. Health coaching to promote healthier lifestyle among older people at moderate risk for cardiovascular diseases, diabetes and depression: a study protocol for a randomized controlled trial in Sweden. BMC Public Health. 2013;13:199. KQ1gE5, KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23497163].
384 Salazar I, Sainz JA, Garcia E, et al. Influence of early postpartum home visits on the detection and clinical course of postpartum depression. Progresos de Obstetricia y Ginecologia. 2011;54:65-70. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
385 Salisbury AL, Wisner KL, Pearlstein T, et al. Newborn neurobehavioral patterns are differentially related to prenatal maternal major depressive disorder and serotonin reuptake inhibitor treatment. Depress Anxiety. Nov. 2011;28(11):1008-19. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21898709].
386 Salkeld E, Ferris LE, Juurlink DN. The risk of postpartum hemorrhage with selective serotonin reuptake inhibitors and other antidepressants. J Clin Psychopharmacol. Apr. 2008;28(2):230-4. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18344737].
387 Santucci AK, Singer LT, Wisniewski SR, et al. Impact of prenatal exposure to serotonin reuptake inhibitors or maternal major depressive disorder on infant developmental outcomes. J Clin Psychiatry. Oct. 2014;75(10):1088-95. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE5. [pmid: 25373117].
388 Schembri A. Beating the Blues before Birth - evaluating an antenatal depression treatment program: a randomised controlled trial. Australian New Zealand Clinical Trials Registry. 2009. www.anzctr.or.au. KQ1gE6b, KQ2gE6b, KQ1pE5, KQ2pE5, KQ3pE5, KQ4pE5, KQ5pE5.
389 Seekles W, van SA, Beekman A, et al. Stepped care treatment for depression and anxiety in primary care. a randomized controlled trial. Trials. 2011;12:171. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 21736720].
390 Segre LS, Brock RL, O'Hara MW. Depression treatment for impoverished mothers by point-of-care providers: a randomized controlled trial. J Consult Clin Psychol. 2014. Dec. 8. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ5pE5. [pmid: 25486371].
391 Shamshiri MH, Azarghashb E, Beyraghi N, et al. The effect of volunteers' telephone-based support on decreasing the postnatal depression. Int J Gynaecol Obstet. 2012;119:S479. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE2a, KQ2pE2a, KQ3pE2a, KQ4pE2a, KQ5pE2a.
392 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Arch Gen Psychiatry. Jul. 2001;58(7):696-703. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 11448378].
393 Shorey S, Chan SW, Chong YS, et al. A randomized controlled trial of the effectiveness of a postnatal psychoeducation programme on self-efficacy, social support and postnatal depression among primiparas. J Adv Nurs. 2014. Dec. 15. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 25496615].
394 Sidebottom AC, Harrison PA, Godecker A, et al. Validation of the Patient Health Questionnaire (PHQ)-9 for prenatal depression screening. Arch Womens Ment Health. Oct. 2012;15(5):367-74. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 22983357].
395 Simon GE, Cunningham ML, Davis RL. Outcomes of prenatal antidepressant exposure. Am J Psychiatry. Dec. 2002;159(12):2055-61. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 12450956].
396 Sinnema H, Franx G, Volker D, et al. Randomised controlled trial of tailored interventions to improve the management of anxiety and depressive disorders in primary care. Implement Sci. 2011;6:75. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 21777463].
397 Sit D, Perel JM, Wisniewski SR, et al. Mother-infant antidepressant concentrations, maternal depression, and perinatal events. J Clin Psychiatry. Jul. 2011;72(7):994-1001. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21824458].
398 Sivojelezova A, Shuhaiber S, Sarkissian L, et al. Citalopram use in pregnancy: prospective comparative evaluation of pregnancy and fetal outcome. Am J Obstet Gynecol. Dec. 2005;193(6):2004-9. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16325604].
399 Skurtveit S, Selmer R, Tverdal A, et al. Drug exposure: inclusion of dispensed drugs before pregnancy may lead to underestimation of risk associations. J Clin Epidemiol. Sep. 2013;66(9):964-72. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE13. [pmid: 23800534].
400 Skurtveit S, Selmer R, Roth C, et al. Prenatal exposure to antidepressants and language competence at age three: results from a large population-based pregnancy cohort in Norway. BJOG. 2014. Apr. 14. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE5. [pmid: 24726047].
401 Smith MV, Gotman N, Lin H, et al. Do the PHQ-8 and the PHQ-2 accurately screen for depressive disorders in a sample of pregnant women?. Gen Hosp Psychiatry. Sep. 2010;32(5):544-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 20851275].
402 Smith MV, Sung A, Shah B, et al. Neurobehavioral assessment of infants born at term and in utero exposure to serotonin reuptake inhibitors. Early Hum Dev. Feb. 2013;89(2):81-6. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE8, KQ5pE9c. [pmid: 22999988].
403 Spinelli M. Antidepressant treatment during pregnancy. Am J Psychiatry. Feb. 2012;169(2):121-4. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE8, KQ5pE8. [pmid: 22318792].
404 Spinelli MG. Interpersonal psychotherapy for depressed antepartum women: a pilot study. Am J Psychiatry. Jul. 1997;154(7):1028-30. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE8. [pmid: 9210760].
405 Spinelli MG, Endicott J. Controlled clinical trial of interpersonal psychotherapy versus parenting education program for depressed pregnant women. Am J Psychiatry. Mar. 2003;160(3):555-62. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE6d. [pmid: 12611838].
406 Spinelli MG, Endicott J, Goetz RR. Increased breastfeeding rates in black women after a treatment intervention. Breastfeed Med. Dec. 2013;8(6):479-84. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5. [pmid: 23971683].
407 Spinelli MG, Endicott J, Leon AC, et al. A controlled clinical treatment trial of interpersonal psychotherapy for depressed pregnant women at 3 New York City sites. J Clin Psychiatry. Apr. 2013;74(4):393-9. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5. [pmid: 23656847].
408 Steiner M. Prenatal exposure to antidepressants: how safe are they?. Am J Psychiatry. Nov. 1. 2012;169(11):1130-2. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23128917].
409 Stephansson O, Kieler H, Haglund B, et al. Selective serotonin reuptake inhibitors during pregnancy and risk of stillbirth and infant mortality. JAMA. Jan. 2. 2013;309(1):48-54. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 23280224].
410 Stewart JC, Perkins AJ, Callahan CM. Effect of collaborative care for depression on risk of cardiovascular events: Data from the IMPACT randomized controlled trial. Psychosom Med. 2014;76:29-37. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 24367124].
411 Stowe ZN, Casarella J, Landry J, et al. Sertraline in the treatment of women with postpartum major depression. Depression. Jan. 1. 1995;3(1-2):49-55. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5.
412 Stuart S, O'Hara MW. Interpersonal psychotherapy for postpartum depression : a treatment program. J Psychother Pract Res. 1995;4(1):18-29. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5. [pmid: 22700210].
413 Subramanian S, Katz KS, Rodan M, et al. An integrated randomized intervention to reduce behavioral and psychosocial risks: pregnancy and neonatal outcomes. Matern Child Health J. Apr. 2012;16(3):545-54. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 21931956].
414 Suri R, Altshuler L, Hendrick V, et al. The impact of depression and fluoxetine treatment on obstetrical outcome. Arch Womens Ment Health. Jul. 2004;7(3):193-200. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 15241665].
415 Suri R, Burt VK, Altshuler LL. Nefazodone for the treatment of postpartum depression. Arch Womens Ment Health. May. 2005;8(1):55-6. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 15868388].
416 Suri R, Altshuler L, Hellemann G, et al. Effects of antenatal depression and antidepressant treatment on gestational age at birth and risk of preterm birth. Am J Psychiatry. Aug. 2007;164(8):1206-13. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17671283].
417 Suri R, Hellemann G, Stowe ZN, et al. A prospective, naturalistic, blinded study of early neurobehavioral outcomes for infants following prenatal antidepressant exposure. J Clin Psychiatry. Jul. 2011;72(7):1002-7. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21672498].
418 Surkan PJ, Gottlieb BR, McCormick MC, et al. Impact of a health promotion intervention on maternal depressive symptoms at 15 months postpartum. Matern Child Health J. Jan. 2012;16(1):139-48. KQ1gE6b, KQ2gE6b, KQ1pE6c, KQ2pE6c, KQ3pE6c, KQ4pE6c, KQ5pE7a. [pmid: 21153759].
419 Swanson L, Arnedt J, Adams J, et al. An open pilot of cognitive behavioral therapy for insomnia in women with postpartum depression. Sleep. 2011;34:A319. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ2pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 23216373].
420 Szanton SL, Thorpe RJ Jr., Gitlin LN. Beat the blues decreases depression in financially strained older african-american adults. Am J Geriatr Psychiatry. Jul. 2014;22(7):692-7. KQ1gE2, KQ2gE2, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23954036].
421 Tancredi DJ, Slee CK, Jerant A, et al. Targeted versus tailored multimedia patient engagement to enhance depression recognition and treatment in primary care: randomized controlled trial protocol for the AMEP2 study. BMC Health Serv Res. 2013;13:141. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 23594572].
422 Tandon SD, Perry DF, Mendelson T, et al. Preventing perinatal depression in low-income home visiting clients: a randomized controlled trial. J Consult Clin Psychol. Oct. 2011;79(5):707-12. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE5. [pmid: 21806298].
423 Tandon SD, Cluxton-Keller F, Leis J, et al. A comparison of three screening tools to identify perinatal depression among low-income African American women. J Affect Disord. Jan. 2012;136(1-2):155-62. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 21864914].
424 Tandon SD, Leis JA, Mendelson T, et al. Six-month outcomes from a randomized controlled trial to prevent perinatal depression in low-income home visiting clients. Matern Child Health J. May. 2014;18(4):873-81. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE5. [pmid: 23793487].
425 Tang YF, Shi SX, Lu W, et al. Prenatal psychological prevention trial on postpartum anxiety and depression. Chin Ment Health J. 2009;23:83-9. PMID: None. KQ1gE10, KQ2gE10, KQ1pE10, KQ2pE10, KQ3pE10, KQ4pE10, KQ5pE10.
426 Teng HW, Hsu CS, Shih SM, et al. Screening postpartum depression with the Taiwanese version of the Edinburgh Postnatal Depression scale. Compr Psychiatry. Jul. 2005;46(4):261-5. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 16175756].
427 Thompson WM, Harris B, Lazarus J, et al. A comparison of the performance of rating scales used in the diagnosis of postnatal depression. Acta Psychiatr Scand. Sep. 1998;98(3):224-7. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE9a, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 9761410].
428 Toh S, Mitchell AA, Louik C, et al. Selective serotonin reuptake inhibitor use and risk of gestational hypertension. Am J Psychiatry. Mar. 2009;166(3):320-8. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19122006].
429 Toh S, Mitchell AA, Louik C, et al. Antidepressant use during pregnancy and the risk of preterm delivery and fetal growth restriction. J Clin Psychopharmacol. Dec. 2009;29(6):555-60. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19910720].
430 Toreki A, Ando B, Kereszturi A, et al. The Edinburgh Postnatal Depression Scale: translation and antepartum validation for a Hungarian sample. Midwifery. Apr. 2013;29(4):308-15. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 22417756].
431 Toreki A, Ando B, Dudas RB, et al. Validation of the Edinburgh Postnatal Depression Scale as a screening tool for postpartum depression in a clinical sample in Hungary. Midwifery. Aug. 2014;30(8):911-8. KQ1gE6b, KQ2gE6b, KQ1pE1, KQ3pE1, KQ4pE1, KQ5pE1. [pmid: 24742635].
432 Toth SL, Rogosch FA, Oshri A, et al. The efficacy of interpersonal psychotherapy for depression among economically disadvantaged mothers. Dev Psychopathol. Nov. 2013;25(4:Pt 1). t-78. KQ1gE6b, KQ2gE6b, KQ1pE6c, KQ2pE6c, KQ3pE6c, KQ4pE3, KQ5pE3. [pmid: 24229549].
433 Trinh NH, Bedoya CA, Chang TE, et al. A study of a culturally focused psychiatric consultation service for Asian American and Latino American primary care patients with depression. BMC Psychiatry. 2011;11:166. KQ1gE7c, KQ2gE7c, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 21995514].
434 Tsivos ZL, Calam R, Sanders MR, et al. A pilot randomised controlled trial to evaluate the feasibility and acceptability of the Baby Triple P Positive Parenting Programme in mothers with postnatal depression. Clin Child Psychol Psychiatry. 2014. Apr. 28. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6d, KQ5pE5. [pmid: 24778436].
435 Tsuji SR, Atallah AN, Aranha FC, et al. Cluster randomized clinical trial (ISRCTN23732000) to evaluate the effectiveness of a diagnosis recognition and treatment guide for depressive disorders in primary care. J Eval Clin Pract. Feb. 2009;15(1):222-5. KQ1gE2a, KQ2gE2a, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 19239608].
436 van der Weele GM, de Waal MW, van den Hout WB, et al. Yield and costs of direct and stepped screening for depressive symptoms in subjects aged 75 years and over in general practice. Int J Geriatr Psychiatry. Mar. 2011;26(3):229-38. KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 20665554].
437 van der Weele GM, de Waal MW, van den Hout WB, et al. Effects of a stepped-care intervention programme among older subjects who screened positive for depressive symptoms in general practice: the PROMODE randomised controlled trial. Age Ageing. Jul. 2012;41(4):482-8. KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 22427507].
438 Van Doesum KT, Riksen-Walraven JM, Hosman CM, et al. A randomized controlled trial of a home-visiting intervention aimed at preventing relationship problems in depressed mothers and their infants. Child Dev. May. 2008;79(3):547-61. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE1, KQ5pE1. [pmid: 18489412].
439 Verkerk GJ, Denollet J, Van Heck GL, et al. Personality factors as determinants of depression in postpartum women: a prospective 1-year follow-up study. Psychosom Med. Jul. 2005;67(4):632-7. KQ1gE6b, KQ2gE6b, KQ1pE7a, KQ2pE7a, KQ3pE7a, KQ4pE7a, KQ5pE7a. [pmid: 16046379].
440 Ververs TF, van WK, Freund MW, et al. Association between antidepressant drug use during pregnancy and child healthcare utilisation. BJOG. Nov. 2009;116(12):1568-77. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19681852].
441 Wan MW, Sharp DJ, Howard LM, et al. Attitudes and adjustment to the parental role in mothers following treatment for postnatal depression. J Affect Disord. Jun. 2011;131(1-3):284-92. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 21349585].
442 Warren JB. Antidepressants and the developing nervous system. Br J Clin Pharmacol. Jan. 2012;73(1):1-3. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 21955357].
443 Webster J, Linnane J, Roberts J, et al. IDentify, Educate and Alert (IDEA) trial: an intervention to reduce postnatal depression. BJOG. Sep. 2003;110(9):842-6. KQ1gE6b, KQ2gE6b, KQ1pE6c, KQ2pE6c, KQ3pE6c, KQ4pE6c, KQ5pE6c. [pmid: 14511967].
444 Weikum WM, Brain U, Chau CM, et al. Prenatal serotonin reuptake inhibitor (SRI) antidepressant exposure and serotonin transporter promoter genotype (SLC6A4) influence executive functions at 6 years of age. Front Cell Neurosci. 2013;7:180. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE8, KQ5pE5. [pmid: 24130516].
445 Wells KB, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: A randomized controlled trial. JAMA. 2000;283(2):212-20. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 10634337].
446 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: Results of a group-level randomized controlled trial. Arch Gen Psychiatry. 2004;61(4):378-86. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 15066896].
447 Wen SW, Yang Q, Garner P, et al. Selective serotonin reuptake inhibitors and adverse pregnancy outcomes. Am J Obstet Gynecol. Apr. 2006;194(4):961-6. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16580283].
448 Whiffen VE. Screening for postpartum depression: a methodological note. J Clin Psychol. May. 1988;44(3):367-71. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE4a, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 3384962].
449 Whooley M, Stone B. Randomized trial of case-finding for depression in elderly primary care patients. J Gen Intern Med. 2000;15(5):293-300. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 10840264].
450 Wichman CL, Moore KM, Lang TR, et al. Congenital heart disease associated with selective serotonin reuptake inhibitor use during pregnancy. Mayo Clin Proc. 2009;84(1):23-7. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19121250].
451 Wickberg B, Hwang CP. Counselling of postnatal depression: A controlled study on a population based Swedish sample. J Affect Disorder. 1996;39:209-16. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 8856425].
452 Wickberg B, Tjus T, Hwang P. Using the EPDS in routine antenatal care in Sweden: a naturalistic study. J Reprod Infant Psychol. Feb. 1. 2005;23(1):33-41. PMID: None. KQ1gE6b, KQ2gE6b, KQ2pE1, KQ3pE5, KQ4pE7d, KQ5pE7d.
453 Wiklund I, Mohlkert P, Edman G. Evaluation of a brief cognitive intervention in patients with signs of postnatal depression: a randomized controlled trial. Acta Obstet Gynecol Scand. Aug. 2010;89(8):1100-4. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ5pE5. [pmid: 20636249].
454 Williams J, Mulrow CD, Kroenke K. Case-finding for depression in primary care: A randomized trial. Am J Med. 1999;106(1):36-43. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 10320115].
455 Wilson KL, Zelig CM, Harvey JP, et al. Persistent pulmonary hypertension of the newborn is associated with mode of delivery and not with maternal use of selective serotonin reuptake inhibitors. Am J Perinatol. Jan. 2011;28(1):19-24. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 20607643].
456 Wisner KL, Hanusa BH, Perel JM, et al. Postpartum depression: a randomized trial of sertraline versus nortriptyline. J Clin Psychopharmacol. Aug. 2006;26(4):353-60. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 16855451].
457 Wisner KL, Sit DK, Hanusa BH, et al. Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. Am J Psychiatry. May. 2009;166(5):557-66. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 19289451].
458 Wisner KL, Sit DK, McShea MC, et al. Onset timing, thoughts of self-harm, and diagnoses in postpartum women with screen-positive depression findings. JAMA Psychiatry. 2013;70:490-8. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23487258].
459 Wisner KL, Bogen DL, Sit D, et al. Does fetal exposure to SSRIs or maternal depression impact infant growth?. [Erratum appears in Am J Psychiatry. 2013 Oct 1;70(10):1218]. Am J Psychiatry. May. 1. 2013;170(5):485-93. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 23511234].
460 Wisner KL, Wisniewski SR, Eckhardt CL, et al. Long-term effects of prenatal SSRI exposure on child growth: Weighing the evidence: Response to editor. Am J Psychiatry. 2013;170(11):1364-5. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 24185244].
461 Wisner KL, Bogen DL, Sit D, et al. “Does fetal exposure to SSRIs or maternal depression impact infant growth?”: Correction. Am J Psychiatry. 2013;170(10):1218. PMID: None. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14.
462 Wogelius P, Norgaard M, Gislum M, et al. Maternal use of selective serotonin reuptake inhibitors and risk of congenital malformations. Epidemiology. Nov. 2006;17(6):701-4. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 17028507].
463 Woolhouse H, Mercuri K, Judd F, et al. Antenatal mindfulness intervention to reduce depression, anxiety and stress: a pilot randomised controlled trial of the MindBabyBody program in an Australian tertiary maternity hospital. BMC Pregnancy Childbirth. Oct. 25. 2014;14(1):369. KQ1gE6b, KQ2gE6b, KQ1pE7c, KQ2pE7c, KQ3pE7c, KQ4pE6c, KQ5pE6c. [pmid: 25343848].
464 Worsley R, Gilbert H, Gavrilidis E, et al. Breastfeeding and psychotropic medications. Lancet. Mar. 16. 2013;381(9870):905. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23499040].
465 Xu S, Rost K, Dong F, et al. Stakeholder benefit from depression disease management: differences by rurality?. J Behav Health Serv Res. 2011;38:114-21. KQ2gE5, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 20052619].
466 Yamashita H, Yoshida K, Nakano H, et al. Postnatal depression in Japanese women. Detecting the early onset of postnatal depression by closely monitoring the postpartum mood. J Affect Disord. May. 2000;58(2):145-54. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ3pE8, KQ4pE1, KQ5pE1. [pmid: 10781704].
467 Yano EM, Chaney EF, Campbell DG, et al. Yield of practice-based depression screening in VA primary care settings. J Gen Intern Med. Mar. 2012;27(3):331-8. KQ1gE8, KQ2gE8, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 21975821].
468 Yawn BP, Dietrich AJ, Wollan P, et al. TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Ann Fam Med. Jul. 2012;10(4):320-9. KQ1gE6b, KQ2gE6b, KQ2pE5, KQ3pE5, KQ4pE7d, KQ5pE7d. [pmid: 22778120].
469 Yazdy MM, Mitchell AA, Louik C, et al. Use of selective serotonin-reuptake inhibitors during pregnancy and the risk of clubfoot. Epidemiology. Nov. 2014;25(6):859-65. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8. [pmid: 25171134].
470 Yeung A, Shyu I, Fisher L, et al. Culturally sensitive collaborative treatment for depressed chinese americans in primary care. Am J Public Health. Dec. 2010;100(12):2397-402. KQ1gE1, KQ2gE1, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 20966373].
471 Yonkers KA, Lin H, Howell HB, et al. Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. J Clin Psychiatry. Apr. 2008;69(4):659-65. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 18363420].
472 Yonkers KA, Smith MV, Lin H, et al. Depression screening of perinatal women: an evaluation of the healthy start depression initiative. Psychiatr Serv. Mar. 2009;60(3):322-8. PMID:. [pii: 60/3/322]. [doi: 10.1176/appi.ps.60.3.322]. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 19252044].
473 Yonkers KA, Norwitz ER, Smith MV, et al. Depression and serotonin reuptake inhibitor treatment as risk factors for preterm birth. Epidemiology. Sep. 2012;23(5):677-85. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 22627901].
474 Yu X, Stewart SM, Wong PT, et al. Screening for depression with the Patient Health Questionnaire-2 (PHQ-2) among the general population in Hong Kong. J Affect Disord. Nov. 2011;134(1-3):444-7. KQ1gE8, KQ2gE8, KQ1pE6b, KQ2pE6b, KQ3pE6b, KQ4pE6b, KQ5pE6b. [pmid: 21665288].
475 Zainul Rashid MR, Das S. Antidepressant medication use patterns during pregnancy and pregnancy outcomes: an insight. Am J Obstet Gynecol. Feb. 2013;208(2):159-60. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 23159746].
476 Zeskind PS, Stephens LE. Maternal selective serotonin reuptake inhibitor use during pregnancy and newborn neurobehavior. Pediatrics. Feb. 2004;113(2):368-75. KQ1gE6b, KQ2gE6b, KQ1pE14, KQ2pE14, KQ3pE14, KQ4pE14, KQ5pE14. [pmid: 14754951].
477 Zlotnick C, Miller IW, Pearlstein T, et al. A preventive intervention for pregnant women on public assistance at risk for postpartum depression. Am J Psychiatry. Aug. 2006;163(8):1443-5. KQ1gE6b, KQ2gE6b, KQ1pE6c, KQ2pE6c, KQ3pE6c, KQ4pE6c, KQ5pE6c. [pmid: 16877662].
478 Zuccotti GV, Fabiano V, Manfredini V. Neonates born to mothers using antidepressant drugs. Early Hum Dev. May. 2012;88(Suppl 2):S84-S85. KQ1gE6b, KQ2gE6b, KQ1pE8, KQ2pE8, KQ3pE8, KQ4pE8, KQ5pE8. [pmid: 22633523].