# Detailed Methods

## Systematic Reviews Literature Search Strategies

### Cochrane Database of Systematic Reviews Issue 10 of 12, October 2013

#1 | [mh ^depression] from 2008 to 2013, in Cochrane Reviews
#2 | [mh ^“depression, postpartum”] from 2008 to 2013, in Cochrane Reviews
#3 | [mh ^“depressive disorder, major”] from 2008 to 2013, in Cochrane Reviews
#4 | [mh ^“dysthymic disorder”] from 2008 to 2013, in Cochrane Reviews
#5 | [mh ^“depressive disorder”] from 2008 to 2013, in Cochrane Reviews
#6 | [mh ^“seasonal affective disorder”] from 2008 to 2013, in Cochrane Reviews
#7 | [mh ^“Depressive Disorder, Treatment-Resistant”] from 2008 to 2013, in Cochrane Reviews
#8 | (depress*.ti or dysthymi*.ti or antidepress*.ti or mood.ti) from 2008 to 2013, in Cochrane Reviews
#9 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 from 2008 to 2013, in Cochrane Reviews

### Database of Abstracts of Reviews of Effects (Via CRD)

((depression or depressed or depressive or mood)):TI OR (dysthimi*):TI OR (antidepress*):TI IN DARE FROM 2008 TO 2013

### Health Technology Assessment

((depression or depressed or depressive or mood)):TI OR (dysthimi*):TI OR (antidepress*):TI IN HTA FROM 2008 TO 2013

### Medline

Database: Ovid MEDLINE(R) without Revisions <1996 to September Week 4 2013>, Ovid MEDLINE(R) Daily Update <October 01, 2013>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 01, 2013>

Search Strategy:

--------------------------------------------------------------------------------

1. Depression/dh, dt, pc, rh, su, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Surgery, Therapy] ()
2. Depression, Postpartum/dh, dt, pc, rh, su, th ()
3. Depressive Disorder, Major/dh, dt, pc, rh, su, th ()
4. Dysthymic Disorder/dh, dt, pc, rh, su, th ()
5. Depressive Disorder/dh, dt, pc, rh, su, th ()
6. Depressive Disorder, Treatment-Resistant/dh, dt, pc, rh, su, th ()
7. Depression/ ()
8. Depression, Postpartum/ ()
9. Depressive Disorder, Major/ ()
10. Dysthymic Disorder/ ()
11. Depressive Disorder/ ()
12. Depressive Disorder, Treatment-Resistant/ ()
13. Mass screening/ ()
14. screen$.ti,ab. ()
15. 13 or 14 ()
16. 7 or 8 or 9 or 10 or 11 or 12 ()
17. 15 and 16 ()
18. 1 or 2 or 3 or 4 or 5 or 6 or 17 ()
19. limit 18 to “all adult (19 plus years)” ()
20. limit 19 to systematic reviews ()
21. limit 20 to (english language and yr=“2008 -Current”) ()
22. depression.ti. ()
23. depressed.ti. ()
24. depressive.ti. ()
25. dysthymi$.ti. ()
26. antidepress$.ti. ()
27. mood.ti. ()
28. 22 or 23 or 24 or 25 or 26 or 27 ()
29. limit 28 to systematic reviews ()
30. limit 29 to (“in data review” or in process or “pubmed not medline”) ()
31. limit 30 to (english language and yr=“2008 -Current”) ()
32. 21 or 31 ()
33. remove duplicates from 32 ()

### PubMed

#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #2 AND publisher[sb] Filters: Publication date from 2008/01/01 to 2013/12/31; English
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND systematic[sb]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search depression[ti] OR depressive[ti] OR depressed[ti] OR antidepress*[ti] OR dysthymi*[ti] OR mood[ti]

### PsycINFO <1806 to October Week 1 2013>

Search Strategy:

--------------------------------------------------------------------------------

1. major depression/ ()
2. dysthymic disorder/ ()
3. Postpartum Depression/ ()
4. Recurrent Depression/ ()
5. Treatment Resistant Depression/ ()
6. “Depression (Emotion)”/ ()
7. 1 or 2 or 3 or 4 or 5 or 6 ()
8. limit 7 to “300 adulthood <age 18 yrs and older>” ()
9. limit 8 to “0830 systematic review” ()
10. limit 8 to 1200 meta analysis ()
11. 9 or 10 ()
12. limit 11 to (english language and yr=“2008 -Current”) ()

## Literature Search Strategies for Primary Literature

### Ovid Medline

#### General adult population - screening

Database: Ovid MEDLINE(R) without Revisions <1996 to January Week 2 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <January 19, 2015>, Ovid MEDLINE(R) Daily Update < January 19, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Depression/ ()
2. Depressive Disorder/ ()
3. Depressive Disorder, Major/ ()
4. Dysthymic Disorder/ ()
5. depress$.ti,ab. ()
6. dysthym$.ti,ab. ()
7. 1 or 2 or 3 or 4 or 5 or 6 ()
8. Mass screening/ ()
9. screen$.ti,ab. ()
10. casefinding.ti,ab. ()
11. case finding.ti,ab. ()
12. (diagnos$ or detect$ or identif$).ti. ()
13. 8 or 9 or 10 or 11 or 12 ()
14. 7 and 13 ()
15. Mental disorders/di ()
16. depress$.ti,ab. ()
17. 15 and 16 ()
18. 14 or 17 ()
19. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
20. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
21. (random$ or placebo$).ti,ab. ()
22. control groups/ or double-blind method/ or single-blind method/ ()
23. clinical trial$.ti,ab. ()
24. controlled trial$.ti,ab. ()
25. (meta analy$ or metaanaly$).ti,ab. ()
26. 19 or 20 or 21 or 22 or 23 or 24 or 25 ()
27. 18 and 26 ()
28. limit 27 to “all child (0 to 18 years)” ()
29. limit 27 to “all adult (19 plus years)” ()
30. 28 not 29 ()
31. 27 not 30 ()
32. limit 31 to (english language and yr=“2009 -Current”) ()
33. remove duplicates from 32 ()

#### Pregnant and postpartum women – screening and test performance

Database: Ovid MEDLINE(R) without Revisions <1996 to January Week 2 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < January 19, 2015>, Ovid MEDLINE(R) Daily Update < January 19, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Pregnant women/ ()
3. Prenatal care/ ()
4. Perinatal care/ ()
5. Postnatal care/ ()
6. Postpartum period/ ()
7. Peripartum period/ ()
8. Maternal Health Services/ ()
9. Puerperal Disorders/ ()
10. pregnan$.ti,ab. ()
11. prenatal.ti,ab. ()
12. pre natal.ti,ab. ()
13. perinatal.ti,ab. ()
14. peri natal.ti,ab. ()
15. antenatal.ti,ab. ()
16. ante natal.ti,ab. ()
17. antepartum.ti,ab. ()
18. ante partum.ti,ab. ()
19. postnatal.ti,ab. ()
20. post natal.ti,ab. ()
21. postpartum.ti,ab. ()
22. post partum.ti,ab. ()
23. new mother$.ti,ab. ()
24. puerperal.ti,ab. ()
25. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 ()
26. Depression/ ()
27. Depressive Disorder/ ()
28. Depressive Disorder, Major/ ()
29. Dysthymic Disorder/ ()
30. Anxiety/ ()
31. depress$.ti,ab. ()
32. dysthym$.ti,ab. ()
33. (anxiety or anxious).ti,ab. ()
34. blues.ti,ab. ()
35. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 ()
36. 25 and 35 ()
37. Depression, Postpartum/ ()
38. 36 or 37 ()
39. Mass screening/ ()
40. Questionnaires/ ()
41. Interview/ ()
42. Psychiatric Status Rating Scales/ ()
43. Self Report/ ()
44. screen$.ti,ab. ()
45. casefinding.ti,ab. ()
46. case finding.ti,ab. ()
47. self report$.ti,ab. ()
48. (depress$ adj5 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$)).ti,ab. ()
49. Patient Health Questionnaire.ti,ab. ()
50. PHQ-2.ti,ab. ()
51. PHQ-9.ti,ab. ()
52. “Hospital Anxiety and Depression Scale”.ti,ab. ()
53. Geriatric Depression Scale.ti,ab. ()
54. Beck Depression Inventory.ti,ab. ()
55. Center for Epidemiologic Studies Depression Scale.ti,ab. ()
56. Hamilton Depression Rating Scale.ti,ab. ()
57. Hamilton Rating Scale for Depression.ti,ab. ()
58. Montgomery-Asberg Depression Rating Scale.ti,ab. ()
59. Zung Self-Rating Depression Scale.ti,ab. ()
60. Quick Inventory of Depressive Symptoms.ti,ab. ()
61. Mini-Neuropsychiatric Interview.ti,ab. ()
62. Composite International Diagnostic Interview.ti,ab. ()
63. Primary Care Evaluation of Mental Disorders.ti,ab. ()
64. PRIME-MD.ti,ab. ()
65. Center for Epidemiologic Studies Depression Scale.ti,ab. ()
66. CES-D.ti,ab. ()
67. General Health Questionnaire.ti,ab. ()
68. GHQ-D.ti,ab. ()
69. Generalized Contentment Scale.ti,ab. ()
70. Edinburgh Postpartum Depression Scale.ti,ab. ()
71. EPDS.ti,ab. ()
72. Bromley Postnatal Depression Scale.ti,ab. ()
73. Postpartum Depression Screening Scale.ti,ab. ()
74. PDSS.ti,ab. ()
75. Leverton Questionnaire.ti,ab. ()
76. Postpartum Depression Predictors Inventory.ti,ab. ()
77. PDPI$.ti,ab. ()
78. 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 ()
79. 38 and 78 ()
80. Postpartum Depression/di ()
81. 79 or 80 ()
82. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
83. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
84. (random$ or placebo$).ti,ab. ()
85. control groups/ or double-blind method/ or single-blind method/ ()
86. clinical trial$.ti,ab. ()
87. controlled trial$.ti,ab. ()
88. (meta analy$ or metaanaly$).ti,ab. ()
89. 82 or 83 or 84 or 85 or 86 or 87 or 88 ()
90. 81 and 89 ()
91. limit 90 to (english language and yr=“2012 -Current”) ()
92. “Sensitivity and Specificity”/ ()
93. “Predictive Value of Tests”/ ()
94. ROC Curve/ ()
95. False Negative Reactions/ ()
96. False Positive Reactions/ ()
97. Diagnostic Errors/ ()
98. “Reproducibility of Results”/ ()
99. Reference Values/ ()
100. Reference Standards/ ()
101. Observer Variation/ ()
102. Receiver operat$.ti,ab. ()
103. ROC curve$.ti,ab. ()
104. sensitivit$.ti,ab. ()
105. specificit$.ti,ab. ()
106. predictive value.ti,ab. ()
107. accuracy.ti,ab. ()
108. false positive$.ti,ab. ()
109. false negative$.ti,ab. ()
110. miss rate$.ti,ab. ()
111. error rate$.ti,ab. ()
112. 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 ()
113. 81 and 112 ()
114. limit 113 to (english language and yr=“2012 -Current”) ()
115. 91 or 114 ()
116. remove duplicates from 115 ()

#### Pregnant and postpartum women – drug treatment and harms

Database: Ovid MEDLINE(R) without Revisions <1996 to January Week 2 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < January 19, 2015>, Ovid MEDLINE(R) Daily Update < January 19, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Pregnant women/ ()
3. Prenatal care/ ()
4. Perinatal care/ ()
5. Postnatal care/ ()
6. Postpartum period/ ()
7. Peripartum Period/ ()
8. Maternal Health Services/ ()
9. Puerperal Disorders/ ()
10. pregnan$.ti,ab. ()
11. prenatal.ti,ab. ()
12. pre natal.ti,ab. ()
13. perinatal.ti,ab. ()
14. peri natal.ti,ab. ()
15. antenatal.ti,ab. ()
16. ante natal.ti,ab. ()
17. antepartum.ti,ab. ()
18. ante partum.ti,ab. ()
19. postnatal.ti,ab. ()
20. post natal.ti,ab. ()
21. postpartum.ti,ab. ()
22. post partum.ti,ab. ()
23. new mother$.ti,ab. ()
24. puerperal.ti,ab. ()
25. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 ()
26. Depression/ ()
27. Depressive Disorder/ ()
28. Depressive Disorder, Major/ ()
29. Dysthymic Disorder/ ()
30. Anxiety/ ()
31. depress$.ti,ab. ()
32. dysthym$.ti,ab. ()
33. (anxiety or anxious).ti,ab. ()
34. blues.ti,ab. ()
35. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 ()
36. 25 and 35 ()
37. Depression, Postpartum/ ()
38. 36 or 37 ()
39. Antidepressive Agents/ ()
40. Antidepressive Agents, Second-Generation/ ()
41. Serotonin Uptake Inhibitors/ ()
42. Neurotransmitter Uptake Inhibitors/ ()
43. Adrenergic Uptake Inhibitors/ ()
44. Dopamine Uptake Inhibitors/ ()
45. Citalopram/ ()
46. Fluoxetine/ ()
47. Fluvoxamine/ ()
48. Paroxetine/ ()
49. Sertraline/ ()
50. Bupropion/ ()
51. (antidepress$ or anti depress$).ti,ab. ()
52. pharmacotherap$.ti,ab. ()
53. (psychotropic adj (drug$ or agent$ or medicat$ or medicine$)).ti,ab. ()
54. Serotonin$ Uptake Inhib$.ti,ab. ()
55. Serotonin$ Re uptake Inhib$.ti,ab. ()
56. Serotonin$ Reuptake Inhib$.ti,ab. ()
57. (serotonergic adj (drug$ or agent$ or medicat$)).ti,ab. ()
58. SSRI$.ti,ab. ()
59. SNRI$.ti,ab. ()
60. Neurotransmitter Uptake Inhib$.ti,ab. ()
61. Neurotransmitter Re uptake Inhib$.ti,ab. ()
62. Neurotransmitter Reuptake Inhib$.ti,ab. ()
63. Adrenergic Uptake Inhib$.ti,ab. ()
64. Adrenergic Re uptake Inhib$.ti,ab. ()
65. Adrenergic Reuptake Inhib$.ti,ab. ()
66. Norepinephrine Uptake Inhib$.ti,ab. ()
67. Norepinephrine Re uptake Inhib$.ti,ab. ()
68. Norepinephrine Reuptake Inhib$.ti,ab. ()
69. Dopamine Uptake Inhib$.ti,ab. ()
70. Dopamine Re uptake Inhib$.ti,ab. ()
71. Dopamine Reuptake Inhib$.ti,ab. ()
72. Bupropion.ti,ab. ()
73. Celexa.ti,ab. ()
74. Citalopram.ti,ab. ()
75. Cymbalta.ti,ab. ()
76. Desvenlafaxine.ti,ab. ()
77. Duloxetine.ti,ab. ()
78. Effexor.ti,ab. ()
79. Escitalopram.ti,ab. ()
80. Fluoxetine.ti,ab. ()
81. Fluvoxamine.ti,ab. ()
82. Lexapro.ti,ab. ()
83. Mirtazapine.ti,ab. ()
84. Nefazodone.ti,ab. ()
85. Paroxetine.ti,ab. ()
86. Paxil.ti,ab. ()
87. Pexeva.ti,ab. ()
88. Pristiq.ti,ab. ()
89. Prozac.ti,ab. ()
90. Remeron.ti,ab. ()
91. Sertraline.ti,ab. ()
92. Trazadone.ti,ab. ()
93. Venlafaxine.ti,ab. ()
94. Wellbutrin.ti,ab. ()
95. Zoloft.ti,ab. ()
96. 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 ()
97. 38 and 96 ()
98. Depression, Postpartum/dt [Drug Therapy] ()
99. 97 or 98 ()
100. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
101. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
102. (random$ or placebo$).ti,ab. ()
103. control groups/ or double-blind method/ or single-blind method/ ()
104. clinical trial$.ti,ab. ()
105. controlled trial$.ti,ab. ()
106. (meta analy$ or metaanaly$).ti,ab. ()
107. 100 or 101 or 102 or 103 or 104 or 105 or 106 ()
108. 99 and 107 ()
109. limit 108 to (english language and yr=“2012 -Current”) ()
110. Mortality/ ()
111. Morbidity/ ()
112. Death/ ()
113. “Drug-Related Side Effects and Adverse Reactions”/ ()
114. safety.ti,ab. ()
115. harm$.ti,ab. ()
116. mortality.ti,ab. ()
117. toxicity.ti,ab. ()
118. complication$.ti,ab. ()
119. (death or deaths).ti,ab. ()
120. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. ()
121. adverse effects.fs. ()
122. toxicity.fs. ()
123. mortality.fs. ()
124. Prenatal Injuries/ ()
125. Prenatal Exposure Delayed Effects/ ()
126. Fetal Development/ ()
127. Congenital Abnormalities/ ()
128. Abnormalities, Drug-Induced/ ()
129. (deform$ or malform$).ti,ab. ()
130. (congenital adj (defect$ or abnormality)).ti,ab. ()
131. birth defect$.ti,ab. ()
132. teratogen$.ti,ab. ()
133. birth outcome$.ti,ab. ()
134. Infant, Low Birth Weight/ ()
135. Infant, Small for Gestational Age/ ()
136. Infant, Very Low Birth Weight/ ()
137. Infant, Extremely Low Birth Weight/ ()
138. low birth weight$.ti,ab. ()
139. small for gestational age.ti,ab. ()
140. fetal growth.ti,ab. ()
141. Maternal Exposure/ ()
142. maternal exposure.ti,ab. ()
143. Pregnancy Outcome/ ()
144. pregnancy outcome$.ti,ab. ()
145. Pregnancy Complications/ ()
146. Pregnancy Complications, Cardiovascular/ ()
147. (cardiac or cardiovascular).ti,ab. ()
148. Suicide/ ()
149. Suicidal Ideation/ ()
150. Suicide, Attempted/ ()
151. suicid$.ti,ab. ()
152. Seizures/ ()
153. seizure$.ti,ab. ()
154. Hyponatremia/ ()
155. hyponatremi$.ti,ab. ()
156. Drug-Induced Liver Injury/ ()
157. hepatoxicity.ti,ab. ()
158. Serotonin Syndrome/ ()
159. serotonin syndrome.ti,ab. ()
160. Hypertension/ ()
161. (blood pressure$ or hypertens$).ti,ab. ()
162. Sexual Dysfunction, Physiological/ ()
163. (sexual adj (function$ or disorder$ or dysfunction$)).ti,ab. ()
164. (libido adj3 (decrease$ or loss)).ti,ab. ()
165. Nausea/ ()
166. Vomiting/ ()
167. (nausea$ or nauseous or vomit$).ti,ab. ()
168. Diarrhea/ ()
169. diarr$.ti,ab. ()
170. Dizziness/ ()
171. (dizzy or dizziness).ti,ab. ()
172. Headache/ ()
173. headache$.ti,ab. ()
174. Xerostomia/ ()
175. xerostomia$.ti,ab. ()
176. (dry$ adj3 mouth).ti,ab. ()
177. Weight Gain/ ()
178. (weight adj3 (gain$ or increase$)).ti,ab. ()
179. Metabolic Syndrome X/ ()
180. metabolic syndrome.ti,ab. ()
181. withdrawal$.ti,ab. ()
182. discontinu$.ti,ab. ()
183. 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 or 137 or 138 or 139 or 140 or 141 or 142 or 143 or 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156 or 157 or 158 or 159 or 160 or 161 or 162 or 163 or 164 or 165 or 166 or 167 or 168 or 169 or 170 or 171 or 172 or 173 or 174 or 175 or 176 or 177 or 178 or 179 or 180 or 181 or 182 ()
184. 99 and 183 ()
185. Milk, human/ ()
186. Lactation/ ()
187. Breast Feeding/ ()
188. Breast Milk Expression/ ()
189. (breast feed$ or breastfeed$ or breast fed or breastfed or lactat$).ti,ab. ()
190. 185 or 186 or 187 or 188 or 189 ()
191. (96 or 98) and 190 ()
192. 184 or 191 ()
193. limit 192 to (english language and yr=“2012 -Current”) ()
194. 109 or 193 ()
195. Animal/ not (Animal/ and Human/) ()
196. 194 not 195 ()
197. remove duplicates from 196 ()

#### Pregnant and postpartum women – psychotherapy treatment

Database: Ovid MEDLINE(R) without Revisions <1996 to January Week 2 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <January 19, 2015>, Ovid MEDLINE(R) Daily Update < January 19, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Pregnant women/ ()
3. Prenatal care/ ()
4. Perinatal care/ ()
5. Postnatal care/ ()
6. Postpartum period/ ()
7. Peripartum period/ ()
8. Maternal Health Services/ ()
9. Puerperal Disorders/ ()
10. pregnan$.ti,ab. ()
11. prenatal.ti,ab. ()
12. pre natal.ti,ab. ()
13. perinatal.ti,ab. ()
14. peri natal.ti,ab. ()
15. antenatal.ti,ab. ()
16. ante natal.ti,ab. ()
17. antepartum.ti,ab. ()
18. ante partum.ti,ab. ()
19. postnatal.ti,ab. ()
20. post natal.ti,ab. ()
21. postpartum.ti,ab. ()
22. post partum.ti,ab. ()
23. new mother$.ti,ab. ()
24. puerperal.ti,ab. ()
25. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 ()
26. Depression/ ()
27. Depressive Disorder/ ()
28. Depressive Disorder, Major/ ()
29. Dysthymic Disorder/ ()
30. Anxiety/ ()
31. depress$.ti,ab. ()
32. dysthym$.ti,ab. ()
33. (anxiety or anxious).ti,ab. ()
34. blues.ti,ab. ()
35. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 ()
36. 25 and 35 ()
37. Depression, Postpartum/ ()
38. 36 or 37 ()
39. Psychotherapy/ ()
40. Psychotherapy, Brief/ ()
41. Psychotherapy, Group/ ()
42. Behavior Therapy/ ()
43. Cognitive Therapy/ ()
44. Counseling/ ()
45. Directive Counseling/ ()
46. Nondirective Therapy/ ()
47. Problem Solving/ ()
48. psychotherap$.ti,ab. ()
49. (psychological adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
50. (psychosocial adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
51. (behavi$ adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
52. (cognitive adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
53. cbt.ti,ab. ()
54. (psychodynamic adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
55. (nondirective adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
56. (non directive adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
57. interpersonal therap$.ti,ab. ()
58. interpersonal psychotherap$.ti,ab. ()
59. interpersonal intervention$.ti,ab. ()
60. supportive therap$.ti,ab. ()
61. group therap$.ti,ab. ()
62. counsel$.ti,ab. ()
63. problem solving.ti,ab. ()
64. 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 ()
65. 38 and 64 ()
66. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
67. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
68. (random$ or placebo$).ti,ab. ()
69. control groups/ or double-blind method/ or single-blind method/ ()
70. clinical trial$.ti,ab. ()
71. controlled trial$.ti,ab. ()
72. (meta analy$ or metaanaly$).ti,ab. ()
73. 66 or 67 or 68 or 69 or 70 or 71 or 72 ()
74. 65 and 73 ()
75. limit 74 to (english language and yr=“2012 -Current”) ()

#### Pregnant and postpartum women – collaborative care

Database: Ovid MEDLINE(R) without Revisions <1996 to January Week 2 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < January 19, 2015>, Ovid MEDLINE(R) Daily Update < January 19, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Pregnant women/ ()
3. Prenatal care/ ()
4. Perinatal care/ ()
5. Postnatal care/ ()
6. Postpartum period/ ()
7. Peripartum period/ ()
8. Maternal Health Services/ ()
9. Puerperal Disorders/ ()
10. pregnan$.ti,ab. ()
11. prenatal.ti,ab. ()
12. pre natal.ti,ab. ()
13. perinatal.ti,ab. ()
14. peri natal.ti,ab. ()
15. antenatal.ti,ab. ()
16. ante natal.ti,ab. ()
17. antepartum.ti,ab. ()
18. ante partum.ti,ab. ()
19. postnatal.ti,ab. ()
20. post natal.ti,ab. ()
21. postpartum.ti,ab. ()
22. post partum.ti,ab. ()
23. new mother$.ti,ab. ()
24. puerperal.ti,ab. ()
25. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 ()
26. Depression/ ()
27. Depressive Disorder/ ()
28. Depressive Disorder, Major/ ()
29. Dysthymic Disorder/ ()
30. Anxiety/ ()
31. depress$.ti,ab. ()
32. dysthym$.ti,ab. ()
33. (anxiety or anxious).ti,ab. ()
34. blues.ti,ab. ()
35. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 ()
36. 25 and 35 ()
37. Depression, Postpartum/ ()
38. 36 or 37 ()
39. Case management/ ()
40. Patient care team/ ()
41. Cooperative behavior/ ()
42. Community mental health services/ ()
43. Interprofessional Relations/ ()
44. Continuity of patient care/ ()
45. Patient-centered care/ ()
46. Patient care management/ ()
47. Delivery of Health Care, Integrated/ ()
48. collaborat$.ti,ab. ()
49. interdisciplinary.ti,ab. ()
50. multidisciplinary.ti,ab. ()
51. (integrated adj5 (healthcare or care)).ti,ab. ()
52. care manag$.ti,ab. ()
53. case manag$.ti,ab. ()
54. cooperative care.ti,ab. ()
55. patient centered care.ti,ab. ()
56. 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 ()
57. 38 and 56 ()
58. Depression, Postpartum/dh, pc, rh, th [Diet Therapy, Prevention & Control, Rehabilitation, Therapy] ()
59. 57 or 58 ()
60. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
61. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
62. (random$ or placebo$).ti,ab. ()
63. control groups/ or double-blind method/ or single-blind method/ ()
64. clinical trial$.ti,ab. ()
65. controlled trial$.ti,ab. ()
66. (meta analy$ or metaanaly$).ti,ab. ()
67. 60 or 61 or 62 or 63 or 64 or 65 or 66 ()
68. 59 and 67 ()
69. limit 68 to (english language and yr=“2009 -Current”) ()

### PsycInfo

#### Adult population – screening

Database: PsycINFO <1806 to January Week 2 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Major depression/ ()
2. Dysthymic disorder/ ()
3. depress$.ti,ab,id. ()
4. dysthym$.ti,ab,id. ()
5. 1 or 2 or 3 or 4 ()
6. Screening/ ()
7. Health Screening/ ()
8. Screening Tests/ ()
9. Intake Interview/ ()
10. Symptom Checklists/ ()
11. Interviews/ ()
12. Questionnaires/ ()
13. Rating Scales/ ()
14. Psychological Screening Inventory/ ()
15. Psychodiagnostic Interview/ ()
16. General Health Questionnaire/ ()
17. Beck Depression Inventory/ ()
18. Zungs Self Rating Depression Scale/ ()
19. screen$.ti,ab,id. ()
20. casefinding.ti,ab,id. ()
21. case finding.ti,ab,id. ()
22. (diagnos$ or detect$ or identif$).ti. ()
23. 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 ()
24. 5 and 23 ()
25. random$.ti,ab,id,hw. ()
26. placebo$.ti,ab,hw,id. ()
27. controlled trial$.ti,ab,id,hw. ()
28. clinical trial$.ti,ab,id,hw. ()
29. meta analy$.ti,ab,hw,id. ()
30. metaanaly$.ti,ab,hw,id. ()
31. treatment outcome clinical trial.md. ()
32. 25 or 26 or 27 or 28 or 29 or 30 or 31 ()
33. 24 and 32 ()
34. limit 33 to (100 childhood <birth to age 12 yrs> or 120 neonatal <birth to age 1 mo> or 140 infancy <2 to 23 mo> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>) ()
35. limit 33 to “300 adulthood <age 18 yrs and older>” ()
36. 34 not 35 ()
37. 33 not 36 ()
38. limit 37 to (english language and yr=“2009 -Current”) ()

### PsycInfo

#### Pregnant and postpartum women – screening and test performance

Database: PsycINFO <1806 to January Week 2 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Expectant Mothers/ ()
3. Prenatal Care/ ()
4. Perinatal Period/ ()
5. Postnatal Period/ ()
6. Mother Child Relations/ ()
7. pregnan$.ti,ab,id. ()
8. prenatal.ti,ab,id. ()
9. pre natal.ti,ab,id. ()
10. perinatal.ti,ab,id. ()
11. peri natal.ti,ab,id. ()
12. antenatal.ti,ab,id. ()
13. ante natal.ti,ab,id. ()
14. antepartum.ti,ab,id. ()
15. ante partum.ti,ab,id. ()
16. postnatal.ti,ab,id. ()
17. post natal.ti,ab,id. ()
18. postpartum.ti,ab,id. ()
19. post partum.ti,ab,id. ()
20. new mother$.ti,ab,id. ()
21. puerperal.ti,ab,id. ()
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 ()
23. Major Depression/ ()
24. Dysthymic disorder/ ()
25. Anxiety/ ()
26. depress$.ti,ab,id. ()
27. dysthym$.ti,ab,id. ()
28. (anxiety or anxious).ti,ab,id. ()
29. blues.ti,ab,id. ()
30. 23 or 24 or 25 or 26 or 27 or 28 or 29 ()
31. 22 and 30 ()
32. Postpartum Depression/ ()
33. Postpartum Psychosis/ ()
34. 31 or 32 or 33 ()
35. Screening/ ()
36. Health Screening/ ()
37. Screening Tests/ ()
38. Intake Interview/ ()
39. Symptom Checklists/ ()
40. Interviews/ ()
41. Questionnaires/ ()
42. Rating Scales/ ()
43. Psychological Screening Inventory/ ()
44. Psychodiagnostic Interview/ ()
45. Self Report/ ()
46. General Health Questionnaire/ ()
47. Beck Depression Inventory/ ()
48. Zungs Self Rating Depression Scale/ ()
49. screen$.ti,ab,id. ()
50. casefinding.ti,ab,id. ()
51. case finding.ti,ab,id. ()
52. self report$.ti,ab,id. ()
53. (depress$ adj5 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$)).ti,ab,id. ()
54. Patient Health Questionnaire.ti,ab,id. ()
55. PHQ-2.ti,ab,id. ()
56. PHQ-9.ti,ab,id. ()
57. “Hospital Anxiety and Depression Scale”.ti,ab,id. ()
58. Geriatric Depression Scale.ti,ab,id. ()
59. Beck Depression Inventory.ti,ab,id. ()
60. Center for Epidemiologic Studies Depression Scale.ti,ab,id. ()
61. Hamilton Depression Rating Scale.ti,ab,id. ()
62. Hamilton Rating Scale for Depression.ti,ab,id. ()
63. Montgomery-Asberg Depression Rating Scale.ti,ab,id. ()
64. Zung Self-Rating Depression Scale.ti,ab,id. ()
65. Quick Inventory of Depressive Symptoms.ti,ab,id. ()
66. Mini-Neuropsychiatric Interview.ti,ab,id. ()
67. Composite International Diagnostic Interview.ti,ab,id. ()
68. Primary Care Evaluation of Mental Disorders.ti,ab,id. ()
69. PRIME-MD.ti,ab,id. ()
70. Center for Epidemiologic Studies Depression Scale.ti,ab,id. ()
71. CES-D.ti,ab,id. ()
72. General Health Questionnaire.ti,ab,id. ()
73. GHQ-D.ti,ab,id. ()
74. Generalized Contentment Scale.ti,ab,id. ()
75. Edinburgh Postpartum Depression Scale.ti,ab,id. ()
76. EPDS.ti,ab,id. ()
77. Bromley Postnatal Depression Scale.ti,ab,id. ()
78. Postpartum Depression Screening Scale.ti,ab,id. ()
79. PDSS.ti,ab,id. ()
80. Leverton Questionnaire.ti,ab,id. ()
81. Postpartum Depression Predictors Inventory.ti,ab,id. ()
82. PDPI$.ti,ab,id. ()
83. 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 ()
84. 34 and 83 ()
85. random$.ti,ab,id,hw. ()
86. placebo$.ti,ab,hw,id. ()
87. controlled trial$.ti,ab,id,hw. ()
88. clinical trial$.ti,ab,id,hw. ()
89. meta analy$.ti,ab,hw,id. ()
90. metaanaly$.ti,ab,hw,id. ()
91. treatment outcome clinical trial.md. ()
92. 85 or 86 or 87 or 88 or 89 or 90 or 91 ()
93. 84 and 92 ()
94. limit 93 to (english language and yr=“2012 -Current”) ()
95. ROC curve/ ()
96. Psychometrics/ ()
97. Test Validity/ ()
98. Interrater Reliability/ ()
99. validity.ti,ab,id. ()
100. reliability.ti,ab,id. ()
101. psychometrics.ti,ab,id. ()
102. Receiver operat$.ti,ab,id. ()
103. ROC curve$.ti,ab,id. ()
104. sensitivit$.ti,ab,id. ()
105. specificit$.ti,ab,id. ()
106. predictive value.ti,ab,id. ()
107. accuracy.ti,ab,id. ()
108. false positive$.ti,ab,id. ()
109. false negative$.ti,ab,id. ()
110. miss rate$.ti,ab,id. ()
111. error rate$.ti,ab,id. ()
112. 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 ()
113. 84 and 112 ()
114. limit 113 to (english language and yr=“2012 -Current”) ()
115. 94 or 114 ()

#### Pregnant and postpartum women – drug treatment

Database: PsycINFO <1806 to January Week 2 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Expectant Mothers/ ()
3. Prenatal Care/ ()
4. Perinatal Period/ ()
5. Postnatal Period/ ()
6. Mother Child Relations/ ()
7. pregnan$.ti,ab,id. ()
8. prenatal.ti,ab,id. ()
9. pre natal.ti,ab,id. ()
10. perinatal.ti,ab,id. ()
11. peri natal.ti,ab,id. ()
12. antenatal.ti,ab,id. ()
13. ante natal.ti,ab,id. ()
14. antepartum.ti,ab,id. ()
15. ante partum.ti,ab,id. ()
16. postnatal.ti,ab,id. ()
17. post natal.ti,ab,id. ()
18. postpartum.ti,ab,id. ()
19. post partum.ti,ab,id. ()
20. new mother$.ti,ab,id. ()
21. puerperal.ti,ab,id. ()
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 ()
23. Major Depression/ ()
24. Dysthymic disorder/ ()
25. Anxiety/ ()
26. depress$.ti,ab,id. ()
27. dysthym$.ti,ab,id. ()
28. (anxiety or anxious).ti,ab,id. ()
29. blues.ti,ab,id. ()
30. 23 or 24 or 25 or 26 or 27 or 28 or 29 ()
31. 22 and 30 ()
32. Postpartum Depression/ ()
33. Postpartum Psychosis/ ()
34. 31 or 32 or 33 ()
35. Drug Therapy/ ()
36. Antidepressant Drugs/ ()
37. Serotonin Reuptake Inhibitors/ ()
38. Serotonin Norepinephrine Reuptake Inhibitors/ ()
39. Neurotransmitter Uptake Inhibitors/ ()
40. Bupropion/ ()
41. Citalopram/ ()
42. Fluoxetine/ ()
43. Fluvoxamine/ ()
44. Nefazodone/ ()
45. Paroxetine/ ()
46. Sertraline/ ()
47. Trazodone/ ()
48. Venlafaxine/ ()
49. (antidepress$ or anti depress$).ti,ab,id. ()
50. pharmacotherap$.ti,ab,id. ()
51. (psychotropic adj (drug$ or agent$ or medicat$ or medicine$)).ti,ab,id. ()
52. Serotonin$ Uptake Inhib$.ti,ab,id. ()
53. Serotonin$ Re uptake Inhib$.ti,ab,id. ()
54. Serotonin$ Reuptake Inhib$.ti,ab,id. ()
55. (serotonergic adj (drug$ or agent$ or medicat$)).ti,ab,id. ()
56. SSRI$.ti,ab,id. ()
57. SNRI$.ti,ab,id. ()
58. Neurotransmitter Uptake Inhib$.ti,ab,id. ()
59. Neurotransmitter Re uptake Inhib$.ti,ab,id. ()
60. Neurotransmitter Reuptake Inhib$.ti,ab,id. ()
61. Adrenergic Uptake Inhib$.ti,ab,id. ()
62. Adrenergic Re uptake Inhib$.ti,ab,id. ()
63. Adrenergic Reuptake Inhib$.ti,ab,id. ()
64. Norepinephrine Uptake Inhib$.ti,ab,id. ()
65. Norepinephrine Re uptake Inhib$.ti,ab,id. ()
66. Norepinephrine Reuptake Inhib$.ti,ab,id. ()
67. Dopamine Uptake Inhib$.ti,ab,id. ()
68. Dopamine Re uptake Inhib$.ti,ab,id. ()
69. Dopamine Reuptake Inhib$.ti,ab,id. ()
70. Bupropion.ti,ab,id. ()
71. Celexa.ti,ab,id. ()
72. Citalopram.ti,ab,id. ()
73. Cymbalta.ti,ab,id. ()
74. Desvenlafaxine.ti,ab,id. ()
75. Duloxetine.ti,ab,id. ()
76. Effexor.ti,ab,id. ()
77. Escitalopram.ti,ab,id. ()
78. Fluoxetine.ti,ab,id. ()
79. Fluvoxamine.ti,ab,id. ()
80. Lexapro.ti,ab,id. ()
81. Mirtazapine.ti,ab,id. ()
82. Nefazodone.ti,ab,id. ()
83. Paroxetine.ti,ab,id. ()
84. Paxil.ti,ab,id. ()
85. Pexeva.ti,ab,id. ()
86. Pristiq.ti,ab,id. ()
87. Prozac.ti,ab,id. ()
88. Remeron.ti,ab,id. ()
89. Sertraline.ti,ab,id. ()
90. Trazadone.ti,ab,id. ()
91. Venlafaxine.ti,ab,id. ()
92. Wellbutrin.ti,ab,id. ()
93. Zoloft.ti,ab,id. ()
94. 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 ()
95. 34 and 94 ()
96. limit 95 to animal ()
97. limit 95 to human ()
98. 96 not 97 ()
99. 95 not 98 ()
100. limit 99 to (english language and yr=“2012 -Current”) ()

#### Pregnancy/postpartum – psychotherapy treatment

Database: PsycINFO <1806 to January Week 2 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Expectant Mothers/ ()
3. Prenatal Care/ ()
4. Perinatal Period/ ()
5. Postnatal Period/ ()
6. Mother Child Relations/ ()
7. pregnan$.ti,ab,id. ()
8. prenatal.ti,ab,id. ()
9. pre natal.ti,ab,id. ()
10. perinatal.ti,ab,id. ()
11. peri natal.ti,ab,id. ()
12. antenatal.ti,ab,id. ()
13. ante natal.ti,ab,id. ()
14. antepartum.ti,ab,id. ()
15. ante partum.ti,ab,id. ()
16. postnatal.ti,ab,id. ()
17. post natal.ti,ab,id. ()
18. postpartum.ti,ab,id. ()
19. post partum.ti,ab,id. ()
20. new mother$.ti,ab,id. ()
21. puerperal.ti,ab,id. ()
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 ()
23. Major Depression/ ()
24. Dysthymic disorder/ ()
25. Anxiety/ ()
26. depress$.ti,ab,id. ()
27. dysthym$.ti,ab,id. ()
28. (anxiety or anxious).ti,ab,id. ()
29. blues.ti,ab,id. ()
30. 23 or 24 or 25 or 26 or 27 or 28 or 29 ()
31. 22 and 30 ()
32. Postpartum Depression/ ()
33. Postpartum Psychosis/ ()
34. 31 or 32 or 33 ()
35. Psychotherapy.hw. ()
36. Counseling.hw. ()
37. Therapy.hw. ()
38. Behavior Therapy/ ()
39. Cognitive Therapy/ ()
40. Cognitive Behavior Therapy/ ()
41. Cognitive Restructuring/ ()
42. Problem Solving/ ()
43. psychotherap$.ti,ab,id. ()
44. (psychological adj5 (therap$ or treatment$ or intervention$)).ti,ab,id. ()
45. (psychosocial adj5 (therap$ or treatment$ or intervention$)).ti,ab,id. ()
46. (behavi$ adj5 (therap$ or treatment$ or intervention$)).ti,ab,id. ()
47. (cognitive adj5 (therap$ or treatment$ or intervention$)).ti,ab,id. ()
48. cbt.ti,ab,id. ()
49. (psychodynamic adj5 (therap$ or treatment$ or intervention$)).ti,ab. ()
50. (nondirective adj5 (therap$ or treatment$ or intervention$)).ti,ab,id. ()
51. (non directive adj5 (therap$ or treatment$ or intervention$)).ti,ab,id. ()
52. interpersonal therap$.ti,ab,id. ()
53. interpersonal psychotherap$.ti,ab,id. ()
54. interpersonal intervention$.ti,ab,id. ()
55. supportive therap$.ti,ab,id. ()
56. group therap$.ti,ab,id. ()
57. counsel$.ti,ab,id. ()
58. problem solving.ti,ab,id. ()
59. 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 ()
60. 34 and 59 ()
61. random$.ti,ab,id,hw. ()
62. placebo$.ti,ab,hw,id. ()
63. controlled trial$.ti,ab,id,hw. ()
64. clinical trial$.ti,ab,id,hw. ()
65. meta analy$.ti,ab,hw,id. ()
66. treatment outcome clinical trial.md. ()
67. 61 or 62 or 63 or 64 or 65 or 66 ()
68. 60 and 67 ()
69. limit 68 to (english language and yr=“2012 -Current”) ()

#### Pregnancy/postpartum – collaborative care

Database: PsycINFO <1806 to January Week 2 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Pregnancy/ ()
2. Expectant Mothers/ ()
3. Prenatal Care/ ()
4. Perinatal Period/ ()
5. Postnatal Period/ ()
6. Mother Child Relations/ ()
7. pregnan$.ti,ab,id. ()
8. prenatal.ti,ab,id. ()
9. pre natal.ti,ab,id. ()
10. perinatal.ti,ab,id. ()
11. peri natal.ti,ab,id. ()
12. antenatal.ti,ab,id. ()
13. ante natal.ti,ab,id. ()
14. antepartum.ti,ab,id. ()
15. ante partum.ti,ab,id. ()
16. postnatal.ti,ab,id. ()
17. post natal.ti,ab,id. ()
18. postpartum.ti,ab,id. ()
19. post partum.ti,ab,id. ()
20. new mother$.ti,ab,id. ()
21. puerperal.ti,ab,id. ()
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 ()
23. Major Depression/ ()
24. Dysthymic disorder/ ()
25. Anxiety/ ()
26. depress$.ti,ab,id. ()
27. dysthym$.ti,ab,id. ()
28. (anxiety or anxious).ti,ab,id. ()
29. blues.ti,ab,id. ()
30. 23 or 24 or 25 or 26 or 27 or 28 or 29 ()
31. 22 and 30 ()
32. Postpartum Depression/ ()
33. Postpartum Psychosis/ ()
34. 31 or 32 or 33 ()
35. Interdisciplinary Treatment Approach/ ()
36. Integrated Services/ ()
37. Collaboration/ ()
38. Cooperation/ ()
39. Case Management/ ()
40. Work Teams/ ()
41. Community Mental Health Services/ ()
42. Health Care Delivery/ ()
43. Community Psychology/ ()
44. Community Psychiatry/ ()
45. collaborat$.ti,ab,id. ()
46. interdisciplinary.ti,ab,id. ()
47. multidisciplinary.ti,ab,id. ()
48. (integrated adj5 (healthcare or care)).ti,ab,id. ()
49. care manag$.ti,ab,id. ()
50. case manag$.ti,ab,id. ()
51. cooperative care.ti,ab,id. ()
52. patient centered care.ti,ab,id. ()
53. 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 48 or 49 or 50 or 51 or 52 ()
54. 34 and 53 ()
55. random$.ti,ab,id,hw. ()
56. placebo$.ti,ab,hw,id. ()
57. controlled trial$.ti,ab,id,hw. ()
58. clinical trial$.ti,ab,id,hw. ()
59. meta analy$.ti,ab,hw,id. ()
60. metaanaly$.ti,ab,hw,id. ()
61. treatment outcome clinical trial.md. ()
62. 55 or 56 or 57 or 58 or 59 or 60 or 61 ()
63. 54 and 62 ()
64. limit 63 to (english language and yr=“2009 -Current”) ()

### PubMed, publisher-supplied

#### General adult population

#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND (#2 OR #3) AND #4 AND publisher[sb] AND English[Language] AND (“2009”[Date - Publication] : “2015”[Date - Publication])
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search random*[tiab] OR placebo*[tiab] OR trial[tiab] OR trials[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR “meta analyses”[tiab] OR “meta analytic”[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search diagnos*[title] OR detect*[title] OR identif*[title]
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search screen*[tiab] OR casefinding[tiab] OR “case finding”[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search depress*[title] OR dysthym*[title] OR mental[title] OR mood[title] OR psycholog*[title] OR psychiat*[title]

#### Pregnant/postpartum population

#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #4 OR #6 OR #8
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #2 AND #7 AND publisher[sb] AND English[Language] AND (“2012”[Date - Publication] : “2015”[Date - Publication]
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search treat*[tiab] OR therap*[tiab] OR antidepress*[tiab] OR pharmacotherap*[tiab] OR psychotropic*[tiab] OR drug*[tiab] OR medicat*[tiab] OR medicine*[tiab]
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #2 AND #5 AND publisher[sb] AND English[Language] AND “2012”[Date - Publication] : “2014”[Date - Publication]
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search screen*[tiab] OR casefinding[tiab] OR “case finding”[tiab] OR scale*[tiab] OR inventor*[tiab] OR questionnaire*[tiab] OR survey*[tiab] OR index*[tiab] OR checklist*[tiab] OR interview*[tiab] OR diagnos*[title] OR detect*[title] OR identif*[title]
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #2 AND #3 AND publisher[sb] AND English[Language] AND “2009”[Date - Publication] : “2014”[Date - Publication]
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search random*[tiab] OR placebo*[tiab] OR trial[tiab] OR trials[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR “meta analyses”[tiab] OR “meta analytic”[tiab]
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search depress*[title] OR dysthym*[title] OR anxiety[title] OR anxious[title] OR blues[title] OR mental[title] OR mood[title] OR psycholog*[title] OR psychiat*[title]
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search pregnan*[title] OR prenatal[title] OR pre natal[title] OR perinatal[title] OR peri natal[title] OR antenatal[title] OR ante natal[title] OR antepartum[title] OR ante partum[title] OR postnatal[title] OR post natal[title] OR postpartum[title] OR post partum[title] OR mother*[title] OR maternal[title] OR puerperal[title]

### Cochrane Central Register of Controlled Trials : Issue 5 of 19, January 2015

#### Adult population – Screening

#1 | (depress* or dysthym*):ti,ab,kw
#2 | screen*:ti,ab,kw
#3 | (casefinding or “case finding”):ti,ab,kw
#4 | (detect* or identif*):ti,ab,kw
#5 | diagnos*:ti
#6 | #2 or #3 or #4 or #5
#7 | #1 and #6 Publication Year from 2009 to 2015, in Trials

#### Pregnant/postpartum population - screening

#1 | pregnan*:ti,ab,kw
#2 | prenatal:ti,ab,kw
#3 | pre natal:ti,ab,kw
#4 | perinatal:ti,ab,kw
#5 | peri natal:ti,ab,kw
#6 | antenatal:ti,ab,kw
#7 | ante natal:ti,ab,kw
#8 | antepartum:ti,ab,kw
#9 | ante partum:ti,ab,kw
#10 | postnatal:ti,ab,kw
#11 | post natal:ti,ab,kw
#12 | postpartum:ti,ab,kw
#13 | post partum:ti,ab,kw
#14 | (new next mother*):ti,ab,kw
#15 | puerperal:ti,ab,kw
#16 | or #1-#15
#17 | depress$:ti,ab,kw
#18 | dysthym*:ti,ab,kw
#19 | (anxiety or anxious):ti,ab,kw
#20 | blues:ti,ab,kw
#21 | #17 or #18 or #19 or #20
#22 | #16 and #21 Publication Year from 2009 to 2015, in Trials

Appendix B Figure 1 Literature Flow Diagram: Pregnant and Postpartum Women

Abbreviations: CE = comparative effectiveness; KQ = Key Question.

This figure is a flow chart that summarizes the search and selection of articles in pregnant and postpartum women. There were 8,919 citations identified through literature databases. An additional 381 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 6,523 unique citations were screened at the title/abstract stage. The full-text of 455 citations were examined for inclusion for one or more of the five Key Questions. The following number of articles were included for Key Question 1 (n=8), Key Question 2 (n=25), Key Question 3 (n=1), Key Question 4 (n=21), and Key Question 5 (n=13, including 1 systematic review). Reasons for excluding the other articles are available in Appendix C.

Appendix B Figure 2 Literature Flow Diagram: General Adult Population, Including Older Adults

Abbreviations: CE = comparative effectiveness; KQ = Key Question; SER = systematic evidence review.

This figure is a flow chart that summarizes the search and selection of articles in general and older adults. There were 8,919 citations identified through literature databases. An additional 381 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 6,523 unique citations were screened at the title/abstract stage. The full-text of 455 citations were examined for inclusion for one or more of the Key Questions. The following number of articles were included for Key Question 1 (n=17) and Key Question 2 (n=5). Reasons for excluding the other articles are available in Appendix C.

Appendix B Table 1 Inclusion and Exclusion Criteria: General Adult Population, Including Older Adults

Category | Inclusion criteria | Exclusion criteria
Condition definition | Focus on major depressive disorder, persistent depressive disorder/dysthymia, and depression not otherwise specified, or “depression” with no further diagnostic specificity | Trials restricted only to persons with bipolar disorder, schizoaffective disorder, seasonal affective disorder, cyclothymia, substance-induced mood disorder, minor depression, or adjustment disorder with depressed mood
Aim | Studies targeting depression screening | Studies restricted to screening or treatment of suicidality, bipolar disorder, or treatment-resistant depression
Population | Adults, including older adults, age 18 years and older | - Nonhuman populations; - Children and adolescents (age <18 years), except when related to harms of antidepressants in pregnant women; - Persons in institutions (e.g., psychiatric inpatients or prison inmates); - Persons in long-term care (e.g., nursing homes); - Trials limited to persons with comorbid conditions; - Trials within closed preexisting social networks (e.g., church, worksite programs)
Intervention | Brief standardized instrument designed to identify persons with depression (no more than 15 minutes if completed prior to visit, no more than 5 minutes if completed during visit); self-report, clinician-administered, or electronically delivered | Trials primarily using treatment modalities other than psychotherapy or FDA-approved antidepressants (e.g., exercise, electroshock treatment, St. John's wort, social marketing, policy, system-level interventions, or adjunctive agents to enhance the effects of antidepressants)
Comparator | Usual care, no screening, and screening with no feedback of results to providers
Outcomes | Benefits of screening (KQ 1): Primary health outcomes; - Depression symptoms; - Depression remission; - Other health outcomes; - Depression response; - Suicide deaths, attempts, or ideation; - All-cause mortality; - Quality of life; - Functioning (including days of missed work); - Change in health status (e.g., improvement in comorbid conditions or reduction in physical complaints); - Emergency department visits or inpatient stays; Harms of screening (KQ 2):; - Treatment avoidance; - Deterioration in patient-provider relationship; - Other harms reported by screening trials; - Labeling or stigma; - Inappropriate/unnecessary treatment
Timing of outcome assessment | ≥6 weeks after baseline
Setting | - Primary care settings (e.g., internal medicine, family medicine, obstetrics/gynecology, family planning, military health clinics, university-based health clinics); - Virtual (e.g., online screening tools), if patients are identified through screening in primary care or other population-based screening; - Psychotherapy: Mental health clinic setting acceptable only if patients are identified through screening in primary care or other population-based screening | - Community/university research laboratories or other nonmedical centers; - Mental health clinics (unless recruitment is through primary care screening); - Correctional facilities; - School classrooms; - Worksites; - Inpatient/residential facilities; - Emergency departments
Study design | RCTs, CCTs | All other study designs
Country | Countries categorized as “Very High” on the Human Development Index (as defined by the World Health Organization): Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei, Canada, Chile, Croatia, Cyprus , Czech Republic , Denmark , Estonia, Finland, France , Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy , Japan, Korea Rep , Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand , Norway, Poland , Portugal, Qatar, Seychelles, Singapore, Slovakia/Slovak Republic, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States + Taiwan. | Countries not categorized as “Very High” on the Human Development Index
Language | English | Languages other than English
Study quality | Fair or good | Poor, according to design-specific USPSTF criteria

Abbreviations: FDA = Food and Drug Administration; KQ = Key Question; RCT = randomized, controlled trial; CCT = controlled clinical trial.

Appendix B Table 2 Inclusion and Exclusion Criteria: Pregnant and Postpartum Women

Category | Inclusion criteria | Exclusion criteria
Condition definition | Focus on major depressive disorder, persistent depressive disorder/dysthymia, and depression not otherwise specified, or “depression” with no further diagnostic specificity | Trials restricted only to persons with bipolar disorder, schizoaffective disorder, seasonal affective disorder, cyclothymia, substance-induced mood disorder, minor depression, or adjustment disorder with depressed mood
Aim | Screening (KQs 1, 3) and treatment (KQs 4, 5): Studies targeting depression screening and treatment Diagnostic accuracy of screening (KQ 2): Studies addressing accuracy of depression screening instruments Harms of antidepressants (KQ 5): Studies addressing harms of antidepressants | Studies restricted to screening or treatment of suicidality, bipolar disorder, or resistant depression
Population | Screening (KQs 1, 3): Pregnant and postpartum women age 18 years and older Treatment (KQs 4, 5): Pregnant and postpartum women who screen positive for depression in a primary care setting or are identified through other population-based screening | - Nonhuman populations; - Children and adolescents (age <18 years), except when related to harms of antidepressants in pregnant women; - Persons in institutions (e.g., psychiatric inpatients or prison inmates); - Persons in long-term care (e.g., nursing homes); - Trials limited to persons with comorbid conditions; - Trials within closed preexisting social networks (e.g., church, worksite programs)
Intervention | Screening (KQs 1, 3): Brief standardized instrument designed to identify persons with depression (no more than 15 minutes if completed prior to visit, no more than 5 minutes if completed during visit); self-report, clinician-administered, or electronically delivered Instrument accuracy (KQ 2): Limited to the most widely used screening tools in this population—the Patient Health Questionnaire (PHQ), in any form, including the related Primary Care Evaluation of Mental Disorders Patient Questionnaire (PRIME-MD, depression section), and the Edinburgh Postpartum Depression Scale (EPDS) Treatment (KQs 4, 5): Primary care–relevant interventions, including psychotherapy, FDA-approved antidepressants (except tricyclic antidepressants [TCAs] and monoamine oxidase inhibitors[MAOIs], and collaborative care | Treatment modalities other than psychotherapy or FDA-approved antidepressants (e.g., exercise, electroshock treatment, St. John's wort, social marketing, policy, system-level interventions, or adjunctive agents to enhance the effects of antidepressants); TCAs and MAOIs
Comparator | Screening (KQs 1, 3): Usual care, no screening, and screening with no feedback of results to providers Treatment (KQs 4, 5): Psychotherapy; - No intervention; - Usual care; - Waitlist; - Attention control; - Minimal intervention (e.g., usual care limited to no more than 15 minutes of information); Antidepressants; - No intervention; - Placebo; - Waitlist; Collaborative care; - Usual care | Treatment (KQs 4, 5 ): Active intervention (i.e., comparative effectiveness)
Outcomes | Benefits of screening (KQ 1) and treatment (KQ 4): Primary health outcomes; - Depression symptoms; - Depression remission; Other health outcomes; - Depression response; - Suicide deaths, attempts, or ideation; - All-cause mortality; - Quality of life; - Functioning (including days of missed work); - Change in health status (e.g., improvement in comorbid conditions or reduction in physical complaints); - Child/infant outcomes (continuation of breastfeeding, achievement of recognized developmental milestones, reduced abuse or neglect); - Emergency department visits or inpatient stays; Diagnostic accuracy of screening (KQ 2):; - Sensitivity; - Specificity; - Positive predictive value; - Negative predictive value; - Equivalent data to make such calculations (i.e., 2 × 2 table); Harms of screening (KQ 3):; - Treatment avoidance; - Deterioration in patient-provider relationship; - Other harms reported by screening trials; - Labeling or stigma; - Inappropriate/unnecessary treatment; Harms of antidepressant treatment (KQ 5):; - Suicidality; - Serotonin syndrome; - Cardiac effects; - Seizures (bupropion only); - Fetal/infant harms (neonatal death, major malformations, small for gestational age/low birth weight, preeclampsia)
Timing of outcome assessment | Screening (KQs 1, 3): ≥6 weeks after baseline Diagnostic accuracy of screening (KQ 2): Maximum of 2 weeks between screening and reference standard Treatment (KQs 4, 5):; - ≥6 weeks after baseline for treatment and harms of psychotherapy or collaborative care; - No minimum followup for harms of antidepressants
Setting | - Primary care settings (e.g., internal medicine, family medicine, obstetrics/gynecology, pediatrics [for postpartum screening], family planning, military health clinics, university-based health clinics); - Virtual (e.g., online screening tools), if patients are identified through screening in primary care or other population-based screening; - Psychotherapy: Mental health clinic setting acceptable only if patients are identified through screening in primary care or other population-based screening; Harms of antidepressant treatment (KQ 5): Any outpatient clinical setting | - Community/university research laboratories or other nonmedical centers; - Mental health clinics (unless recruitment is through primary care screening); - Correctional facilities; - School classrooms; - Worksites; - Inpatient/residential facilities; - Emergency departments
Study design | Benefits of screening (KQ 1), harms of screening (KQ 3), and benefits of treatment (KQ 4): RCTs, CCTs Diagnostic accuracy (KQ 2): Comparison with gold standard (structured or semistructured diagnostic interview or a nonbrief [>5 minutes] unstructured interview with mental health clinician) within 2 weeks of screening in populations that include a full spectrum of patient severity for the given setting (i.e., studies cannot limit the patient pool to only nondepressed and known/highly likely depressed patients) Harms of antidepressant treatment (KQ 5): Systematic reviews; large comparative cohort or case-control observational studies published after identified systematic reviews that include observational studies. “Large” is operationalized as:; - n ≥10,000 with at least 6 months of followup for suicide attempts and deaths; - n ≥1,000 with at least 3 months of followup for other outcomes | All other study designs
Country | Countries categorized as “Very High” on the Human Development Index (as defined by the World Health Organization): Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei, Canada, Chile, Croatia, Cyprus , Czech Republic , Denmark , Estonia, Finland, France , Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy , Japan, Korea Rep , Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand , Norway, Poland , Portugal, Qatar, Seychelles, Singapore, Slovakia/Slovak Republic, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States + Taiwan. | Countries not categorized as “Very High” on the Human Development Index
Language | English | Languages other than English
Study quality | Fair or good | Poor, according to design-specific USPSTF criteria

Abbreviations: FDA = Food and Drug Administration; KQ = Key Question; RCT = randomized, controlled trial; CCT = controlled clinical trial.

Appendix B Table 3 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods94 | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was there a difference in attrition between groups?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there risk of contamination?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)96 | - Was there representativeness of the exposed cohort?; - Was the non-exposed systematically selected?; - Was the ascertainment of exposure reported?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid and reliable?; - Were outcome assessors blinded?; - Was followup long enough for the outcome to occur?; - Was there acceptable followup?; - Was there adjustment for confounders?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) II instrument95 | - Could the selection of patients have introduced bias?; ○ Was a consecutive or random sample of patients enrolled?; ○ Was a case-control design avoided?; ○ Did the study avoid inappropriate exclusions?; - Could the conduct or interpretation of the index test have introduced bias?; ○ Was the index test interpreted without knowledge of the reference standard results?; ○ If a threshold was use, was it pre-specified?; ○ Was staff trained in the use of the index test?; ○ Was the fidelity of the index test monitored and/or reported?; - Could the conduct or interpretation of the reference standard have introduced bias?; ○ Is the reference standard likely to correctly classify the target condition?; ○ Was the reference standard interpreted without knowledge of the index test results?; ○ Was staff trained in the assessment of the reference standard?; ○ Was the fidelity of the reference test monitored and/or reported?; - Could the patient flow have introduced bias?; ○ Was there an appropriate interval between the index test and reference standard?; ○ Did all patients receive the same reference standard?; ○ Did the whole or partial selection of patients receive the reference standard? If so, was it adjusted?; ○ Was the order of tests randomized among patients?; ○ Did all participants complete both the index test and reference standard?; ○ Were all patients included in the analysis?
Assessment of Multiple Systematic Reviews (AMSTAR)97 | - Was an ‘a priori’ design provided?; - Was there dual study selection?; - Was there dual data extraction?; - Was a comprehensive literature search performed?; - Was a list of studies included provided?; - Was a list of excluded studies provided?; - Were the characteristics of the included studies provided?; - Was the scientific quality of the included studies assessed and documented?; - Was the scientific quality of the included studies used appropriately in formulating conclusions?; - Were the methods used to combine the findings of studies appropriate?; - Was the likelihood of publication bias assessed?; - Were potential conflicts of interest/source(s) of support of the systematic review stated?; - Were potential conflicts of interest/source(s) of support of the included studies stated?