# References

1 Chou R, Dana T, Bougatsos C. Screening for Visual Impairment in Older Adults: Systematic Review to Update the 1996 U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 71. AHRQ Publication No. 09-05135-EF-1. Rockville, Maryland. Agency for Healthcare Research and Quality. 2009.
2 Chou R, Dana T, Bougatsos C. Screening older adults for impaired visual acuity: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(1):44-58.
3 U. S. Preventive Services Task Force. Screening for impaired visual acuity in older adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(1):37-43. [pmid: 19581645].
4 Selph S, Dana T, Bougatsos C, Blazina I, Patel H, Chou R. Screening for Abnormal Glucose and Type 2 Diabetes Mellitus: Systematic Review to Update the 2008 U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 117. AHRQ Publication No. 13-05190-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2015.
5 Ervin AM, Boland MV, Myrowitz EH, Prince J, Hawkins B, Vollenweider D, Ward D, Suarez-Cuervo C, Robinson KA. Screening for Glaucoma: Comparative Effectiveness. Comparative Effectiveness Review No. 59. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061.) AHRQ Publication No. 12-EHC037-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012.
6 Munoz B, West SK, Rubin GS, et al. Causes of blindness and visual impairment in a population of older Americans: The Salisbury Eye Evaluation Study. Arch Ophthalmol. 2000;118(6):819-825. [pmid: 10865321].
7 Vitale S, Cotch MF, Sperduto RD. Prevalence of visual impairment in the United States. JAMA. 2006;295:2158-2163. [pmid: 16684986].
8 International Council for Ophthalmology. Visual Standards: Aspects and Ranges of Vision Loss with Emphasis on Populations Surveys. Sydney, Australia. International Council of Ophthalmology. 2002.
9 Fisher JB, Jacobs DA, Markowitz CE, et al. Relation of visual function to retinal nerve fiber layer thickness in multiple sclerosis. Ophthalmology. 2006;113(2):324-332. [pmid: 16406539].
10 The Eye Diseases Prevalence Research Group. The prevalence of refractive errors among adults in the United States, Western Europe, and Australia. Arch Ophthalmol. 2004;122(4):495-505. [pmid: 15078666].
11 Centers for Disease Control and Prevention National Center for Health Statistics. Summary Health Statistics for U.S. Adults: National Health Interview Survey. 2011. http://www.cdc.gov/nchs/data/series/sr_10/sr10_256.pdf.
12 The Eye Diseases Prevalence Research Group. Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol. 2004;122:477-485. [pmid: 15078664].
13 Centers for Disease Control and Prevention National Center for Chronic Disease Prevention and Health Promotion. The State of Vision, Aging, and Public Health in America. 2011. http://www.cdc.gov/visionhealth/pdf/vision_brief.pdf.
14 Klein R, Chou CF, Klein BE, Zhang X, Meuer SM, Saaddine JB. Prevalence of age-related macular degeneration in the US population. Arch Ophthalmol. 2011;129(1):75-80. [pmid: 21220632].
15 Zambelli-Weiner A, Crews JE, Friedman DS. Disparities in adult vision health in the United States. Am J Ophthalmol. 2012;154(6 Suppl):S23-30 e21. [pmid: 22633355].
16 The Eye Diseases Prevalence Research Group. Prevalence of cataract and pseudophakia/aphakia among adults in the United States. Arch Ophthalmol. 2004;122:487-494. [pmid: 15078665].
17 Eye Health Statistics at a Glance. 2011. http://www.aao.org/newsroom/upload/Eye-Health-Statistics-April-2011.pdf.
18 Weale RA. Epidemiology of refractive errors and presbyopia. Surv Ophthalmol. 2003;48(5):515-543. [pmid: 14499819].
19 Tanna AP, Kaye HS, Tanna AP, Kaye HS. Trends in self-reported visual impairment in the United States: 1984 to 2010. Ophthalmology. 2012;119(10):2028-2032. [pmid: 22683061].
20 National Eye Institute. The Eye Health Needs of Older Adults. 2013. http://www.nei.nih.gov/nehep/research/The_Eye_Health_needs_of_Older_Adults_Literature_Review.pdf.
21 Rubin G, Roche KB, Prasada-Rao P, Fried LP. Visual Impairment and disability in older adults. Optom Vis Sci. 1994;71:750-760. [pmid: 7898882].
22 Klein BEK, Moss SE, Klein R, Lee KE, Cruickshanks KJ. Associations of visual function with physical outcomes and limitations 5 years later in an older population: The Beaver Dam eye study. Ophthalmology. 2003;110(4):644-650. [pmid: 12689880].
23 Haymes SA, Johnston AW, Heyes AD. Relationship between vision impairment and ability to perform activities of daily living. Ophthalmic Physiol Opt. 2002;22(2):79-91. [pmid: 12014491].
24 Sims RV, Owsley C, Allman RM, Ball K, Smoot TM. A preliminary assessment of the medical and functional factors associated with vehicle crashes by older adults. J Am Geratr Soc. 1998;46:556-561.
25 Owsley C, Stalvey B, Wells J, et al. Older drivers and cataract. Driving habits and crash risk. The Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 1999;54:M203-211.
26 McGwin G Jr, Chapman V, Owsley C. Visual risk factors for driving difficulty among older drivers. Accid Anal Prev. 2000;32(6):735-744. [pmid: 10994600].
27 Lord SR, Dayhew J. Visual risk factors for falls in older people. J Am Geriatr Soc. 2001;49(5):508-515. [pmid: 11380741].
28 Ivers RQ, Cumming RG, Mitchell P, Attebo K. Visual impairment and falls in older adults: the Blue Mountains Eye Study. J Am Geriatr Soc. 1998;46:58-64. [pmid: 9434666].
29 Chou CF, Cotch MF, Vitale S, et al. Age-related eye diseases and visual impairment among U.S. adults. Am J Prev Med. 2013;45(1):29-35. [pmid: 23790986].
30 American Foundation for the Blind. Aging and vision loss fact sheet. 2013. http://www.afb.org/info/programs-and-services/professional-development/experts-guide/aging-and-vision-loss/1235.
31 Centers for Disease Control and Prevention. Vision Health Initiative. 2013. http://www.cdc.gov/visionhealth/index.htm.
32 American Foundation for the Blind. Special Report on Aging and vision Loss. 2013. http://www.afb.org/info/blindness-statistics/special-report-on-aging-and-vision-loss/25.
33 Administration on Aging, Administration for Community Living, U.S. Department of Health and Human Services. 2012 Profile of Older Americans. 2012. http://www.aoa.gov/AoARoot/Aging_Statistics/Profile/2012/docs/2012profile.pdf.
34 American Academy of Ophthalmology. Comprehensive adult medical eye evaluation - 2010. http://one.aao.org/preferred-practice-pattern/comprehensive-adult-medical-eye-evaluation--octobe.
35 Hyman L. Myopic and hyperopic refractive error in adults: an overview. Ophthalmic Epidemiol. 2007;14(4):192-197. [pmid: 17896297].
36 Asbell PA, Dualan I, Mindel J, Brocks D, Ahmad M, Epstein S. Age-related cataract. Lancet. 2005;365:599-609. [pmid: 15708105].
37 de Jong PTVM. Age-related macular degeneration. N Engl J Med. 2006;355:1474-1485. [pmid: 17021323].
38 Congdon NG. Prevention strategies for age related cataract. Br J Ophthalmol. 2001;85:516-520. [pmid: 11316704].
39 West SK, Valmadrid CT. Epidemiology of risk factors for age-related cataracts. Surv Ophthalmol. 1995;39:323-334. [pmid: 7725232].
40 Sommer A, Tielsch JM, Katz J, et al. Racial differences in the cause-specific prevalence of blindness in east Baltimore. N Engl J Med. 1991;325(20):1412-1417. [pmid: 1922252].
41 Smith W, Assink J, Klein R, et al. Risk factors for age-related macular degeneration. Pooled findings from three continents. Ophthalmology. 2001;108:697-704. [pmid: 11297486].
42 National Eye Institute. News brief: three studies point to same risk gene for age-related macular degeneration. 2013. http://www.nei.nih.gov/news/briefs/risk_gene_amd.asp?nav=rss.
43 Centers for Disease Control. Improving the Nation’s Vision Health. A Coordinated Public Health Approach. 2010. http://www.cdc.gov/visionhealth/pdf/improving_nations_vision_health.pdf.
44 The Eye Diseases Prevalence Research Group. Prevalence of age-related macular degeneration in the United States. Arch Ophthalmol. 2004;122(4):564-572. [pmid: 15078675].
45 Ghanem RC, de la Cruz J, Tobaigy FM, Ang LPK, Azar DT. LASIK in the presbyopic age group: safety, efficacy, and predictability in 40- to 69-year-old patients. Ophthalmology. 2007;114(7):1303-1310. [pmid: 17382397].
46 Macular Photocoagulation Study Group. Argon laser photocoagulation for senile macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1982;100(6):912-918. [pmid: 7046707].
47 Riaz Y, Mehta JS, Wormald R, et al. Surgical interventions for age-related cataract. Cochrane Database Syst Rev. 2008;1.
48 Rosenthal BP. Ophthalmology. Screening and treatment of age-related and pathologic vision changes. Geriatrics. 2001;56(12):27-31. [pmid: 11766560].
49 Evans JR. Ginkgo Biloba extract for age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
50 McNeil JJ, Robman L, Tikellis G, Sinclair MI, McCarty CA, Taylor HR. Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75-84. [pmid: 14711717].
51 Christen WG, Manson JE, Glynn RJ, et al. A randomized trial of beta carotene and age-related cataract in US physicians. Arch Ophthalmol. 2003;121(3):372-378. [pmid: 12617708].
52 Christen W, Glynn R, Sperduto R, Chew E, Buring J. Age-related cataract in a randomized trial of beta-carotene in women. Ophthalmic Epidemiol. 2004;11(5):401-412. [pmid: 15590586].
53 Gohel PS, Mandava N, Olson JL, Durairaj VD. Age-related macular degeneration: an update on treatment. Am J Med. 2008;121(4):279-281. [pmid: 18374683].
54 Chiu C-J, Taylor A. Nutritional antioxidants and age-related cataract and maculopathy. Exp Eye Res. 2007;84(2):229-245. [pmid: 16879819].
55 Geltzer A, Turalba A, Vedula SS. Surgical implantation of steroids with antiangiogenic characteristics for treating neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
56 Reddy U, Krzystolik M. Antiangiogenic therapy with interferon alfa for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
57 Sivagnanavel V, Evans JR, Ockrim Z, Chong V. Radiotherapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
58 Loewenstein JI, Palmberg PF, Connett JE, Wentworth DN. Effectiveness of a pinhole method for visual acuity screening. Arch Ophthamol. 1985;103:222-223.
59 Melki SA, Safar A, Martin J, Ivanova A, Adi M. Potential acuity pinhole: a simple method to measure potential visual acuity in patients with cataracts, comparison to potential acuity meter. Ophthalmology. 1999;106(7):1262-1267. [pmid: 10406603].
60 Amsler M. Earliest symptoms of diseases of the macular. Br J Ophthalmol. 1953;37:521-537. [pmid: 13081950].
61 Fine AM. Earliest symptoms caused by neovascular membranes in the macula. Arch Opthalmol. 1986;104:513-514.
62 Fine SL. Early detection of extrafoveal neovascular membranes by daily central field evaluation. Opthalmology. 1985;92:603-609.
63 Haase KW, Bryant EE. Development of a scale designed to measure functional distance vision loss using an interview technique. Porc Am Stat Assoc. 1973;(SS):274-279.
64 Zheng X, Saaddine JB, Lee PP, et al. Eye care in the United States. Do we deliver to high-risk people who can benefit most from it?. Arch Opthalmol. 2007;125:411-418.
65 Rosenfield M. Computer vision syndrome: a review of ocular causes and potential treatments. Opthalmic Phyciol Opt. 2011;31(5):502-515.
66 American Optometric Association. Adult Vision: Over 60 Years of age. 2013. http://www.aoa.org/patients-and-public/good-vision-throughout-life/adult-vision-19-to-40-years-of-age/adult-vision-over-60-years-of-age.
67 American Academy of Family Physicians. Clinical recommendations: visual difficulties, adults. 2013. http://www.aafp.org/patient-care/clinical-recommendations/all/visual.html.
68 Procedure Manual. U. S. Preventive Services Task Force. 2014. http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
69 Eekhof J, De Bock G, Schaapveld K, Springer M. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329-333. [pmid: 10934182].
70 Moore AA, Siu A, Partridge JM, Hays RD, Adams J. A randomized trial of office-based screening for common problems in older persons. Am J Med. 1997;102(4):371-378. [pmid: 9217619].
71 Smeeth L, Fletcher AE, Hanciles S, Evans J, Wormald R. Screening older people for impaired vision in primary care: cluster randomised trial. BMJ. 2003;327(7422):1027-1031. [pmid: 14593039].
72 Cumming RG, Ivers R, Clemson L, et al. Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175-181. [pmid: 17302652].
73 Swamy B, Cumming RG, Ivers R, et al. Vision screening for frail older people: a randomised trial. Br J Ophthalmol. 2009;93(6):736-741. [pmid: 18614568].
74 Ariyasu RG, Lee PP, Linton KP, LaBree LD, Azen SP, Siu AL. Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population. Ophthalmology. 1996;103(11):1751-1760. [pmid: 8942866].
75 Eekhof JA, De Bock GH, Schaapveld K, Springer MP. Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action?. Scand J Prim Health Care. 2000;18(4):203-207. [pmid: 11205087].
76 Hiller R, Krueger DE. Validity of a survey question as a measure of visual acuity impairment. Am J Public Health. 1983;73:93-96. [pmid: 6848004].
77 Ivers RQ, Optom B, Macaskill P, Cumming RG, Mitchell P. Sensitivity and specificity of tests to detect eye disease in an older population. Ophthalmology. 2001;108(5):968-975. [pmid: 11320029].
78 McMurdo M, Baines P. The detection of visual disability in the elderly. Health Bulletin. 1988;46(6):327-329. [pmid: 3240947].
79 Teh RC, Lim WS. Utility of a patient-response screening question for visual impairment. J Am Geriatr Soc. 2006;54(2):370-372. [pmid: 16460398].
80 Wang F, Tielsch JM, Ford DE, Quigley HA, Whelton PK. Evaluation of screening schemes for eye disease in a primary care setting. Ophthalmic Epidemiol. 1998;5(2):69-82. [pmid: 9672907].
81 Woods RL, Tregear SJ, Mitchell RA. Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity. Ophthalmology. 1998;105(12):2318-2326. [pmid: 9855166].
82 Jessa Z, Evans BJW, Thomson DW. The development & evaluation of two vision screening tools for correctable visual loss in older people. Ophthalmic Physiol Opt. 2012;32(4):332-348. [pmid: 22670892].
83 Swanson MW, McGwin G Jr, Elliott AF, Owsley C. The nursing home minimum data set for vision and its association with visual acuity and contrast sensitivity. J Am Geriatr Soc. 2009;57(3):486-491. [pmid: 19187419].
84 Coleman AL, Yu F, Keeler E, Mangione CM. Treatment of uncorrected refractive error improves vision-specific quality of life. J Am Geriatr Soc. 2006;54(6):883-890. [pmid: 16776781].
85 Owsley C, McGwin G Jr, Scilley K, Meek GC, Seker D, Dyer A. Effect of refractive error correction on health-related quality of life and depression in older nursing home residents. Arch Ophthalmol. 2007;125(11):1471-1477. [pmid: 17998508].
86 Elliott AF, McGwin G Jr, Owsley C. Vision-enhancing interventions in nursing home residents and their short-term effect on physical and cognitive function. J Am Geriatr Soc. 2009;57(2):202-208. [pmid: 19170783].
87 Murray A, Jones L, Milne A, Fraser CM, Lourenco T, Burr J. A systematic review of the safety and efficacy of elective photorefractive surgery for the correction of refractive error. Aberdeen. Health Services Research Unit, University of Aberdeen. April. 2005.
88 McDonnell PJ, Mangione C, Lee P, et al. Responsiveness of the National Eye Institute Refractive Error Quality of Life instrument to surgical correction of refractive error. Ophthalmology. 2003;110(12):2302-2309. [pmid: 14644711].
89 Schein OD, Vitale S, Cassard SD, Steinberg EP. Patient outcomes of refractive surgery. The refractive status and vision profile. J Cataract Refract Surg. 2001;27(5):665-673. [pmid: 11377893].
90 Tahzib NG, Bootsma SJ, Eggink FA, Nabar VA, Nuijts RM. Functional outcomes and patient satisfaction after laser in situ keratomileusis for correction of myopia. J Cataract Refract Surg. 2005;31(10):1943-1951. [pmid: 16338565].
91 Powe N, Schein O, Gieser S, et al. Synthesis of the literature on visual acuity and complications following cataract extraction with intraocular lens implantation. Arch Opthalmol. 1994;112(2):239-252.
92 Harwood RH, Foss AJE, Osborn F, Gregson RM, Zaman A, Masud T. Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial. Br J Ophthalmol. 2005;89(1):53-59. [pmid: 15615747].
93 Foss AJE, Harwood RH, Osborn F, Gregson RM, Zaman A, Masud T. Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial. Age Ageing. 2006;35(1):66-71. [pmid: 16364936].
94 Chylack LT Jr, Brown NP, Bron A, et al. The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient mixture to slow progression of age-related cataract. Ophthalmic Epidemiol. 2002;9(1):49-80. [pmid: 11815895].
95 Hall TA, McGwin G Jr, Owsley C. Effect of cataract surgery on cognitive function in older adults. J Am Geriatr Soc. 2005;53(12):2140-2144. [pmid: 16398899].
96 Owsley C, McGwin G Jr, Scilley K, Meek GC, Seker D, Dyer A. Impact of cataract surgery on health-related quality of life in nursing home residents. Br J Ophthalmol. 2007;91(10):1359-1363. [pmid: 17522143].
97 AREDS Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. 2001;119(10):1417-1436. [pmid: 11594942].
98 Evans JR. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2008;(1).
99 Chew EY, Clemons TE, Agron E, et al. Long-term effects of vitamins C and E, beta-carotene, and zinc on age-related macular degeneration: AREDS report no. 35. Ophthalmology. 2013;120(8):1604-1611.e1604. [pmid: 23582353].
100 Evans JR, Lawrenson JG. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2012;11.
101 Bartlett HE, FAE. Effect of lutein and antioxidant dietary supplementation on contrast sensitivity in age-related macular degeneration: a randomized controlled trial. Eur J Clin Nutr. 2001;61(9):1121-1127. [pmid: 17268417].
102 Piermarocchi S, Saviano S, Parisi V, et al. Carotenoids in Age-related Maculopathy Italian Study (CARMIS): two-year results of a randomized study. Eur J Ophthalmol. 2012;22(2):216-225. [pmid: 22009916].
103 Newsome DA. A randomized, prospective, placebo-controlled clinical trial of a novel zinc-monocysteine compound in age-related macular degeneration. Curr Eye Res. 2008;33(7):591-598. [pmid: 18600492].
104 Weigert G, Kaya S, Pemp B, Sacu S, Lasta M, Werkmeister RM. Effects of lutein supplementation on macular pigment optical density and visual acuity in patients with age-related macular degeneration. Invest Ophthalmol Vis Sci. 2011;52(11):8174-8178. [pmid: 21873668].
105 Murray IJ, Makridaki M, van der Veen RLP, Carden D, Parry NRA, Berendschot TTJM. Lutein supplementation over a one-year period in early AMD might have a mild beneficial effect on visual acuity: the CLEAR study. Invest Ophthalmol Vis Sci. 2013;54(3):1781-1788. [pmid: 23385792].
106 Ma L, Yan SF, Huang YM, et al. Effect of lutein and zeaxanthin on macular pigment and visual function in patients with early age-related macular degeneration. Ophthalmology. 2012;119(11):2290-2297. [pmid: 22858124].
107 Souied EH, Delcourt C, Querques G, et al. Oral docosahexaenoic acid in the prevention of exudative age-related macular degeneration: the Nutritional AMD Treatment 2 study. Ophthalmology. 2013;120(8):1619-1631. [pmid: 23395546].
108 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions. Wiley Online Library. 2008;5.
109 Holz F, Wolfensberger T, Piguet B, Gross-Jendroska M, Arden G, Bird A. Oral zinc-therapy in age-related macular degeneration: a double-blind study (abstract). German J Ophthalmol. 1993;2:391.
110 Stur M, Tittl M, Reitner A, Meisinger V. Oral zinc and the second eye in age-related macular degeneration. Invest Ophthalmol Vis Sci. 1996;37(7):1225-1235. [pmid: 8641826].
111 Garrett SK, McNeil JJ, Silagy C, et al. Methodology of the VECAT study: vitamin E intervention in cataract and age-related maculopathy. Ophthalmic Epidemiol. 1999;6(3):195-208. [pmid: 10487974].
112 Chew EY, Sperduto RD, Milton RC, et al. Risk of advanced age-related macular degeneration after cataract surgery in the Age-Related Eye Disease Study: AREDS report 25. Ophthalmology. 2009;116(2):297-303. [pmid: 19091420].
113 Virgili G, Bini A. Laser photocoagulation for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2007;1.
114 Wormald R, Evans J, Smeeth L, Henshaw K. Photodynamic therapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
115 TAP Study Group. Photodynamic therapy of subfoveal choroidal neovascularization in age-related macular degeneration with verteporfin: one-year results of 2 randomized clinical trials--TAP report. Arch Ophthalmol. 1999;117(10):1329-1345. [pmid: 10532441].
116 VIM Study Group. Verteporfin therapy in subfoveal minimally classis choroidal neovascularization in age-related macular degeneration. Arch Ophthalmol. 2005;123:448-457. [pmid: 15824216].
117 Kaiser PK. VIO Study Group. Verteporfin PDT for subfoveal occult CNV in AMD: two-year results of a randomized trial. Curr Med Res Opin. 2009;25(8):1853-1860. [pmid: 19530976].
118 VIP Study Group. Photodynamic therapy of subfoveal choroidal neovascularization in pathologic myopia with verteporfin. Ophthalmology. 2001;108:841-852. [pmid: 11320011].
119 Azab M, Boyer DS, Bressler NM, et al. Verteporfin therapy of subfoveal minimally classic choroidal neovascularization in age-related macular degeneration: 2-year results of a randomized clinical trial. Arch Ophthalmol. 2005;123(4):448-457. [pmid: 15824216].
120 Vedula SS, Krzystolik MG. Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;(2).
121 Rosenfeld PJ, Brown DM, Heier JS, et al. Ranibizumab for neovascular age-related macular degeneration. New Engl J Med. 2006;355(14):1419-1431. [pmid: 17021318].
122 Gragoudas ES, Adamis AP, Cunningham ET, Feinsod M, Guyer DR. VEGF Inhibition Study in Ocular Neovascularization Clinical Trial Group. Pegaptanib for neovascular age-related macular degeneration. N Engl J Med. 2004;351(27):2805-2816. [pmid: 15625332].
123 Regillo CD, Brown DM, Abraham P, et al. Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER Study year 1. Am J Ophthalmol. 2008;145(2):239-248. [pmid: 18222192].
124 Solomon SD, Lindsley K, Vedula SS, Krzystolik MG, Hawkins BS. Anti-vascular endothelial growth factor for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2014;8:CD005139. [pmid: 25170575].
125 Brown DM, Kaiser PK, Michels M, et al. Ranibizumab versus verteporfin for neovascular age-related macular degeneration. N Engl J Med. 2006;355(14):1432-1444. [pmid: 17021319].
126 Bressler NM, Chang TS, Varma R, et al. Driving ability reported by neovascular age-related macular degeneration patients after treatment with ranibizumab. Ophthalmology. 2013;120(1):160-168. [pmid: 23009891].
127 Chang TS, Bressler NM, Fine JT, et al. Improved vision-related function after ranibizumab treatment of neovascular age-related macular degeneration: results of a randomized clinical trial. Arch Ophthalmol. 2007;125(11):1460-1469. [pmid: 17998507].
128 Lord SR, Dayhew J, Howland A. Multifocal glasses impair edge-contrast sensitivity and depth perception and increase the risk of falls in older people. J Am Geriatr Soc. 2002;50(11):1760-1766. [pmid: 12410892].
129 Cheng KH, Leung SL, Hoekman HW, et al. Incidence of contact-lens-associated microbial keratitis and its related morbidity. Lancet. 1999;354(9174):181-185. [pmid: 10421298].
130 Nilsson SE, Montan PG. The annualized incidence of contact lens induced keratitis in Sweden and its relation to lens type and wear schedule: results of a 3-month prospective study. Clao J. 1994;20(4):225-230. [pmid: 7820916].
131 Schein OD, McNally JJ, Katz J, et al. The incidence of microbial keratitis among wearers of a 30-day silicone hydrogel extended-wear contact lens. Ophthalmology. 2005;112(12):2172-2179. [pmid: 16325711].
132 Chalmers RL, McNally JJ, Schein OD, et al. Risk factors for corneal infiltrates with continuous wear of contact lenses. Optom Vis Sci. 2007;84(7):573-579. [pmid: 17632304].
133 Schaumberg DA, Dana MR, Christen WG, Glynn R. A systematic overview of the incidence of posterior capsular opacification. Ophthalmology. 1998;105:1213-1221. [pmid: 9663224].
134 Taban M, Behrens A, Newcomb RL, et al. Acute endophthalmitis following cataract surgery: a systematic review of the literature. Arch Ophthalmol. 2005;123(5):613-620. [pmid: 15883279].
135 Johnson AR, Munoz A, Gottlieb JL, et al. High dose zinc increases hospital admissions due to genitourinary complications. J Urol. 2007;177(2):639-643. [pmid: 17222649].
136 World Health Organization. Global data on visual impairments. 2010. http://www.who.int/blindness/GLOBALDATAFINALforweb.pdf.
137 Colenbrander A. Visual standards: aspects and ranges of vision loss with emphasis on population surveys. Paper presented at: 29th International Congress of Ophthalmology. 2002. Sydney, Australia.
138 Summary of visual acuity and bioptic telescope requirements by state. 2014. http://www.mdsupport.org/library/summarychart.pdf.
139 Suner IJ, Kokame GT, Yu E, Ward J, Dolan C, Bressler NM. Responsiveness of NEI VFQ-25 to changes in visual acuity in neovascular AMD: validation studies from two phase 3 clinical trials. Invest Ophthalmol Vis Sci. 2009;50(8):3629-3635. [pmid: 19255158].
140 Lindblad AS, Clemons TE. Responsiveness of the National Eye Institute Visual Function Questionnaire to progression to advanced age-related macular degeneration, vision loss, and lens opacity: AREDS Report no. 14. Arch Ophthalmol. 2005;123(9):1207-1214. [pmid: 16157800].
141 Beck RW, Maguire MG, Bressler NM, Glassman AR, Lindblad AS, Ferris FL. Visual acuity as an outcome measure in clinical trials of retinal diseases. Ophthalmology. 2007;114(10):1804-1809. [pmid: 17908590].
142 Bilbao A, Quintana JM, Escobar A, et al. Responsiveness and clinically important differences for the VF-14 index, SF-36, and visual acuity in patients undergoing cataract surgery. Ophthalmology. 2009;116(3):418-424.e411. [pmid: 19168220].
143 Quintana JM, Aguirre U, Las-Hayas C, et al. Use of the patient acceptable symptom state and the minimal clinically important difference to evaluate the outcomes of cataract extraction. Am J Ophthalmol. 2011;152(2):234-243.e233. [pmid: 21683328].
144 Miskala PH, Hawkins BS, Mangione CM, et al. Responsiveness of the National Eye Institute Visual Function Questionnaire to changes in visual acuity: findings in patients with subfoveal choroidal neovascularization--SST Report No. 1. Arch Ophthalmol. 2003;121(4):531-539. [pmid: 12695250].
145 Arditi A, Cagenello R. On the statistical reliability of letter-chart visual acuity measurements. Invest Ophthalmol Vis Sci. 1993;34(1):120-129. [pmid: 8425819].
146 Siderov J, Tiu AL. Variability of measurements of visual acuity in a large eye clinic. Acta Ophthalmol Scand. 1999;77(6):673-676. [pmid: 10634561].
147 Rosser DA, Cousens SN, Murdoch IE, Fitzke FW, Laidlaw DA. How sensitive to clinical change are ETDRS logMAR visual acuity measurements?. Invest Ophthalmol Vis Sci. 2003;44(8):3278-3281. [pmid: 12882770].
148 Lim LA, Frost NA, Powell RJ, Hewson P. Comparison of the ETDRS logMAR, ‘compact reduced logMar’ and Snellen charts in routine clinical practice. Eye. 2010;24(4):673-677. [pmid: 19557025].
149 Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. BMJ (Clinical Research Ed.). 1978;2(6141):859-861.
150 The HOPE and HOPE-TOO Trial Investigators. Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. 2005;293:1338-1347. [pmid: 15769967].
151 Omenn GS, Goodman GE, Thornquist MD, et al. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 1996;334:1150-1155. [pmid: 8602180].
152 The Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. New Engl J Med. 1994;330:1029-1035. [pmid: 8127329].
153 Whitlock EP, Lin JS, Chou R, Shekelle P, Robinson KA. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776-782. [pmid: 18490690].
154 Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(02):138-144. [pmid: 22559755].
155 Guymer RH, Baird PN, Varsamidis M, et al. Proof of concept, randomized, placebo-controlled study of the effect of simvastatin on the course of age-related macular degeneration. PLoS ONE. 2013;8(12):e83759. [pmid: 24391822].
156 Williams MA, McKay GJ, Chakravarthy U. Complement inhibitors for age-related macular degeneration. Cochrane Database Syst Rev. 2014;(1).
157 Holladay JT. Visual acuity measurements. J Cataract Refract Surg. 2004;30(2):287-290. [pmid: 15030802].
158 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventative Services. 2009. http://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf.
159 Rosenfeld PJ, Heier JS, Hantsbarger G, Shams N. Tolerability and efficacy of multiple escalating doses of ranibizumab (Lucentis) for neovascular age-related macular degeneration. Ophthalmology. 2006;113(4):632.e631.