# Discussion

## Summary of Review Findings

Table 6 summarizes the evidence reviewed for this update. We identified no new trials of vision screening versus no screening, delayed screening, or usual care. Three fair- to good-quality cluster-randomized trials included in the prior USPSTF review1 that enrolled more than 4,700 patients found vision screening in older adults as part of a multicomponent screening intervention in primary care settings to be no more effective than no vision screening, delayed screening, or usual care.69–71 A fourth trial found that optometrist screening was associated with an increased risk of falls in frail elderly.72 The reason for an increased risk of falls in this trial was unclear, but could be related to difficulty adapting to large corrections in visual acuity or use of multifocal lenses. There remains no evidence to determine optimal screening intervals in older adults.

Table 6 Summary of Evidence

Key Question Topic | Main findings from 2009 USPSTF review | Number of studies identified for update | Number of participants identified for update | Study design identified for update | Summary of findings (including consistency and precision) | Applicability | Limitations (including reporting bias) | Overall study quality^*^
Key Question 1. Benefits of screening | 3 cluster RCTs found no difference between vision screening and usual care, no vision screening, or delayed screening on vision and other clinical outcomes. 1 RCT found that vision screening by an optometrist in frail elderly persons was associated with an increased risk of falls (rate ratio, 1.57 [95% CI, 1.20 to 2.05]) and a trend toward increased risk of fractures (RR, 1.74 [95% CI, 0.97 to 3.11]). | None | - | - | Unchanged from the 2009 review; no new studies. Evidence was consistent and imprecise. | Good (mainly primary care-applicable settings, as part of multicomponent screening intervention) | All studies had different types of comparators. Reporting bias was not detected. | Fair
Key Question 2. Harms of screening | See Key Question 1 for evidence on falls. | None | - | - | Unchanged from the 2009 review; no new studies. Evidence was precise; unable to assess consistency (1 study) | Moderate (screening was done by an optometrist) | 1 study only. Reporting bias was possible since most screening studies did not report harms. | Poor
Key Question 3. Accuracy of screening | 4 studies found that screening questions are not accurate for identifying persons with vision impairment compared to the Snellen chart. 4 studies found that visual acuity testing is not accurate for identifying the presence of vision conditions compared to a detailed ophthalmologic exam. 1 study found that the Amsler grid is not accurate for identifying the presence of vision conditions compared to a detailed ophthalmologic exam. 1 very small (n=50) study found that non-ophthalmologists are as accurate as ophthalmologists for identifying presence of cataracts. All studies were cross-sectional. | 3 | 751 | Cross-sectional | 2 new studies found that a computerized vision screening tool or a flipchart version were not accurate compared with a detailed eye exam and a third study found the Minimum Data Set 2.0 Vision Patterns section was associated with poor diagnostic accuracy compared with an eye chart exam; overall conclusions were unchanged from the 2009 review. Evidence was consistent and precise. | Moderate (tests are practical for primary care but were sometimes performed by optometrists) | Sometimes unclear if the reference standards were interpreted independently of the target test, lack of predefined thresholds for positive results. Reporting bias was possible as some studies reported accuracy based on optimal criteria for a positive test. | Fair
Key Question 4. Benefits of treatment Uncorrected Refractive Error | In 1 large population-based study, 60% of older adults with vision impairment achieved visual acuity of 20/40 or better with refractive correction. 2 RCTs found use of corrective lenses was associated with improvements in vision-related function, but effects on overall function were inconsistent. Numerous observational studies showed that >85% of patients achieved visual acuity of 20/40 or better following photorefractive surgery for myopia or hyperopia. | None | - | - | Unchanged from the 2009 review; no new studies. Evidence was consistent and precise. | Moderate | Mainly observational data and accumulated clinical experience. Reporting bias was not detected. | Fair
Cataract | Numerous observational studies found that >90% of patients achieved visual acuity of 20/40 or better following cataract extraction and intraocular lens implantation. 3 observational studies found cataract surgery was associated with improved vision-related function. 1 trial found immediate first-eye cataract surgery was associated with a decreased rate of second (but not first) fall compared to delayed surgery, resulting in a lower overall rate of falls (rate ratio, 0.66 [95% CI, 0.40 to 0.96]; p=0.03), but a second trial found no effect of second-eye cataract surgery on falls. | 2 | 346 | Prospective cohort | 2 new studies reported improved visual acuity with surgery, with no differences between groups on cognitive function or quality of life; overall conclusions were unchanged from the 2009 review. Evidence was consistent for visual acuity and inconsistent for falls and precise. | Moderate | Mainly observational data. Reporting bias was not detected. | Fair
Dry AMD–Vitamin and Mineral Supplements | A large, good-quality (n=2,556) randomized trial, the Age-Related Eye Disease Study (AREDS), reported results stratified according to the severity of AMD at baseline. Among the subgroup of patients in whom treatment was currently recommended (AREDS categories 3 and 4), AREDS found that an antioxidant + zinc combination was effective for lower likelihood of AMD progression after 6 years of followup (adjusted OR, 0.66 [95% CI, 0.47 to 0.93]), although the difference in the likelihood of ≥15 letters of visual acuity loss was not statistically significant (adjusted OR, 0.75 [95% CI, 0.55 to 1.02]). A systematic review of 9 trials (including AREDS) found insufficient evidence to determine efficacy of vitamins and minerals other than the AREDs combination. | 1 systematic review (updated version of the previously included systematic review, with 4 new RCTs) 3 RCTs + 2 additional reports from AREDS with 10-year followup | 10,010 | Systematic review and RCTs | 10-year followup from AREDS is consistent with prior results, with antioxidant supplements alone (OR, 0.70 [95% CI, 0.56 to 0.88]) or with added zinc (OR, 0.66 [95% CI, 0.53 to 0.83]) associated with decreased risk of AMD progression and the combination associated with decreased risk of visual acuity loss (OR, 0.71 [95% CI, 0.57 to 0.88]). Evidence on the effects of other vitamins and mineral treatments remains limited, with no clear effects on AMD progression or visual acuity; overall conclusions were unchanged from the 2009 review. Evidence was consistent and precise. | Good (participants in AREDS and other studies in general had mild visual impairment at baseline) | Substantial heterogeneity in interventions assessed and outcomes reported. Reporting bias was not detected. | Good
Wet AMD–Laser Photocoagulation | Laser photocoagulation was superior to no treatment for progression of vision loss (loss of ≥6 lines of visual acuity) at 2-year followup (RR, 0.67 [95% CI, 0.53 to 0.83]; 5 trials). | None | - | - | Unchanged from the prior review; no new studies. Evidence was consistent and precise. | Moderate | No new trials published since the prior review; older trials have relatively short duration of followup and methodological limitations, including use of open-label design, incomplete followup, lack of intention-to-treat analysis, and others. Reporting bias was not detected. | Fair
Wet AMD–Photodynamic Therapy | 1 systematic review found that patients undergoing PDT with verteporfin were more likely to gain ≥3 lines of visual acuity at 12 months (3 trials; RR, 2.19 [95% CI, 0.99 to 4.82]; I^2^=0%) and 24 months (3 trials; RR, 2.55 [95% CI, 1.31 to 4.99]; I^2^=0%). | None | - | - | Unchanged from the prior review; no new studies. Evidence was consistent and precise. | Moderate | No new trials published since the prior review; evidence limited to 4 older trials, 1 of which enrolled a younger population than the others (mean age 49 vs. 75–79 years). Reporting bias was not detected. | Fair
Wet AMD– VEGF Inhibitors | RR, 0.71 (95% CI, 0.61 to 0.84), 2 RCTs for pegaptanib (1 trial) and RR, 0.21 (95% CI, 0.16 to 0.27), 2 RCTs for ranibizumab (2 trials) | Additional publication from previously included trial | - | Trial | Unchanged from the 2009 review; no new studies. Evidence was consistent and precise. | Moderate | No new trials published since the prior review; study population in the 4 included trials was older (>75 years) with moderate to severe impaired visual acuity at baseline. Reporting bias was not detected. | Fair
Key Question 5. Harms of treatment Uncorrected Refractive Error | 1 small prospective study found that multifocal lenses were associated with a higher risk of falls in older adults compared to unifocal lenses (OR, 2.09 [95% CI, 1.06 to 4.92]). 3 studies found incidence of infectious keratitis ranging from 0.3 to 3.6 cases per 10,000 contact lens wearers; 1 study found incidence to be higher in persons age >50 years. Corneal ectasia rates ranged from 0% to 0.87% in 5 studies of LASIK, and keratitis rates ranged from 0% to 3.4% in 6 studies of LASIK and 4 studies of LASEK. | None | - | - | Unchanged from the 2009 review; no new studies. Evidence was consistent for contact lenses and refractive surgery (only 1 study for corrective lenses) and imprecise. | Moderate | Only 1 study on corrective lenses. Reporting bias was not detected. | Corrective lenses: Poor Contact lenses; refractive surgery: Fair
Cataract | Systematic reviews of numerous observational studies of cataract surgery found a pooled rate of posterior capsule opacification of 28% after 5 years, and a pooled rate of 0.13% for endophthalmitis. | None | - | - | Unchanged from the 2009 review; no new studies. Evidence was consistent and precise. | Moderate | Mainly observational studies. Reporting bias was not detected. | Fair
Dry AMD–Vitamin and Mineral Supplements | The large AREDS trial found that zinc was associated with significantly increased risk of hospitalization for genitourinary causes compared to nonuse of zinc (RR, 1.47 [95% CI, 1.19 to 1.80]) and antioxidants were associated with increased risk of yellow skin compared to nonuse of antioxidants (RR, 1.38 [95% CI, 1.09 to 1.75]). | 2 | 384 | RCT | 2 new trials found no difference between supplement use vs. placebo in risk of any adverse event (RR, 1.05 [95% CI, 0.97 to 1.13]), serious adverse events (RR, 1.05 [95% CI, 0.72 to 1.49]), serious ocular adverse events (RR, 1.18 [95% CI, 0.50 to 2.75]), or withdrawals due to adverse events (RR, 3.00 [95% CI, 0.33 to 28]). No new evidence on adverse events was associated with zinc or antioxidants; overall conclusions were unchanged from the 2009 review. Evidence was consistent. Evidence was precise for any adverse events but imprecise for other adverse events. | Good (participants in both studies had relatively mild visual impairment at baseline) | Neither trial was designed to assess harms and sample sizes were relatively small (n=94 and 300). Reporting bias was possible due to inconsistent reporting of harms. | Good
Wet AMD–Laser Photocoagulation | Visual acuity loss of ≥6 lines compared to observation 3 months after treatment (absolute rate, 16.6%; RR, 1.41 [95% CI, 1.08 to 1.82]; 5 trials). | None | - | - | Unchanged from the prior review; no new studies. Evidence was consistent and precise. | Moderate | Included studies were not designed to assess harms and duration of followup was short in some studies. Reporting bias was possible due to inconsistent reporting of harms. | Fair
Wet AMD–Photodynamic Therapy | Increased risk of acute severe visual acuity loss (20 letters within 7 days of treatment) compared to placebo (2% vs. 0.2%; RR, 0.02 [95% CI, 0.01 to 0.03]) and increased risk of infusion-related back pain compared to placebo (3.4% vs. 0.3%; RR, 6.50 [95% CI, 1.52 to 27.78]). | None | - | - | Unchanged from the prior review; no new studies. Evidence was consistent. Evidence was precise for risk of severe visual acuity loss and imprecise for infusion-related back pain. | Moderate | Evidence limited to 4 older trials; few adverse events reported. Reporting bias was possible due to inconsistent reporting of harms. | Fair
Wet AMD–VEGF Inhibitors | More cases of endophthalmitis and uveitis compared to placebo, but small numbers of events. No increase in risk of systemic hypertension or arterial thromboembolic events. | None | - | - | Unchanged from the 2009 review; no new studies. Evidence was consistent and imprecise. | Moderate | Evidence limited to 4 older trials; few adverse events reported. Reporting bias was possible due to inconsistent reporting of harms. | Fair

* “Overall quality” is based on new evidence plus previously reviewed evidence.

Abbreviations: AREDS = Age-Related Eye Disease Study; AMD = age-related macular degeneration; CI = confidence interval; KQ = key question; LASEK = laser assisted sub-epithelial keratomileusis; LASIK = laser assisted in situ keratomileusis; NA = not applicable; OR = odds ratio; PTD = photodynamic therapy; RCT = randomized, controlled trial; RR = relative risk; VEGF = vascular endothelin growth factor.

Conclusions regarding the suboptimal diagnostic accuracy of vision screening tests in primary care settings are also unchanged from the prior USPSTF review. Two new studies found that the accuracy of a computer-based screening tool was limited, and one study found that the MDS 2.0 Vision Patterns section questions performed poorly as a screening test.82,83 The prior USPSTF review found that no screening question is comparable in accuracy to tests of visual acuity for identifying impaired visual acuity75,76,79,80,149 and that the Snellen test is inaccurate compared to a detailed eye examination for identifying visual conditions identified on a comprehensive ophthalmological examination. However, the latter studies remain difficult to interpret, as the conditions identified on examination were not necessarily associated with impaired visual acuity. For example, it is not known whether identification of AMD or cataracts prior to the development of impaired visual acuity is associated with improved clinical outcomes compared to identification of these conditions after the development of early impaired visual acuity. Although the Snellen test remains the most widely used tool to measure visual acuity in primary care settings, no clinically relevant reference standard exists to determine its diagnostic accuracy, in part because the Snellen test is often considered the standard for assessing visual acuity in clinical practice. There remains insufficient evidence to assess the accuracy or utility of pinhole testing, the Amsler grid, visual acuity tests other than the Snellen test, physical examination, or funduscopic examination performed in primary care settings.

Conclusions from the prior USPSTF review of strong evidence showing the effectiveness of treatments versus no treatment for common causes of impaired visual acuity also remain unchanged. As noted in the prior review, a very high proportion of patients experience favorable vision-related outcomes following treatment for impaired visual acuity due to refractive error and cataracts.1 More than half of all older adults with impaired visual acuity achieve vision better than 20/40 with refractive correction,7 which can be done noninvasively in most cases with corrective lenses. In patients with cataracts, a large body of observational studies indicates that surgical extraction and intraocular lens implantation results in visual acuity of 20/40 or better in more than 90 percent of patients, and is associated with improvements in vision-related quality of life.91 Correction of refractive error and cataract removal are also associated with improvement in vision-related quality of life, although randomized trials and cohort studies have not shown clear effects on measures of function, cognition, or depression.84–86,95,96 For dry AMD, evidence showing the effectiveness of antioxidant vitamins and minerals for slowing progression of disease or improving visual acuity remains largely restricted to the large AREDS trials.97,98 Extended (10-year) followup from AREDS is now available, showing continued benefits.99 Antioxidants included in the AREDS formulation have been found to be associated with congestive heart failure (vitamin E150) and lung cancer in smokers (beta-carotene151,152) when prescribed for prevention of cancer or cardiovascular disease, although these harms were not observed in AREDS. For wet AMD, evidence reviewed in the prior USPSTF review found intravitreal injection with VEGF inhibitors and PDT with verteporfin to be effective treatment options with a relatively low incidence of serious harms, although they may be associated with an increased risk of acute decline in visual acuity.114,120 An important advantage of these treatments is that they are associated with less retinal scarring compared to laser photocoagulation, which is a particularly important consideration for patients with subfoveal (central) neovascularization. VEGF inhibitors have largely supplanted PDT and laser photocoagulation as treatment for wet AMD. We did not identify new sham-controlled trials of laser photocoagulation, PDT, or VEGF inhibitors.

## Limitations

Our evidence review has some limitations. We included previously published systematic reviews. The reliability of systematic reviews depends on how well they are designed and conducted. We therefore only included systematic reviews meeting a quality threshold based on predefined criteria.153 In addition, we previously verified data abstraction of the systematic reviews by independently abstracting and rating the quality of trials comparing an intervention to placebo, sham treatment, or no treatment. Conclusions were based on the totality of evidence (i.e., evidence reviewed in the prior USPSTF review plus new evidence). Second, we excluded non-English–language studies, which could introduce language bias. However, we identified no relevant non-English–language studies in literature searches or when searching reference lists, and some research has found that exclusion of non-English–language studies has little effect on conclusions of review of noncomplementary and alternative therapies.154 Third, when randomized trials were available, they were too few in number to perform assessments for publication bias.

## Emerging Issues/Next Steps

New therapies are being investigated for their effectiveness in the treatment of AMD. The small (n=114) Age-related Maculopathy Statin Study (ARMSS) trial of simvastatin 40 mg/day versus placebo found that simvastatin was associated with lower risk of AMD progression after 3 years of followup, although the difference was not statistically significant (54.4% vs. 70.2%; RR, 0.78 [95% CI, 0.58 to 1.04]).155 Complement inhibitors (e.g., protease inhibitors) are also being investigated for their potential effects on AMD.156

## Relevance for Priority Populations

The focus of this review was on screening in older adults, a priority population at particular risk for impaired visual acuity as well as sequelae from impaired visual acuity. Although black men are at higher risk of unoperated cataracts, there is no evidence to suggest that cataract surgery is less successful in this patient group. Low socioeconomic status is associated with poorer access to vision services.

## Future Research

Important gaps remain in the evidence on screening for impaired visual acuity in older adults. There is no direct evidence showing that vision screening in older adults is effective for improving visual outcomes or other clinical outcomes. Well-designed studies in primary care settings are needed to identify optimal methods for vision screening, identify potential subgroups within older populations for targeted screening, define appropriate screening intervals, and develop effective strategies for linking older adults with vision impairment to appropriate care. Screening strategies targeted at identification of AMD may be particularly suitable for future studies, given the potential for irreversible effects with delayed diagnosis. Studies are needed on diagnostic accuracy and utility of funduscopic examination, pinhole testing, the Amsler grid, and nonSnellen visual acuity charts in primary care settings for supplementing or replacing the Snellen visual eye chart. Research would also be helpful for determining the feasibility and accuracy of alternative screening modalities to supplement standard visual acuity testing in primary care settings, such as tests for dark adaptation, visual contrast, or useful field of view. Evidence on effectiveness of antioxidants and vitamins for the treatment of dry AMD remains largely dependent on a single large trial reporting a posthoc subgroup analysis97 and would be strengthened by similar findings from other, well-designed trials that are also designed to adequately evaluate potential harms associated with components of the supplements, such as congestive heart failure and lung cancer risk. Trials to determine the comparative effectiveness of treatments for wet AMD, and the effectiveness of combinations of treatments, would help clarify optimal therapy. More studies are needed to understand the potential association between correction of refractive errors and risk of falls,72 and, if an association is present, to identify methods for mitigating these risks (e.g., avoid large corrections in visual acuity, education or training with multifocal lens), and to better understand the association between improved visual acuity and vision-related quality of life with improved function.

## Conclusions

Impaired visual acuity is common in older adults, effective treatments are available for common causes of impaired visual acuity, and vision impairment can be identified noninvasively using the Snellen or other visual acuity chart. However, direct evidence found no significant difference between vision screening in older adults in primary care settings versus no screening for improving visual acuity or other clinical outcomes.