# Results

## Key Question 1 Does Vision Screening in Asymptomatic Older Adults Result in Improved Vision, Morbidity or Mortality, Quality of Life, Functional Status, or Cognition?

### Summary

Three cluster-randomized trials included in the prior USPSTF review found no difference between vision screening versus no vision screening, usual care, or delayed screening on vision and other clinical outcomes. One trial included in the prior USPSTF review found that vision screening by an optometrist in frail elderly persons was associated with an increased risk for falls (rate ratio, 1.57 [95% CI, 1.20 to 2.05]) and a trend toward increased risk for fractures (relative risk [RR], 1.74 [95% CI, 0.97 to 3.11]). No study published since the prior review evaluated the effects of vision screening in asymptomatic older adults versus no vision screening, usual care, or delayed screening.

### Evidence

We identified no study published since the prior USPSTF review that evaluated the effects of vision screening in asymptomatic older adults versus no screening, delayed screening, or usual care on visual acuity, morbidity, mortality, quality of life, functional status, or cognition. The prior USPSTF review included three fair- to good-quality cluster-randomized trials (n=4,728) performed in primary care–applicable settings of vision screening in older adults as part of a multicomponent screening intervention (Appendix B1).69–71 One trial compared universal visual acuity testing (Glasgow acuity chart followed by pinhole testing for persons with visual acuity worse than 20/60) versus targeted screening based on a brief screening questionnaire,71 one compared immediate versus delayed vision screening,69 and one compared use of a screening question followed by visual acuity testing, if positive, versus usual care.70 Three trials were conducted in community or general practice settings,69–71 while one study that did not meet inclusion criteria for the present review was conducted in an optometry clinic.72 Duration of followup ranged from 6 months to 5 years. None of the trials found beneficial effects on visual acuity, likelihood of vision disorders, or functional impairment related to vision with vision screening. In the highest-quality and largest (n=3,346) trial, universal vision screening identified about 10 times as many patients with impaired visual acuity and correctable impairment as did targeted screening, yet there was no difference in likelihood of visual acuity worse than 20/60 after 3- to 5-year followup (RR, 1.07 [95% CI, 0.84 to 1.36]).71 In this trial, only half of the patients advised to see an eye care provider after vision screening actually received new glasses, which could have attenuated potential benefits. Other reasons for lack of benefit in the screening trials may include the high loss to followup in all trials, similar frequency of vision disorder detection and treatment in the screening and control groups in one trial,70 use of a screening question to identify persons for further testing in one trial,70 and low uptake of recommended interventions in one trial.69

A fourth, fair-quality trial included in the prior USPSTF review did not meet inclusion criteria for this update because it involved vision screening by an optometrist (visual acuity, contrast sensitivity, and visual field testing; slit lamp examination; and direct ophthalmoscopy).72 It found that in frail older adults (n=309), vision screening was not associated with reduced risk of falls (rate ratio, 1.57 [95% CI, 1.20 to 2.05]) or fractures (RR, 1.74 [95% CI, 0.97 to 3.11]) after 1 year compared with usual care. Rather, an opposite effect was observed: screening led to new eyeglasses or referral for further treatment in about half (146 of 309 [47%]) of study participants. A subsequent report of this same study also found no difference between groups in improvement in vision or vision-related quality of life after 1 year.73

## Key Question 2 Are There Harms Associated With Vision Screening in Asymptomatic Older Adults?

### Summary

No study published since the prior USPSTF review addressed harms of vision screening in asymptomatic older adults. See Key Question 1 for evidence on falls.

### Evidence

No study published since the prior USPSTF review addressed harms of vision screening in asymptomatic older adults. As described above in Key Question 1, the prior review included one trial that reported an increased risk of falls and a trend toward increased risk of fractures among frail older adults who underwent vision screening by an optometrist versus usual care.72 No study included in the prior USPSTF review evaluated other harms such as anxiety, complications of treatment, or unnecessary interventions resulting from false-positive screening tests.

## Key Question 3 What Is the Accuracy of Screening for Early Impairment in Visual Acuity Due to Uncorrected Refractive Error, Cataracts, or AMD?

### Summary

The prior USPSTF review included four studies that found that screening questions or questionnaires are not accurate for identifying persons with impaired visual acuity compared with the Snellen eye chart, and four studies that found that visual acuity testing is not accurate for identifying the presence of vision conditions compared with a detailed ophthalmologic examination. Two studies published subsequent to the prior USPSTF review found that a computerized vision screening tool or a flipchart version were not accurate compared with a detailed eye examination (sensitivity, 0.80; specificity, 0.68) and one study found that the Minimum Data Set 2.0 (MDS) Vision Patterns section was associated with poor diagnostic accuracy compared with an eye chart examination.

### Evidence

The prior review identified eight cross-sectional studies that evaluated the diagnostic accuracy of screening for impaired visual acuity in older adults (Appendix B2, B3).74–81 Four studies assessed the diagnostic accuracy of screening questions or questionnaires, with none reporting both high sensitivity and specificity compared to a standard (Snellen) eye chart as the reference standard.75,76,79,80 Positive likelihood ratios (PLRs) ranged from 1.19 to 3.23 and negative likelihood ratios (NLRs) ranged from 0.23 to 0.78; diagnostic odds ratios (DORs), the ratio of the odds of testing positive if the subject has the target condition to the odds of testing positive if the subject does not have the target condition ([true positives/false negatives]/[false positives/true negatives]), were similarly weak, ranging from 1.60 to 9.45. Four studies reported low diagnostic accuracy of visual acuity tests compared to complete examination by an ophthalmologist for identifying visual conditions.74,77,80,81 However, interpretation of diagnostic accuracy based on this reference standard is a challenge because the clinical significance of visual conditions not necessarily associated with impaired visual acuity was unclear. No visual acuity test was associated with both high sensitivity and specificity; resulting PLRs ranged from 1.00 to 8.07 and NLRs ranged from 0.32 to 1.00, resulting in DORs of less than 10. The exception was one study, which found that presenting distance acuity of 20/40 or worse was associated with a DOR of 18.9 (95% CI, 13.64 to 26.26) for identifying any visual condition.81 However, three other studies74,77,80 found the same distance acuity threshold was associated with weaker DORs of 2.47 (95% CI, 2.08 to 2.94)77 to 4.40 (95% CI, 2.69 to 7.18).74 Two studies reported areas under the receiver operating characteristic curve of 0.66 and 0.83 for various tests of visual acuity.74,77 One study reported diagnostic accuracy of visual acuity testing specifically for identifying cataracts or early AMD, with results similar to those for identifying any visual condition.77 No study compared the Snellen test to an established, clinically relevant reference standard for impaired visual acuity, possibly because the Snellen test is often considered the clinical standard for evaluating visual acuity. One study assessed the Amsler grid and reported poor accuracy for identifying visual conditions (PLR, 1.65; NLR, 0.91).74 One study reported that 100 percent of cataract patients and 75 percent of AMD patients were correctly identified by a geriatrician compared to an ophthalmologist, with no false positives.78

Three fair-quality, cross-sectional studies (reported in two publications) published subsequent to the prior review evaluated the diagnostic accuracy of screening tests in primary care settings for impaired visual acuity in older adults (Table 3, Appendix C1, C2).82,83 Sample sizes ranged from 189 to 371 patients. A methodological shortcoming in all of these studies was uncertainty whether the reference standard was interpreted independently from the target test. In addition, the studies did not use predefined thresholds for positive results.

Table 3 Studies of Diagnostic Accuracy Published Since the Prior USPSTF Review

Study, Year | Study design | Sample size | Reference standard | Target vision condition | Screening test | Sensitivity (95% CI) | Specificity (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Diagnostic odds ratio
Jessa, 2012^82^ Study 1 | Cross-sectional | 180 | “Gold standard eye exam,” including computerized high-contrast visual acuity and low-contrast visual acuity tests | Any ocular disease | High contrast visual acuity >0.19 logMAR or abnormal near visual acuity | 0.80 (0.72 to 0.86) | 0.68 (0.57 to 0.77) | 2.48 (1.76 to 3.49) | 0.29 (0.20 to 0.45) | 8.55
Jessa, 2012^82^ Study 2 | Cross-sectional | 200 | “Gold standard eye exam,” including computerized high-contrast visual acuity and low-contrast visual acuity tests | Any ocular disease | A: High contrast visual acuity >0.9 logMAR or abnormal near visual acuity B: Low contrast visual acuity >0.49 logMAR | A: 0.75 (0.67 to 0.82) B: 0.75 (0.67 to 0.82) | A: 0.69 (0.58 to 0.78) B: 0.77 (0.66 to 0.85) | A: 2.45 (1.78 to 3.36) B: 3.26 (2.24 to 4.76) | A: 0.36 (0.25 to 0.51) B: 0.32 (0.22 to 0.46) | A: 6.81 B: 10.3
Swanson, 2009^83^ | Cross-sectional | 371 | ETDRS chart | Any ocular disease | MDS Vision Patterns section score >0 (adequate) | 0.52 (0.45 to 0.59) | 0.75 (0.68 to 0.82) | 2.11 (1.56 to 2.86) | 0.64 (0.54 to 0.75) | 3.30

Abbreviations: CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; logMAR = logarithm of the minimum angle of resolution; MDS = Minimum Data Set.

Two studies evaluated a computerized vision screening tool (Computer Vision Screen), and one of the studies also evaluated a flipchart version of the tool.82 The original version of the screening tool included questions on history and symptoms as well as six tests of vision function (near visual acuity, visual field, fixation disparity, stereoacuity, high contrast distance visual acuity, and low contrast distance visual acuity); two items (fixation disparity and stereoacuity) were subsequently dropped due to poor performance. The studies (n=180 and n=200) were conducted in the United Kingdom among community-recruited participants age 65 years or older (mean age, 77 to 80 years), of which about 30 percent had cataracts, 30 to 39 percent had significant refractive error, 51 to 58 percent had correctable visual loss, and 22 to 29 percent had significant macular degeneration. Results for the computerized screening tool were combined across the two studies. Individual component items and various combinations were assessed for optimal sensitivity and specificity against a “gold standard eye exam” that included detailed history and symptoms, slit lamp and dilated funduscopic examination, tests of visual acuity, visual field, orthoptic tests, and others. Optimal sensitivity (0.80) and specificity (0.68) were observed with the combination of abnormal high contrast visual acuity (threshold >0.19 logMAR) or abnormal near visual acuity, resulting in a PLR of 2.5 and a NLR of 0.29 (DOR, 8.6). The flipchart instrument performed similarly, based on the low contrast visual acuity test alone (sensitivity, 0.75; specificity, 0.77; PLR, 3.26; NLR, 0.32; DOR, 10.2).

A third study (n=371) compared the scores on the MDS Vision Patterns section against a standard visual acuity (Early Treatment Diabetic Retinopathy Study [ETDRS] chart) test for detecting impaired visual acuity.83 Participants age 55 years or older (mean age, 80.7 years) were recruited from nursing homes and assessed by trained research staff (not further described). The prevalence of impaired visual acuity was about 40 percent, mean near visual acuity was 0.56 in the better eye and 0.81 in the worse eye, and mean distance visual acuity was 0.43 in the better eye and 0.64 in the worse eye. The MDS Visual Patterns section is scored from 0 to 4, with 0 indicating adequate vision and 4 severely impaired vision. Diagnostic accuracy was poor using any cutoff score on the MDS Visual Patterns. Using a cutoff score of 1 or greater (0 indicating adequate vision and scores of 1 to 3 indicating various degrees of impairment), sensitivity of the MDS Visual Patterns section for detecting visual acuity worse than 20/40 was 0.52 and specificity was 0.75, resulting in a PLR of 2.11 and a NLR of 0.64.

## Key Question 4 Does Treatment of Early Impairment in Visual Acuity Due to Uncorrected Refractive Error, Cataracts, or AMD Lead to Improved Morbidity or Mortality or Quality of Life?

### Summary

For uncorrected refractive error and cataracts, the prior USPSTF review found evidence from a large body of observational data and accumulated clinical experience that refractive lenses and refractive surgery are highly effective at restoring normal or near-normal visual acuity. For mild uncorrected refractive errors, the prior USPSTF review included two randomized trials of corrective lenses that reported beneficial effects on vision-related quality of life but not functional status. We identified no new randomized trial or controlled observational study on treatment versus no treatment for mild uncorrected refractive errors.

For cataracts, the prior USPSTF review found evidence from observational studies that more than 90 percent of patients undergoing cataract surgery achieve visual acuity of 20/40 or better, and one trial found that immediate cataract surgery was associated with decreased risk of falls (rate ratio, 0.66 [95% CI, 0.40 to 0.96]). Two cohort studies of cataract surgery versus no cataract surgery that were not included in the prior USPSTF review found no effects on cognitive function or quality of life, though visual acuity was improved following cataract surgery in both studies.

For dry AMD, the prior USPSTF review included one large randomized trial, the Age-Related Eye Disease Study (AREDS), which found that an antioxidant and zinc combination was effective for lower likelihood of AMD progression (adjusted odds ratio [OR], 0.66 [95% CI, 0.47 to 0.93]), although the difference in the likelihood of losing 15 letters or more of visual acuity was not statistically significant (adjusted OR, 0.75 [95% CI, 0.55 to 1.02]) after 6 years of followup. Ten-year followup results from AREDS are consistent with prior results, with antioxidant supplements alone (OR, 0.70 [95% CI, 0.56 to 0.88]) or with added zinc (OR, 0.66 [95% CI, 0.53 to 0.83]) associated with decreased risk of AMD progression and the combination associated with decreased risk of visual acuity loss (OR, 0.71 [95% CI, 0.57 to 0.88]). Evidence on the effects of other vitamins and mineral treatments remains limited, with no clear effects on AMD progression or visual acuity.

For wet AMD, the prior USPSTF review included systematic reviews that found laser photocoagulation to be associated with lower likelihood of losing 6 lines or more of visual acuity versus placebo (five trials; RR, 0.67 [95% CI, 0.53 to 0.83]) and PDT was associated with lower likelihood of losing 3 lines or more of visual acuity versus placebo (four trials; RR, 0.80 [95% CI, 0.73 to 0.88]). We identified no trials of laser photocoagulation or PDT published since the prior USPSTF review.

The prior USPSTF review included four trials of intravitreal injection with VEGF inhibitors versus sham therapy; an updated meta-analysis based on these trials found that VEGF inhibitors were associated with greater likelihood of gaining 15 letters or more of visual acuity (RR, 2.92 [95% CI, 1.20 to 7.12]) and greater likelihood of having vision of 20/200 or better versus sham injection (RR, 1.47 [95% CI, 1.30 to 1.66]); beneficial effects were also observed in one trial with 2 years of followup. One trial each found that intravitreal injection with VEGF inhibitors was associated with small improvements in vision-related function and likelihood of driving among participants driving at baseline.

### Evidence

#### Uncorrected Refractive Error

We identified no new randomized trial or controlled observational study on effects of treatment versus no treatment for mild impaired visual acuity on vision, vision-related quality of life, or function. The prior USPSTF review found good evidence from a large body of observational data and accumulated clinical experience that corrective lenses are highly effective at restoring normal or near-normal visual acuity. For mild uncorrected refractive errors, the prior USPSTF review included two randomized trials on the effects of immediate versus delayed corrective lenses (Appendix B4).84,85 One trial provided a prescription and voucher for free eyeglasses,84 while the other trial directly provided prescription glasses.85 In one trial of community-dwelling adults age 65 years or older,84 mean baseline visual acuity was 20/63; in the other trial,85 which evaluated nursing home patients age 55 years or older, about 30 percent were moderately myopic (−0.50 to −2.00 D), 30 percent were moderately hyperopic (+0.50 to +2.00 D), and about 25 percent had minimum impaired visual acuity (−0.50 to +0.50 D). Both trials reported improvements in vision-related quality of life in patients with immediate eyeglasses versus delayed treatment, and one of the trials85 reported improvements in depressive symptoms. However, few differences in measures of general functional status or quality of life were found. A report from one of these studies85 published subsequent to the USPSTF review also found no effects on function or cognitive status as measured by the Functional Independence Measure, Survey of Activities and Fear of Falling, Nursing Home Life-Space Diameter, and the Mini-Mental State Examination (Appendix C3).86

The prior review also included a large systematic review87 of 27 randomized trials and 130 observational studies that found refractive surgery to be highly effective at improving refractive error (92% to 94% of persons with myopia and 86% to 96% with hyperopia achieved visual acuity of 20/40 or better) (Appendix B5), and three observational studies that found refractive surgery to be associated with improved quality of life.88–90

#### Cataracts

The prior USPSTF review identified no trials of cataract surgery versus no surgery, but included one systematic review of observational studies that found cataract surgery to be associated with improved visual acuity of 20/40 or better in more than 90 percent of patients and in 89 percent of all eyes (n=17,390) (Appendix B6).91 One trial found that immediate cataract surgery was associated with a decreased risk of a second (but not first) fall, resulting in a lower overall risk of falls (rate ratio, 0.66 [95% CI, 0.40 to 0.96]).92 Another trial found no effect of immediate second-eye surgery on risk of falls or fracture risk.93 One trial of antioxidant vitamins versus placebo found no difference in risk of progression of cataract opacities (Appendix B7).94

Two fair-quality prospective cohort studies published since the prior USPSTF review assessed the effects of cataract surgery versus no surgery on measures of function or quality of life (Appendix C3, C4).86,95 One study (n=45) conducted in U.S. nursing home patients age 55 years or older found no differences between cataract surgery and no surgery in measures of function and cognition after 4 months of followup, based on the Functional Independence Measure, Survey of Activities and Fear of Falling, Nursing Home Life-Space Diameter, and the Mini-Mental State Examination, despite improvement in visual acuity (distance acuity of 0.74 logMAR at baseline vs. 0.25 logMAR after surgery).86 An earlier report from this study reported no differences on the Short Form-36, the Geriatric Depression Scale, or the Cataract Symptom Score, though cataract surgery was associated with improvements in vision-targeted health-related quality of life as measured by the Nursing Home Vision-Targeted Health-Related Questionnaire and the VF-14 (improvement on the VF-14 of 24.9 points following cataract surgery vs. 1.5 points without cataract surgery; p=0.004 after adjustment for age).96 Another study (n=301) conducted in U.S. ophthalmology clinics among cataract patients age 55 years or older found no differences between cataract surgery versus no surgery in cognitive function (based on the Mattis Organic Mental Syndrome Screening Examination), though both groups improved from baseline.95 There was also no effect of cataract surgery on depression (based on the Center for Epidemiological Studies Depression Scale). Visual acuity improved following cataract surgery (visual acuity in worse eye of 0.55 logMAR at baseline vs. 0.28 logMAR after surgery), with no change in the no surgery group. Methodological shortcomings in the studies included lack of blinding of outcomes assessors and baseline differences in age, sex, comorbid conditions, and visual acuity. One study did not attempt to adjust for potential confounders.86

#### Dry (Nonexudative) AMD

##### Antioxidant Vitamins and Minerals and Other Supplements

The prior USPSTF review1 included results from the large, good-quality AREDS97 trial and a good-quality systematic review of nine trials (total n=5,769) of antioxidant supplements (Appendix B8, B9).98 Since publication of the prior review, longer followup from the AREDS trial99 and an updated version of the antioxidant systematic review,100 with four additional trials (total n=6,510),101–104 has been published. We also identified three other recently published, placebo-controlled trials105–107 not included in the systematic review.

The sample sizes of trials included in the updated systematic review of antioxidant supplements versus placebo or no intervention ranged from 20 to 400 in 11 trials; two other trials (AREDS and the Vitamin E, Cataract, and Age-related Maculopathy[VECAT] Study) enrolled larger samples (n=2,556 and 1,204) (Appendix C5, C6). The interventions evaluated were zinc (five trials), lutein (two trials), vitamin E (one trial), antioxidant combination (four trials), or multiple interventions (one trial). Mean age ranged from 65 to 75 years (in 11 trials; two trials did not report mean age) and the proportion of females from 4 to 80 percent. Best-corrected visual acuity at baseline ranged from near-normal, 20/23 (0.073 logMAR), to 20/80 (0.60 logMAR). Mean duration of followup ranged from 6 months to 7 years. Quality of studies included in the systematic review was assessed using Cochrane Collaboration risk of bias criteria,108 which included assessment of method of randomization, allocation concealment, blinding, and attrition. Most studies were judged to have low risk of bias (i.e., good quality), including the two largest studies, AREDS and VECAT.100 In AREDS, the largest trial, participants were randomized to a daily antioxidant supplement containing vitamin C, E, and beta carotene, zinc, a combination of antioxidant supplement, and zinc or placebo. Nearly half of AREDS participants were age 70 years or older at baseline, 56 percent were women, and 96 percent were white. More than half were either current (8%) or former (48%) smokers. Participants were categorized according to baseline AMD severity, ranging from Category 1 (no existing AMD and <5 drusen) to Category 4 (advanced AMD with central geographic atrophy or neovascular AMD). Patients were required to have baseline best-corrected visual acuity of 20/32 (0.20 logMAR) or better. Followup from AREDS is now available through 10 years (Appendix C7).99

The three new trials not included in the systematic review105–107 enrolled smaller samples than AREDS (n=84 to 300) and had shorter duration of followup (48 weeks to 3 years) (Appendix C7). Two studies evaluated lutein, either alone105 or in combination with zeaxanthin,106 while the third evaluated fish oil supplementation (containing 840 mg docosahexaenoic acid, 270 mg eicosapentaenoic acid, and 2 mg vitamin E).107 Mean age of participants ranged from 69 to 74 years, and more than half were female (56% to 69%). The studies were conducted in China,106 the United Kingdom,105 and France.107 Mean best-corrected visual acuity at baseline ranged from 20/22 to 20/40 (0.05 to 0.30 logMAR). All three trials were rated good quality (Appendix C8).

Mortality. Two trials reported effects of vitamins and minerals on mortality (Table 4).99,107 Mortality outcomes were reported for AREDS severity categories 2, 3, and 4. After 10-years followup, AREDS found no significant difference between antioxidant use versus nonuse in risk of all-cause mortality (hazard ratio [HR], 1.06 [95% CI, 0.93 to 1.21]), cardiovascular mortality (RR, 1.20 [95% CI, 0.97 to 1.49]), or cancer mortality (RR, 0.94 [95% CI, 0.74 to 1.20]) after adjustment for age, sex, race, education, smoking status, body mass index, diabetes, angina, cancer, and hypertension.99 However, for zinc use versus nonuse, there was a significant reduction in risk of all-cause (adjusted HR, 0.83 [95% CI, 0.73 to 0.95]) and cardiovascular mortality (adjusted RR, 0.80 [95% CI, 0.64 to 0.99]), though effects on cancer mortality were not statistically significant (adjusted RR, 0.84 [95% CI, 0.65 to 1.08]). In the second trial (n=300), daily fish oil was not associated with a statistically significant decrease in mortality risk versus placebo, though the estimate was imprecise and favored the intervention (2.2% [3/134] vs. 4.7% [6/129]; RR, 0.48 [95% CI, 0.12 to 1.88]).107

Table 4 Studies of Antioxidant Vitamins, Minerals, and Other Supplements Published Since the Prior USPSTF Review

Author, year Study n Duration of followup Quality | Interventions | Population | Vision-Related Outcomes | Other Outcomes | Adverse Events
Chew, 2013^99^ AREDS (Report #35) n=2,459, focusing on AREDS categories 3 and 4 for vision-related outcomes; 3,476 for categories 2, 3, and 4; total sample 4,753 10 years Good | A. Antioxidant supplement (vitamin C 500 mg + vitamin E 400 IU + beta-carotene, 15 mg/day) B. Zinc 80 mg/day C. Antioxidant supplement + zinc D. Placebo | A vs. B vs. C vs. D^*^ Median age: 69 vs. 70 vs. 69 vs. 69 years Sex: 55% vs. 57% vs. 56% vs. 56% female Race: 97% vs. 96% vs. 97% vs. 96% white 2% vs. 3% vs. 3% vs. 4% black 1% vs. 1% vs. <1% vs. <1% other AMD category: 2: 28% vs. 30% vs. 28% vs. 30% 3: 40% vs. 41% vs. 42% vs. 40% 4: 24% vs. 22% vs. 22% vs. 22% | A vs. D^†^ Loss of visual acuity of ≥15 letters: ETDRS: OR, 0.83 (95% CI, 0.67 to 1.02) Visual acuity of <20/100: OR, 0.82 (95% CI, 0.64 to 1.07) Progression to advanced AMD: OR, 0.70 (95% CI, 0.56 to 0.88) B vs. D^†^ Loss of visual acuity of ≥15 letters: ETDRS: OR, 0.86 (95% CI, 0.70 to 1.07) Visual acuity of <20/100: OR, 0.88 (95% CI, 0.69 to 1.14) Progression to advanced AMD: OR, 0.82 (95% CI, 0.66 to 1.02) C vs D^†^ Loss of visual acuity of ≥15 letters: ETDRS: OR, 0.71 (95% CI, 0.57 to 0.88) Visual acuity of <20/100: OR, 0.72 (95% CI, 0.56 to 0.94) Progression to advanced AMD: OR, 0.66 (95% CI, 0.53 to 0.83) | A + C (antioxidant) vs. B + D (no antioxidant)^‡^ All-cause mortality: 24.0% (439/1831) vs. 23.6% (427/1806); aHR^§^, 1.06 (95% CI, 0.93 to 1.21) CV mortality: aRR^§^, 1.20 (95% CI, 0.97 to 1.49) Cancer mortality: aRR, 1.07 (95% CI, 0.83 to 1.38) NonCV, noncancer mortality: aRR, 0.94 (95% CI, 0.74 to 1.20) B + C (zinc) vs. A + D (no zinc) All-cause mortality: 22.4% (401/1790) vs. 25.2% (465/1847); aHR, 0.83 (95% CI, 0.73 to 0.95) CV mortality: aRR, 0.80 (95% CI, 0.64 to 0.99) Cancer mortality: aRR, 0.84 (95% CI, 0.65 to 1.08) NonCV, noncancer mortality: aRR, 0.93 (95% CI, 0.73 to 1.18) | NR by treatment group; narrative report of no significant increase in incidence of hospitalization after adjustment for age, sex, smoking, and treatment group
Chew, 2009^112^ AREDS (Report #25) n=4,757 total Up to 11 years (mean duration NR) Good | A. Any AREDS active treatment B. Placebo | Same as above | A vs. B Incident cataract surgery: 25.4% (798/3137) vs. 25.2% (369/1440); RR, 1.01 (95% CI, 0.91 to 1.12) | NR | NR
Ma, 2012^106^ n=108 48 weeks Good | A. Lutein 10 mg/day B. Lutein 20 mg/day C. Lutein 10 mg/day + zeaxanthin 10 mg/day D. Placebo | A vs. B vs. C vs. D Mean age: 70 vs. 69 vs. 69 vs. 69 years Sex: 62% vs. 56% vs. 56% vs. 60% female Race: NR BCVA: 0.30 vs. 0.28 vs. 0.28 vs. 0.31 logMAR Smoking history: 89% vs. 89% vs. 85% vs. 89% nonsmoker | A vs. D BCVA, mean change from baseline: −0.04 (95% CI, −0.11 to 0.03) vs. 0.00 (95% CI, −0.06 to 0.05); p=NS B vs. D BCVA, mean change from baseline: −0.02 (95% CI, −0.11 to 0.06) vs. 0.00 (95% CI, −0.06 to 0.05); p=NS C vs. D BCVA, mean change from baseline: −0.04 (95% CI, −0.10 to 0.01) vs. 0.00 (95% CI, −0.06 to 0.05); p=NS | NR | NR by treatment group; narrative report of no adverse events related to interventions
Murray, 2013^105^ CLEAR n=84 1 year Good | A. Lutein 10 mg/day B. Placebo | A vs. B Mean age: 71.9 vs. 69.1 years Sex: 56% vs. 65% female Race: NR Visual acuity: 0.10 vs. 0.05 logMAR | A vs. B Visual acuity, mean change from baseline: 0.01 vs. −0.04; p<0.05 | NR | A vs. B Withdrawals due to adverse events: 7.1% (3/42) vs. 2.3% (1/42); RR, 3.00 (95% CI, 0.33 to 28)
Souied, 2013^107^ NAT2 n=300 3 years Good | A. Fish oil capsules (DHA 280 mg + EPA 90 mg + vitamin E 2 mg) 3x/day B. Placebo (olive oil 602 mg) | A vs. B Mean age: 74 vs. 73 years Sex: 69% vs. 61% female Race: NR Mean visual acuity in study eye: 0.14 vs. 0.12 logMAR Drusen: Absent: 0.7% vs. 0% <5: 0.7% vs. 2% 5–20: 17% vs. 22% >20: 81% vs. 76% Smoking history: Current: 7% vs. 9% Former: 14% vs. 17% Nonsmoker: 79% vs. 74% | A vs. B\|\| Visual acuity, mean change from baseline: 0.155 (SD, 0.297) vs. 0.116 (SD, 0.258); p=0.311 Loss of visual acuity, proportion of subjects with loss of >15 letters ETDRS: 17.8% (21/118) vs. 14.3% (16/112); RR, 1.25 (95% CI, 0.69 to 2.26) | A vs. B All-cause mortality: 2.2% (3/134) vs. 4.7% (6/129); RR, 0.48 (95% CI, 0.12 to 1.88) Any adverse event: 93.3% (125/134) vs. 89.1% (115/129); RR, 1.05 (95% CI, 0.97 to 1.13) Any serious adverse event: 31.3% (42/134) vs. 30.2% (39/129); RR, 1.04 (95% CI, 0.72 to 1.49) Serious ocular adverse event: 8.2% (11/134) vs. 7.0% (9/129); RR, 1.18 (95% CI, 0.50 to 2.75) Cataract development, worsening or need for cataract surgery: 50% (67/134) vs. 62.5% (81/129); RR, 0.80 (95% CI, 0.64 to 0.99) | A vs. B Any adverse event: 93.3% (125/134) vs. 89.1% (115/129); RR, 1.05 (95% CI, 0.97 to 1.13) Any serious adverse event: 31.3% (42/134) vs. 30.2% (39/129); RR, 1.04 (95% CI, 0.72 to 1.49) Treatment-related adverse event (investigator-determined): 3.7% (5/134) vs. 1.6% (2/129); RR, 2.41 (95% CI, 0.48 to 12) Serious ocular adverse event: 8.2% (11/134) vs. 7.0% (9/129); RR, 1.18 (95% CI, 0.50 to 2.75) Ocular adverse event: 65.7% (88/134) vs. 57.4% (74/129); RR, 1.14 (95% CI, 0.94 to 1.39) Cataract development, worsening or need for cataract surgery: 50% (67/134) vs. 62.5% (81/129); RR, 0.80 (95% CI, 0.64 to 0.99) Serious nonocular adverse event: 23.1% (31/134) vs. 23.2% (30/129); RR, 0.99 (95% CI, 0.64 to 1.54)

* Baseline characteristics for the original AREDS cohort.

† Results for participants with high risk of developing advanced AMD (AREDS Category 3 and 4).

‡ Results for participants with AMD (AREDS Category 2, 3, or 4).

§ Adjusted for age, sex, race, education, smoking status, body mass index, and presence of diabetes, angina, cancer, and hypertension.

|| 6-month, 1-year, and 2-year outcomes reported in Appendix.

Abbreviations: aHR = adjusted hazard ratio; AMD = age-related macular degeneration; AREDS = Age-Related Eye Disease Study; aRR = adjusted risk ratio; BCVA = best-corrected visual acuity; CI = confidence interval; CLEAR = Combination of Lutein Effects in the Aging Retina; CV = cardiovascular; EPA = eicosapentaenoic acid; ETDRS = Early Treatment Diabetic Retinopathy Study; logMAR = logarithm of the minimum angle of resolution; NAT2 = Nutritional AMD Treatment 2; NS = not significant; NR = not reported; OR = odds ratio; RR = relative risk; SD = standard deviation; USPSTF = U.S. Preventive Services Task Force.

AMD progression and changes in visual acuity. The prior USPSTF review1 included 6-year results from AREDS, which found a daily combined antioxidant supplement to be associated with reduced risk of AMD progression versus placebo (adjusted OR, 0.66 [99% CI, 0.47 to 0.93]).97 Visual acuity outcomes were reported for the subgroup of patients in whom treatment is currently recommended (AREDS severity categories 3 and 4). Ten-year followup from AREDS reported similar results for antioxidant supplements alone (OR, 0.70 [95% CI, 0.56 to 0.88]) or with added zinc (OR, 0.66 [95% CI, 0.53 to 0.83]) (Table 4).99 For zinc alone, results favored treatment, but the difference was not statistically significant (OR, 0.82 [95% CI, 0.66 to 1.02]).

Although the systematic review100 included three other trials that reported effects of antioxidants or vitamins on risk of AMD progression, results were not pooled because of high statistical heterogeneity and none of the trials were new since publication of the prior USPSTF review (Appendix C5, C6). No statistically significant effects were observed in any of the trials; two small trials (n=58 and 78) evaluated zinc alone (OR, 0.50 [95% CI, 0.05 to 4.79]109 and 2.31 [95% CI, 0.58 to 9.26]),110 and one larger trial (n=1,179) evaluated vitamin E alone (OR, 1.11 [95% CI, 0.80 to 1.55]).111

The prior USPSTF review included 6-year results from AREDS, which found that use of an antioxidant supplement was associated with a nonstatistically significant reduction in risk of loss of 15 letters or more of visual acuity versus placebo (adjusted OR, 0.75 [95% CI, 0.55 to 1.02]).97 At 10-year followup, the combination of antioxidants plus zinc was associated with decreased risk of visual acuity loss (OR, 0.71 [95% CI, 0.57 to 0.88]) (Table 4); effects of an antioxidant alone or zinc alone were similar but remained statistically nonsignificant.99 One trial (n=300) published subsequent to the prior USPSTF review found no difference between supplementation with fish oil capsules versus placebo in risk of visual acuity loss of 15 letters or more after 3 years (RR, 1.25 [95% CI, 0.69 to 2.26]).107

Two trials published since the prior USPSTF review evaluated effects of lutein with and without zeaxanthin on visual acuity.105,106 In one trial (n=108), there was no difference between daily use of lutein or lutein plus zeaxanthin versus placebo in mean change in visual acuity from baseline after 48 weeks of followup (Table 4).106 In the second trial (n=84), daily use of lutein was associated with very small effects on visual acuity, with no clear difference versus placebo (0.01 logMAR improvement vs. −0.04 logMAR decline).105

Other outcomes. Long-term followup of AREDS participants at risk of developing advanced AMD found no significant difference in need for cataract surgery in participants taking any active AREDS intervention compared with placebo (RR, 1.01 [95% CI, 0.91 to 1.12]) (Table 4).112 Another trial found that a daily fish oil supplement was associated with a marginally significant decrease in risk of developing cataracts, worsening cataract, or need for cataract surgery (RR, 0.80 [95% CI, 0.64 to 0.99]).107

#### Wet (Exudative) AMD

##### Laser Photocoagulation

The prior USPSTF review1 included a good-quality Cochrane systematic review on the effects of laser photocoagulation versus no photocoagulation (12 trials; n=1,932) (Appendix B8).113 We identified no new studies published since the prior USPSTF review comparing laser photocoagulation with no treatment.

The trials included in the systematic review compared either direct or grid laser photocoagulation versus no treatment. Enrollees were age 50 years and older, with a mean age of 70 to 74 years in three trials. In nine studies that reported sex, 50 to 77 percent were female. Mean baseline visual acuity ranged from 20/40 to 20/200 or better (0.03 to 1.00 logMAR), and the location of choroidal neovascularization associated with AMD (foveal, juxtafoveal, or extrafoveal) varied. Duration of followup ranged from 2 months to 5 years. The trials had methodological shortcomings, including use of open-label design, incomplete followup, lack of intention-to-treat analysis, and others.1

AMD progression and changes in visual acuity. Pooled estimates from the Cochrane review113 found that laser photocoagulation was more effective than no treatment at preventing loss of 6 lines or more of visual acuity at 2-year followup (five trials; RR, 0.67 [95% CI, 0.53 to 0.83]; I^2^=58%) (Appendix B8).1 After 3- and 5-year followup, participants receiving laser photocoagulation were more likely to have visual acuity of 20/200 or better versus those who received no treatment (three trials; RR, 0.73 [95% CI, 0.61 to 0.86]; I^2^=43%; and two trials; RR, 0.77 [95% CI, 0.66 to 0.90]; I^2^=21%).

Other outcomes, including mortality, were not reported.

##### PDT

The prior USPSTF review1 included a good-quality Cochrane systematic review of PDT for wet AMD (Appendix B8).114 Though the Cochrane review was updated in 2009, no new trials were identified. We also identified no additional trials published since the prior USPSTF review.

The 2007 Cochrane systematic review included four trials (n=117 to 609; total n=1,210) of PDT with verteporfin versus placebo. This included the large Treatment of Age-Related Macular Degeneration with Photodynamic Therapy (TAP) trial,115 which accounted for slightly less than half (n=609) of the total population included in the systematic review. TAP and two other trials, the Visudyne in Minimally Classic (VIM)116 and Visudyne in Occult (VIO)117 Choroidal Neovascularization trials, enrolled similar populations; mean age ranged from 75 to 79 years, 56 to 64 percent were female, and baseline visual acuity was about 20/80. The fourth trial, the Verteporfin in Photodynamic Therapy (VIP) trial,118 enrolled a younger population (mean age, 49 years; 67% female) with slightly better visual acuity at baseline (20/64). Study duration in all trials was 2 years.

Mortality. The prior review found no difference between PDT with verteporfin versus placebo in risk of all-cause mortality, based on the TAP (3% vs. 4%; RR, 0.84 [95% CI, 0.35 to 1.99]) and VIP (2% vs. 3%; RR, 0.68 [95% CI, 0.15 to 2.97]) trials.115,118 The VIM trial119 reported no deaths in either the PDT or placebo group after 2-year followup.

AMD progression and changes in visual acuity. The systematic review found that PDT with verteporfin was associated with lower likelihood of losing 3 lines or more of visual acuity at 12-month (four trials; RR, 0.80 [95% CI, 0.69 to 0.93]; I^2^=30%) and 24-month (four trials; RR, 0.80 [95% CI, 0.73 to 0.88]; I^2^=0%) followup versus placebo (Appendix B8).114 Patients undergoing PDT were also more likely to gain 3 lines or more of visual acuity at 12-month (three trials; RR, 2.19 [95% CI, 0.99 to 4.82]; I^2^=0%) and 24-month followup (three trials; RR, 2.55 [95% CI, 1.31 to 4.99]; I^2^=0%).

##### VEGF Inhibitors

The prior USPSTF review included a good-quality Cochrane systematic review120 on the effectiveness of intravitreal injection with VEGF inhibitors, though only three trials (the Minimally Classic/Occult Trial of the Anti-VEGF Antibody Ranibizumab in the Treatment of Neovascular Age-Related Macular Degeneration [MARINA] trial121 and two VEGF Inhibition Study in Ocular Neovascularization [VISION] trials, reported in one publication122; total n=1,906) compared VEGF inhibitors versus sham (Appendix B8). The prior USPSTF review included one additional trial (the Phase IIIB, multicenter, randomized double-masked sham Injection-controlled study of the Efficacy and safety of Ranibizumab [PIER] trial) (Appendix B9).123 The systematic review was updated in 2014 to include results from the PIER trial; no other new trials of VEGF inhibitors versus sham or placebo were added.124 Pooled estimates from the 2014 Cochrane review are of limited utility for our review, as many analyses included results from a trial125 comparing VEGF inhibitors to PDT. Our literature search identified additional long-term followup from the MARINA trial (n=716) (Appendix C9).126

The four trials121–123 of VEGF inhibitors versus sham injection (MARINA, PIER, and the VISION trials) enrolled 184 to 716 participants; 50 to 65 percent were female (Table 5). Mean age was 77 and 79 years in two studies, while in the other two studies, 62 percent of the population was older than age 75 years. Baseline visual acuity was about 20/80 in three studies, while in the fourth study, 72 percent of the population had baseline visual acuity between 20/40 and 20/200. The MARINA and PIER trials evaluated ranibizumab 0.3 to 0.5 mg every 1 to 3 months or sham injection,121,123 and the VISION trials evaluated pegaptanib (0.3 to 3.0 mg).122 For the PIER trial, we only included 1-year results, as the sham group was discontinued during the second year due to a study protocol change. All trials were rated good quality (Appendix C10).

Table 5 Studies of Vascular Endothelial Growth Factor Inhibitors for Age-Related Macular Degeneration

Trial name Author, year N Duration of followup Quality | Interventions | Population | Vision-Related Outcomes | Other Outcomes | Adverse Events
MARINA Rosenfeld, 2006^159^ n=716 2 years Good | A. Ranibizumab 0.3 to 0.5 mg every month (n=478) B. Sham injection (n=238) | A vs. B Mean age 77 vs. 77 years 64% vs. 67% female 96% vs. 97% white; 4% vs. 3% other Mean visual acuity 53.4 vs. 53.6 letters (approximately 20/80) | A vs. B^†^ Visual acuity, gain ≥15 letters: 29.2% (140/478) vs. 5.0% (12/238); RR, 5.81 (95% CI, 3.29 to 10.26) Visual acuity, loss <15 letters: 94.6% (452/478) vs. 62.2% (148/238); RR, 1.52 (95% CI, 1.37 to 1.68) Visual acuity, 20/200 or better: 88.1% (421/478) vs. 57.1% (136/238); RR, 1.54 (95% CI, 1.37 to 1.73) | A vs. B All-cause mortality: 2.3% (11/478) vs. 2.5% (6/238); RR, 0.91 (95% CI, 0.34 to 2.44) Vascular mortality: 1.3% (6/478) vs. 1.7% (4/236); RR, 0.74 (95% CI, 0.21 to 2.60) MI: 1.9% (9/478) vs. 1.7% (4/238); RR, 1.12 (95% CI, 0.35 to 3.60) CVA: 1.9% (9/478) vs. 0.8% (2/238); RR, 2.24 (95% CI, 0.49 to 10) | A vs. B Withdrawals: 13.2% (63/478) vs. 28.6% (68/238); RR, 0.46 (95% CI, 0.34 to 0.63) Withdrawals due to adverse events: 4.8% (23/478) vs. 5.5% (13/238); RR, 0.88 (95% CI, 0.45 to 1.70) Serious, nonocular hemorrhage: 1.7% (8/478) vs. 0.8% (2/236); RR, 1.97 (95% CI, 0.42 to 9.23) Endophthalmitis: 5/478 vs. 0/238; RR, 5.49 (95% CI, 0.30 to 99) Uveitis: 1.3% (6/478) vs. 0% (0/238); RR, 6.49 (95% CI, 0.37 to 115) Retinal detachment: 0% (0/478) vs. 0.4% (1/238); RR, 0.17 (95% CI, 0.01 to 4.07)
PIER Regillo, 2008^123^ n=184 1 year^*^ Good | A. Ranibizumab 0.3 to 0.5 mg every month for 3 months, followed by every 3 months up to 12 months (n=121) B. Sham injection (n=63) | A vs. B Mean age 79 vs. 78 years 55% vs. 68% female 93% vs. 94% white; 7% vs. 6% other Mean visual acuity 54.8 vs. 55.1 letters (approximately 20/80) | A vs. B Visual acuity, gain ≥15 letters: 12.4% (15/121) vs. 9.5% (6/63); RR, 1.30 (95% CI, 0.53 to 3.19) Visual acuity, loss <15 letters: 86.8% (105/121) vs. 49.2% (31/63); RR, 1.76 (95% CI, 1.36 to 2.29) Visual acuity, 20/200 or better: 73.6% (89/121) vs. 44.4% (28/63); RR, 1.65 (95% CI, 1.23 to 2.23) | A vs. B Mortality and CV events: No deaths, MI, or CVA in either group | A vs. B Withdrawals: 0.8% (1/121) vs. 0% (0/63); RR, 1.57 (95% CI, 0.07 to 38) Ocular hemorrhage: 1.6% (2/121) vs. 3.2% (2/63); RR, 0.52 (95% CI, 0.08 to 3.61) Macular edema: 0.8% (1/121) vs. 3.2% (2/63); RR, 0.26 (95% CI, 0.02 to 2.82)
VISION (2 trials; 1 publication) Gragoudas, 2004^122^ n=1,186 (Ns for individual trials were 586 and 622 prior to exclusions) 1 year Good | A. Pegaptanib 0.3 to 3.0 mg every 6 weeks (n=890) B Sham injection (n=296) | A vs. B Mean age not reported; 62% vs. 61% age ≥75 years 58% vs. 60% female 97% vs. 95% white; 3% vs. 5% other Mean visual acuity 51.5 vs. 52.7 letters | A vs. B Visual acuity, gain ≥15 letters: 5.7% (51/890) vs. 2.0% (6/296); RR, 2.83 (95% CI, 1.23 to 6.52) Visual acuity, loss <15 letters: 68.8% (612/890) vs. 55.4% (164/296); RR, 1.24 (95% CI, 1.11 to 1.39) Visual acuity, 20/200 or better: 58.7% (522/890) vs. 44.3% (131/296); RR, 1.33 (95% CI, 1.15 to 1.52) | Not reported | A vs. B Withdrawals due to adverse events: 1% (9/890) vs. 1% (3/296); RR, 1.00 (95% CI, 0.27 to 3.66) Endophthalmitis: 1.3% (12/890) vs. 0% (0/296); RR, 8.33 (95% CI, 0.50 to 140) Traumatic lens injury: 0.6% (5/890) vs. 0% (0/296); RR, 3.67 (95% CI, 0.20 to 66) Retinal detachment: 0.6% (5/890) vs. 0% (0/296); RR, 3.67 (95% CI, 0.20 to 66) Severe (>30 letters) vision loss: 0.1% (1/890) vs. 0% (0/296); RR, 1.00 (95% CI, 0.04 to 24)

* 2-year results available, but sham group was maintained during the second year.

† 1-year results; 2-year results for visual outcomes appear in Appendix.

Abbreviations: CI = confidence interval; CV = cardiovascular; CVA = cerebrovascular accident; MARINA = Minimally Classic/Occult Trial of the Anti-VEGF Antibody Ranibizumab in the Treatment of Neovascular AMD; MI = myocardial infarction; PIER = Phase IIIb, Multicenter, Randomized, Double-Masked, Sham Injection–Controlled Study of the Efficacy and Safety of Ranibizumab; RR = risk ratio; USPSTF = U.S. Preventive Services Task Force; VISION = VEGF Inhibition Study in Ocular Neovascularization.

Mortality and other nonocular health outcomes. The MARINA trial previously found no difference between ranibizumab versus placebo in all-cause (2% vs. 3%; RR, 0.91 [95% CI, 0.34 to 2.44]) or vascular (1% vs. 2%; RR, 0.74 [95% CI, 0.21 to 2.60]) mortality after 2-year followup (Table 5).121 There were no deaths in either group in the PIER trial,123 and the VISION trials did not report mortality.122 In MARINA, there was also no difference between ranibizumab and sham in risk of myocardial infarction (2% vs. 2%; RR, 1.12 [95% CI, 0.35 to 3.60]) or cerebrovascular accident (RR, 2.24 [95% CI, 0.49 to 10]) (Table 5).121 The PIER trial reported no myocardial infarctions or cerebrovascular accidents in either group after 1 year.123

AMD progression and changes in visual acuity. Based on pooled estimates from a good-quality Cochrane systematic review,120 the prior USPSTF review found that intravitreal injection of the VEGF inhibitors pegaptanib (two trials; RR, 0.71 [95% CI, 0.60 to 0.84]) and ranibizumab (one trial; RR, 0.14 [95% CI, 0.08 to 0.25]) were more effective at preventing visual acuity loss than no or sham treatment (Appendix B8).1 Pooling data from all four trials,121–123 VEGF inhibitor treatment was associated with greater likelihood of gaining more than 15 letters of visual acuity (RR, 2.92 [95% CI, 1.20 to 7.12]; absolute risk difference, 10% [95% CI, −7% to 27%]) (Appendix D1) and losing less than 15 letters of visual acuity (RR, 1.46 [95% CI, 1.22 to 1.75]; absolute risk difference, 27% [95% CI, 12% to 42%]) (Appendix D2) after 1-year followup compared with sham injection, though heterogeneity was high for both estimates (I^2^=76% and 80%.) Use of VEGF inhibitors also resulted in greater proportions of patients with vision of 20/200 or better after 1-year followup versus sham injection (RR, 1.47 [95% CI, 1.30 to 1.66]; I^2^=42%; absolute risk difference, 24% [95% CI, 12% to 37%]) (Appendix D3; Table 5). Only the MARINA trial121 reported effects of VEGF inhibitors versus sham at 2-year followup; ranibizumab was associated with greater likelihood of gaining 15 letters or more of visual acuity (RR, 7.86 [95% CI, 4.08 to 15]), losing less than 15 letters of visual acuity (RR, 1.72 [95% CI, 1.52 to 1.94]), and having 20/200 vision or better (RR, 1.63 [95% CI, 1.44 to 1.86]) (Table 5).121

In posthoc subgroup analyses, the MARINA trial also found that in patients with visual acuity worse than 20/40 at baseline, ranibizumab was associated with greater likelihood of improvement to 20/40 or better after 1-year (27.9% vs. 10.6%; RR, 2.64 [95% CI, 1.41 to 4.92]) or 2-year (31.9% vs. 7.7%; RR, 4.13 [95% CI, 2.03 to 8.42]) followup (Appendix C9).126 Patients with visual acuity better than 20/40 (0.3 logMAR) in at least one eye at baseline were also more likely to maintain good visual acuity (77.2% vs. 56.4% at 2 years; RR, 1.37 [95% CI, 1.14 to 1.64]).

Vision-related function. The prior USPSTF review found that ranibizumab was associated with better vision-related function scores at both 1- and 2-year followup compared with sham.127 Changes from baseline in composite National Eye Institute Visual Function Questionnaire (NEI-VFQ) 25 scores favored ranibizumab, as did subscale scores for general vision, mental health, social functioning, and driving (Appendix B9). However, mean differences (<10 points on a 0 to 100 scale) were below criteria for clinically important differences.127

MARINA results on driving status published since the prior USPSTF review found that ranibizumab 0.3 and 0.5 mg was associated with increased likelihood of driving at 24 months in patients who were driving at baseline versus sham (81% vs. 78% vs. 67%, respectively; p<0.05 for both doses versus sham), though there was no difference in the proportion of drivers at 24 months among those who were not driving at baseline (9% for 0.5 mg dose vs. 7% for sham; p=0.65) (Appendix C9).126

## Key Question 5 Are There Harms Associated With Treating Early Impairment in Visual Acuity Due to Uncorrected Refractive Error, Cataracts, or AMD?

### Summary

The prior USPSTF review included one study reporting a higher risk of falls in older adults using multifocal lenses compared to unifocal lenses (OR, 2.09 [95% CI, 1.06 to 4.92]); three studies that reported an incidence of infectious keratitis that ranged from 0.3 to 3.6 cases per 10,000 contact lens wearers; and rates of corneal ectasia of 0 to 0.87 percent, based on five studies of LASIK, and rates of keratitis of 0 to 3.4 percent, based on six studies of LASIK and four studies of LASEK. No study published since the prior USPSTF review assessed harms of treatment of uncorrected refractive error compared to no treatment.

The prior USPSTF review included three systematic reviews on harms of cataract surgery, which reported pooled rates of posterior lens opacification of 28 percent after 5 years and 0.13 percent for endophthalmitis. No study published since the prior USPSTF review assessed the harms of cataract surgery versus no surgery.

The prior USPSTF review included a systematic review that found laser photocoagulation to be associated with greater risk of acute loss of 6 lines or more of visual acuity versus no treatment (3 months; RR, 1.41 [95% CI, 1.08 to 1.82]), and PDT was associated with increased risk of loss of 20 letters or more of visual acuity within 7 days of treatment versus placebo (three trials; RR, 3.75 [95% CI, 0.87 to 16]). One of two trials found that intravitreal VEGF inhibitor therapy was associated with greater likelihood of withdrawal versus sham; there were no differences in serious or other adverse events, but estimates were imprecise.

### Evidence

#### Refractive Error

One small (n=156) prospective study128 included in the prior USPSTF review found multifocal lenses to be associated with a higher risk of falls in older adults versus unifocal lenses (OR, 2.09 [95% CI, 1.06 to 4.92]). Three studies129–131 found incidence of infectious keratitis ranging from 0.3 to 3.6 cases per 10,000 contact lens wearers; one study found incidence to be higher in persons older than age 50 years.132 A meta-analysis reported corneal ectasia rates ranging from 0 to 0.87 percent in five studies of LASIK and keratitis rates ranging from 0 to 3.4 percent in six studies of LASIK and four studies of LASEK.87

No study published since the prior USPSTF review assessed harms of treatment of uncorrected refractive error versus no treatment or usual care.

#### Cataracts

The prior USPSTF review included three systematic reviews91,133,134 of numerous observational studies of cataract surgery, which found a pooled rate of posterior capsule opacification (clouding of the implanted lens, which leads to impairment of high- and low-contrast visual acuity and glare sensitivity) of 28 percent after 5 years and a pooled rate of 0.13 percent for endophthalmitis.

No study published since the prior USPSTF review assessed harms of cataract surgery versus no treatment or usual care.

#### AMD

##### Antioxidant Vitamins and Minerals and Other Supplements

The prior USPSTF review1 found that use of antioxidant vitamins and mineral supplements was not associated with increased risk of most adverse events, based on evidence from a good-quality systematic review (Appendix B8).98 Previous AREDS trial evidence found that use of zinc was associated with increased risk for hospitalization due to genitourinary causes versus nonuse (RR, 1.47 [95% CI, 1.19 to 1.80])135 and use of an antioxidant supplement was associated with increased risk of skin yellowing compared to nonuse (RR, 1.38 [95% CI, 1.09 to 1.75]).97

Two trials published subsequent to the prior USPSTF review reported harms associated with use of vitamin and mineral supplements (Table 4; Appendix C8).105,107 Neither study found a difference between supplement use versus placebo in risk of any adverse event (RR, 1.05 [95% CI, 0.97 to 1.13]), serious adverse events (RR, 1.05 [95% CI, 0.72 to 1.49]), serious ocular adverse events (RR, 1.18 [95% CI, 0.50 to 2.75]), or withdrawals due to adverse events (RR, 3.00 [95% CI, 0.33 to 28]).

##### Laser Photocoagulation

The prior USPSTF review1 found that laser photocoagulation was associated with an increased risk for acute loss of 6 lines or more of visual acuity versus no treatment, despite protective effects on vision (RR, 1.41 [95% CI, 1.08 to 1.82]) (Appendix B8).113 We identified no new studies on harms of laser photocoagulation versus no treatment.

##### PDT

Based on a good-quality systematic review114 included in the prior USPSTF review,1 PDT was associated with an increased risk of severe acute loss of visual acuity (defined as loss of ≥20 letters within 7 days of treatment) versus placebo, though the difference was not statistically significant (three trials; RR, 3.75 [95% CI, 0.87 to 16]; I^2^=28%.) Other adverse events, including visual disturbance (three trials; RR, 1.56 [95% CI, 1.21 to 2.01]; I^2^=7%), injection site reactions (three trials; RR, 2.09 [95% CI, 1.29 to 3.39]; I^2^=73%), photosensitivity (two trials; RR, 5.37 [95% CI, 1.01 to 29]; I^2^=70%) and infusion-related back pain (four trials; RR, 9.93 [95% CI, 2.82 to 35]; I^2^=0%), were all more likely to occur with PDT versus placebo, though some estimates were imprecise (Appendix B8). We identified no new studies on harms of PDT versus no treatment.

##### VEGF Inhibitors

Based on evidence included in the prior USPSTF review,1 there were no significant differences between VEGF inhibitors and sham in incidence of withdrawals due to adverse events in the MARINA (RR, 0.88 [95% CI, 0.45 to 1.70]121) and VISION (RR, 1.00 [95% CI, 0.27 to 3.66]122) trials, though the MARINA trial reported a lower likelihood of any withdrawal in patients randomized to ranibizumab (RR, 0.46 [95% CI, 0.34 to 0.63]) (Table 5). Other adverse events occurred infrequently and point estimates were imprecise. For example, there were no significant differences between VEGF inhibitors and sham in incidence of serious ocular harms, including ocular hemorrhage (one trial; RR, 0.52 [95% CI, 0.08 to 3.62]), retinal detachment (two trials; RR, 0.17 [95% CI, 0.01 to 4.07] and 3.67 [95% CI, 0.20 to 65]) or endophthalmitis (two trials; RR, 5.49 [95% CI, 0.30 to 99] and 8.33 [95% CI, 0.50 to 140]) (Table 5).121–123

## Contextual Question What Is a Clinically Meaningful Difference in Visual Acuity?

Evidence to determine a clinically meaningful difference in visual acuity is limited, though standards for visual acuity classification are available. According to World Health Organization classification, visual acuity of 20/70 or better is classified as mild or no impairment.136 The International Council of Ophthalmology uses a slightly lower (20/63 or better) threshold for mildly impaired visual acuity.137 However, effects of even mildly impaired visual acuity are variable and can have a significant impact on quality of life; for example, the best-corrected visual acuity acceptable for driving in most U.S. states is 20/40.^138^ Therefore, even relatively small changes in even “mild” impaired visual acuity could theoretically have a clinically important impact, depending on baseline visual acuity and type of work and other activities in which an individual is engaged.

Although definitions for a clinically important change in visual acuity vary across studies, a difference of at least 15 letters (equivalent to three lines on the ETDRS), representative of a doubling of the visual angle, is a commonly reported outcome in studies assessing visual acuity,100,114,120 and has been used to represent a clinically meaningful difference.127,139,140 This assumption is based primarily on studies that evaluate effects of changes in visual acuity on vision-related function. Studies using the NEI-VFQ to assess vision-related function, including AREDS, MARINA, and other trials, have found a difference of 10 points to be clinically meaningful to patients, corresponding to an approximately 15-letter change in visual acuity.127,140 Other studies have questioned the appropriateness of using a 15-letter cutoff as indicative of a clinically meaningful difference.141 For example, in people undergoing cataract surgery with mild (acuity of 20/63 or better) to moderate (acuity of 20/80 to 20/160)137 impaired visual acuity, evidence suggests that clinically meaningful changes in visual acuity following surgery can range from about 40 to 10 letters, depending on baseline acuity.142,143 Another study conducted in people with AMD and moderate to severe (20/200 or worse) impaired visual acuity at baseline found that a 15-letter change in visual acuity was associated with NEI-VFQ score differences that ranged from 3.6 to 16.2 points.144

A factor that complicates determinations of clinically important differences in visual acuity is test-retest variability. Test-retest variability can range from 2 to 9 letters (0.04 to 0.19 logMAR), depending on the test setting and patient population.145–147 For example, a 5-letter change in a person with baseline visual acuity of 20/100 has a 90 percent or greater probability of representing a true difference in visual acuity, while for someone with baseline acuity worse that 20/100, a 10-letter change would be required to have a similarly high probability of difference.141 Therefore, a minimum difference of 10 letters (0.2 logMAR; two lines on the ETDRS)147,148 may be required to indicate a true change in visual acuity (i.e., not a change due to test variability).