# Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,68 the USPSTF determined the scope and Key Questions for this review. In conjunction with the USPSTF, investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure). One Contextual Question was also requested by the USPSTF to help inform the review. Contextual Questions are not reviewed using systematic review methodology.

Figure 1 Analytic Framework

* “Asymptomatic” individuals are defined as those without known impaired visual acuity (based on current corrected vision) who have not sought care for evaluation of vision problems.

Abbreviation: KQ = key question.

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the population, interventions and related harms, and outcomes. The population includes asymptomatic adults without known vision impairment (based on current corrected vision) and who have not sought care for evaluation of vision problems. An arrow from the population leads to screening, followed by normal or abnormal diagnosis. A subsequent arrow from the screening intervention assesses resulting harms. An arrow leading from abnormal screening results incorporates treatment and leads to the outcomes examined in the review, which are improved visual acuity, morbidity, mortality, vision-related quality of life, functional status, and cognition. A subsequent arrow from treatment assesses resulting harms. An additional overarching arrow in the framework examines the effect of screening on outcomes.

### Key Questions

1. Does vision screening in asymptomatic older adults result in improved vision, morbidity or mortality, quality of life, functional status, or cognition?
2. Are there harms of vision screening in asymptomatic older adults?
3. What is the accuracy of screening for early impairment in visual acuity due to uncorrected refractive error, cataracts, or AMD?
4. Does treatment of early impairment in visual acuity due to uncorrected refractive error, cataracts, or AMD lead to improved visual acuity, morbidity, mortality, vision-related quality of life, functional status, or cognition?
5. Are there harms of treating early impairment in visual acuity due to uncorrected refractive error, cataracts, or AMD?

### Contextual Question

1. What is a clinically meaningful difference in visual acuity?

## Search Strategies

We used the National Library of Medicine’s Medical Subject Headings (MeSH^®^) and keyword nomenclature to search Ovid MEDLINE^®^, Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews (2008 to February 2015) for relevant English-language studies, systematic reviews, and meta-analyses published since the prior USPSTF review. MEDLINE search strategies are listed in Appendix A1. An update search conducted on January 6, 2016 using the same databases identified no new studies that would affect the conclusions or understanding of the evidence, and therefore the related USPSTF recommendation. We also reviewed reference lists of relevant articles for additional citations.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2). For studies on screening and diagnostic accuracy, we included studies of asymptomatic adults age 65 years or older without known impaired visual acuity (based on current corrected vision) and who have not sought care for evaluation of vision problems. For screening, we included randomized, controlled trials and controlled observational studies (cohort and case-control studies) that evaluated vision screening performed in primary care or community-based settings versus no screening, delayed screening, or usual care (e.g., targeted screening) and evaluated visual acuity, vision-related quality of life, functional capacity (including ability to drive and driving outcomes), mortality, cognition, or harms (including falls and fractures). For diagnostic accuracy, we included studies on diagnostic accuracy of vision screening tests, questions, or questionnaires performed in primary care or community settings. For treatment, we included studies of asymptomatic adults with mild to moderate vision impairment (defined as best visual acuity worse than 20/40 but better than 20/200) due to uncorrected refractive errors, AMD, or cataracts that evaluated effects of corrective lenses, reading aids, or photorefractive surgery (for refractive errors); cataract surgery; or vitamins and antioxidants, laser therapy, PDT, and VEGF (for AMD) on the outcomes described above for screening. We focused on randomized, controlled trials of treatment versus no treatment, but included controlled observational studies if evidence from randomized trials was insufficient. We excluded studies of screening and diagnostic testing performed in specialty settings and excluded trials of treatment in patients with visual acuity worse than 20/200 or who had other causes of vision loss. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. Two investigators independently applied criteria developed by the USPSTF68 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, or poor) using methods developed by the USPSTF, based on quality of studies, precision of estimates, consistency of results between studies, and directness of evidence.68 Data synthesis was based on evidence from the prior review as well as new evidence.

## External Review

The draft report was reviewed by content experts (Appendix A6), USPSTF members, AHRQ Project Officers, and collaborative partners and was posted for public comment.

## Response to Public Comments

The draft report was posted for public comment from July 21, 2015 to August 17, 2015 and few comments were received. No comments identified missing studies that met inclusion criteria or errors in the evidence reviewed, resulting in no changes to the findings or the conclusion of the report.