# Introduction

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This review updates a 2009 review for the U.S. Preventive Services Task Force (USPSTF)1,2 on screening for impaired visual acuity in older adults. It will be used by the USPSTF to update its 2009 recommendation.3 This review focuses on screening for and treatment of impaired visual acuity associated with the following conditions: uncorrected refractive errors, cataracts, and age-related macular degeneration (AMD). Diabetic retinopathy and screening for glaucoma are not addressed in this update because they are addressed elsewhere by the USPSTF4,5 and involve different screening approaches (e.g., visual field assessment, funduscopic examination, and intraocular pressure measurement) or are considered part of diabetes followup and management. For this review, we use the term “impaired visual acuity” rather than “vision impairment” because the latter term implies functional limitations, which may or may not be present. In addition, vision impairment can occur for reasons other than visual acuity loss. For the purposes of this review, “asymptomatic” individuals are defined as those without known impaired visual acuity (based on current corrected vision) and who have not sought care for evaluation of vision problems.

In 2009, the USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening for visual acuity for the improvement of outcomes in older adults (I statement).3 Although the USPSTF found that impaired visual acuity is common and that effective treatments are available for uncorrected refractive error, cataracts, and AMD, direct evidence showed that screening for vision impairment in older adults in primary care settings is not associated with improved functional outcomes and may be associated with unintended harms, such as increased risk of falls.

## Condition Definition

Impaired visual acuity refers to decreased clarity or sharpness of vision. In addition to decreased or substandard visual acuity, uncorrected impaired visual acuity can also be associated with decreases in lowlight vision, color vision, binocularity, contrast sensitivity, accommodation, or stereopsis, as well as visual field loss (areas in the field of view in which objects cannot be seen). Visual acuity is most commonly determined in primary care settings using the Snellen eye chart, which assesses high contrast visual acuity based on the ability of patients to recognize letters of different sizes arranged in rows from a prespecified distance (typically 20 feet). Roughly speaking, a person with 20/100 vision according to the Snellen chart would need to be 20 feet away to read the smallest letters that someone with “normal” (20/20) vision could read at 100 feet. Visual acuity can also be described in meters (6/6 in meters is equivalent to 20/20 in feet) or using the decimal or the logarithm of the minimum angle of resolution (logMAR) scale (Table 1). The severity of decreased visual acuity varies. Impaired visual acuity has been defined as visual acuity of worse than 20/40^6^ or 20/50^7^ but better than 20/200 (the threshold for legal blindness). Visual acuity can be measured with or without refractive correction; for the purposes of this review, impaired visual acuity refers to current corrected visual acuity.

Table 1 Measurements of Visual Acuity

Snellen | | Decimal | LogMAR
Feet | Meters | Decimal | LogMAR
20/20 | 6/6 | 1.00 | 0.00
20/30 | 6/9 | 0.67 | 0.18
20/40 | 6/12 | 0.50 | 0.30
20/60 | 6/18 | 0.33 | 0.48
20/80 | 6/24 | 0.25 | 0.60
20/100 | 6/30 | 0.20 | 0.70
20/160 | 6/48 | 0.13 | 0.90
20/200 | 6/60 | 0.10 | 1.00

Source: Holladay 2004.^157^

Note: Visual impairment is 20/50 or worse; legal blindness is 20/200 or worse.

Abbreviation: LogMAR = logarithmic minimum angle of resolution.

High contrast visual acuity worse than 20/20 but better than 20/40 is generally thought to have minimal effects on reading ability, functional capacity, or quality of life. In the United States, the visual acuity standard for driving is 20/40 or better. Although the International Council of Ophthalmology defined mild impaired visual acuity in 2002 as worse than 20/25 and better than 20/80,^8^ some studies have used a definition for mild impaired visual acuity of between roughly 20/40 and 20/80.^6,7^ This degree of impaired visual acuity is less likely to cause major functional limitations than more severe impairment, and may be more apt to be unidentified without screening. Although these criteria focus on findings for high contrast visual acuity, even normal high contrast visual acuity can be associated with decreased low contrast visual acuity and contrast sensitivity.9

AMD, cataracts, refractive errors, and presbyopia are common causes of impaired visual acuity in older adults. AMD leads to blurred vision and development of scotomas that obscure central vision. AMD is the leading cause of legal blindness for persons older than age 65 years. Atrophic or “dry” macular degeneration accounts for 85 to 90 percent of AMD cases. Cataracts lead to blurring of vision, increased sensitivity to glare, and loss of sensitivity to differences in contrast. Refractive errors, such as myopia (nearsightedness) or hyperopia (farsightedness), occur when the eye is unable to bring parallel rays of light into focus on the fovea.10 Presbyopia, which occurs as part of the natural aging process of the eye, is the loss of the eye’s ability to change its focus to see objects that are near (farsightedness). This occurs as the eyes’ lenses begin to lose flexibility around age 45 years, and affects most people at some point in life.

## Prevalence and Burden of Disease

In 2011, approximately 12.2 percent of Americans ages 65 to 74 years, and 15.2 percent of those age 75 years or older reported having vision loss.11 Prevalence of impaired visual acuity rises significantly with age in older adults, from 1.1 percent in persons ages 65 to 69 years to 16.7 percent in persons older than age 80 years,12 and the prevalence of both blindness and impaired visual acuity increases with age, especially among people age 75 years and older.13 Prevalence of specific causes of impaired visual acuity (i.e., AMD, cataracts, refractive errors, and presbyopia) varies, as described below.

### AMD

The prevalence of AMD in the 2005 to 2008 National Health and Nutrition Examination Survey was 6.5 percent in persons older than age 40 years and increased with age (2.8% in ages 40 to 59 years and 11.1% in age ≥60 years).14 AMD is more common among whites and Hispanics compared to blacks, especially among the very old (≥75 years).14,15

### Cataracts

In persons with low vision (defined as best-corrected visual acuity <20/40), cataracts are the cause in approximately half of cases.16 The prevalence of cataracts increases sharply with age. Approximately 22 million U.S. adults age 40 years and older were estimated to have cataracts (not necessarily associated with vision impairment) in 2011,^17^ and 50 percent of those age 80 years and older are estimated to have cataracts. In white women, prevalence increases from 27.7 percent in ages 65 to 69 years to 76.6 percent in those age 80 years or older. In black women, respective prevalence rates are 28.5 and 60.9 percent, in white men they are 22.4 and 71.3 percent, and in black men they are 17.5 and 46.2 percent.

### Refractive Errors

In older adults with impaired visual acuity due to hyperopia or myopia (including those currently using corrective lenses), approximately 60 percent have correctable (to better than 20/40) refractive errors.7 In general, the prevalence of hyperopia increases sharply with age, with a prevalence that is 4.2 to 7.4 times higher in persons age 80 years or older compared to those ages 40 to 49 years.10,15 The prevalence of hyperopia requiring a correction of +3.0 diopters (D) or more ranges from about 5.9 percent in U.S. adults ages 50 to 54 years, to 15.2 percent in adults ages 65 to 69 years, to 20.4 percent in adults age 80 years and older. At any age, hyperopia is more common in whites than blacks or Hispanics, and is also more prevalent in women than men. For example, among white men, the prevalence of hyperopia of +3.0 D or more is 3.6 percent among those ages 40 to 49 years, 14.1 percent among those ages 65 to 69 years, and 23.5 percent among those older than 80 years. Respective rates for white women are 3.7, 17.8, and 27.2 percent, and for black women they are 3.1, 10.6, and 13.5 percent. An exception to increasing prevalence of hyperopia with age is adult black men, in whom the prevalence of hyperopia remains fairly constant across age groups, ranging from 1.5 to 3.9 percent.10

Among adults older than age 65 years, the prevalence of myopia is relatively stable with increasing age, though prevalence varies among different ethnic/racial groups. For example, the prevalence of myopia of less than −1.0 D in black men ages 65 to 69 years is 8.1 percent compared with 13.1 percent in Hispanic men and 17.7 percent in white men.10 The prevalence of myopia requiring a correction of less than −1.0 D also tends to decrease with age and ranges from about 27.1 percent in U.S. adults ages 50 to 54 years, to 14.7 percent in adults ages 65 to 69 years, to 16.8 percent in adults age 80 years and older. At any age, myopia is also more prevalent in whites than blacks or Hispanics.

### Presbyopia

The prevalence of presbyopia, or age-related hyperopia, increases with age and affects most people at some point in life. The onset of presbyopia generally occurs around age 45 years, though onset tends to be somewhat earlier in people who live in areas with higher ambient temperatures.18

Regardless of its cause, impaired visual acuity is consistently associated with decreased functional capacity and quality of life in older people, including the ability to live independently, with more severe impaired visual acuity associated with greater negative effects.19–23 Impaired visual acuity can affect ability to perform both basic and instrumental activities of daily living, work, drive safely, or obtain a driver’s license, as well as increase risk of falls and other accidental injuries.24–28 However, there is interindividual variability in the degree of functional impairment in persons with the same degree of impaired visual acuity. Vision loss is also associated with higher prevalence of depression and social isolation.20,29 Of older adults experiencing impaired visual acuity, 57.2 percent are at risk for mild or moderate depression compared to 43.5 percent of those without vision loss.30 When combined with other chronic health conditions, vision loss is associated with overall poorer health among people age 65 years and older.13

According to the Centers for Disease Control and Prevention, an estimated 61 million U.S. adults are at high risk for serious vision loss, which can cause a substantial social and economic toll, including disability, loss of productivity, and reduced quality of life.31 Experts predict that by 2030, rates of severe vision loss will double or triple as the aging population increases30–32 and the number of older adults (age ≥65 years) increases.13,20,30,33 Direct medical expenses for older adults with impaired visual acuity in the United States are $8.3 billion annually,13 including an estimated annual $6.8 billion for cataract treatment.34

## Etiology and Natural History

Refractive errors are a general term to describe conditions associated with the inability of the cornea and lens of the eye to bring parallel rays of light into sharp focus on the fovea, resulting in blurry vision. In adults, common types of refractive errors are myopia, hyperopia, and astigmatism. Myopia occurs when images are focused in front of the fovea, affecting ability to clearly view more distant objects.35 Hyperopia occurs when images are focused behind the fovea, which affects the ability to sharply view closer objects. Hyperopia often presents or worsens with older age due to presbyopia, which refers to age-related changes in the eye, including decreased elasticity of the lens, reducing near-focusing ability. Astigmatism is a condition in which there are two or more focal points in the eye, resulting in distortion of images at various distances. Progression of myopia in older adults can be associated with development and progression of cataracts. Cataracts are opacities in the lens of the eye, which result in decreased visual acuity and glare that generally progress over time.36

AMD affects the macula, the area of the retina responsible for central vision.37 Drusen, which are white to yellow retinal lesions, are an early sign of AMD when they occur in the macula. Advanced AMD is usually classified into “wet” or “dry” forms. The dry form of advanced AMD (also referred to as “geographic atrophy”) is more common and associated with atrophy of the retinal layers and retinal pigmented epithelial cells. The wet form of AMD is associated with the development of abnormal blood vessels in the choroid layer underneath the retina (choroidal neovascularization). Both types of advanced AMD can cause blurred central vision, distorted vision, and decreased lowlight vision. In severe cases, advanced AMD results in central scotomas (complete loss of central vision).

## Risk Factors

Prevalence of impaired visual acuity is higher among people of lower socioeconomic or educational status and those without private health insurance.7,10 Risk factors for specific conditions causing impaired visual acuity vary depending on the condition. A positive family history is a major risk factor for both myopia and hyperopia.35 In both sexes and in various ethnic/racial groups, latent hyperopia tends to manifest with older age due to a loss in accommodation, with the exception of black men, in whom the prevalence of hyperopia remains relatively low.10 Risk factors for cataracts include older age, smoking, alcohol use, exposure to ultraviolet light, eye trauma, ocular inflammatory diseases, diabetes, and exposure to corticosteroids.38,39 Lower socioeconomic status and black race are associated with higher rates of unoperated cataracts.40 Risk factors for AMD are not completely understood, but are thought to include older age, smoking, white race, obesity, diet, elevated cholesterol, cardiovascular disease, and family history.41,42 AMD is more common in whites compared to other races/ethnicities.10

The Behavioral Risk Factor Surveillance System Vision Impairment Expert Panel concluded that the most substantial barriers to vision preventive care, treatment, and rehabilitation appear to be behavioral issues, followed by cost and geographic access. Behavioral and cultural issues of concern included patient belief systems, trust issues, education and language barriers, health literacy issues, immigration status, and concordance between doctor and patient.43

## Rationale for Screening/Screening Strategies

Impaired visual acuity due to uncorrected refractive error, cataracts, and AMD is common in adults and the prevalence increases with age.10,16,44 Impaired visual acuity in older adults may not be recognized or may remain unreported because vision changes can be relatively subtle, progress slowly over time, or occur in persons with cognitive dysfunction or other comorbid conditions. However, mildly impaired visual acuity may be associated with decreased quality of life and functional capacity and increased likelihood of accidents and related injuries.19,21–23 Disparities exist among racial/ethnic groups, with higher age-specific prevalence of diabetic retinopathy, open-angle glaucoma, and impaired visual acuity. Screening for impaired visual acuity in the primary care setting is noninvasive and could potentially identify persons likely to benefit from referral for interventions to improve visual acuity or slow progression of ocular disease.1

## Interventions/Treatment

A number of interventions are available to treat common causes of impaired visual acuity. Although impaired visual acuity may be identified in the primary care setting, most interventions require the involvement of an eye care provider. Presbyopia is often corrected with prescription glasses, contact lenses, reading glasses, progressive addition lenses, or bifocals. Refractive errors may be remedied with corrective lenses, contact lenses, or refractive surgery. Photorefractive surgery, including laser in situ keratomileusis (LASIK), photorefractive keratectomy, or laser epithelial keratomileusis (LASEK), is associated with more upfront costs compared to corrective lenses and more commonly selected as a treatment option by younger adults. The risks and benefits of laser eye surgeries shift at and after midlife. Older patients undergoing photorefractive surgery may be slightly less likely to experience optimal results and slightly more likely to need repeat treatment or enhancement.45

For patients with impaired visual acuity that is not sufficiently improved by correcting refractive error, reading aids (such as magnifiers) are a treatment option.46 For cataracts causing significant impairment in visual acuity, the most common treatment is surgical cataract extraction and intraocular lens implantation.47 Cataract surgery is effective in improving vision in 90 percent of patients, has a low complication rate, generally can be performed as an outpatient procedure, and can restore vision even in patients with advanced cataracts.48

Antioxidants and vitamins have been found to slow the progression of some types of AMD, but have no proven benefit in slowing cataract progression.49–52 No treatment is known to reverse the retinal damage associated with dry AMD. The wet form of AMD accounts for most of the vision loss and blindness associated with advanced AMD. For both dry and wet AMD, early identification and treatment may help to prevent permanent effects on vision. Treatments for wet AMD are aimed at the abnormal retinal vascular growth (choroidal neovascularization) associated with this condition and responsible for vision loss. Laser photocoagulation is an established treatment for wet AMD, but causes blind spots due to retinal damage in areas of treatment.46 It is generally considered a treatment option only in patients with extrafoveal neovascularization, in order to avoid causing central visual field defects.46,53,54 Photodynamic therapy (PDT) with verteporfin, a photoreactive agent, is associated with less retinal scarring compared with laser photocoagulation and is an option for subfoveal neovascularization. Another treatment for wet AMD is intravitreal injection of a vascular endothelial growth factor (VEGF) inhibitor, such as bevacizumab, ranibizumab, or pegaptanib, in order to suppress growth of abnormal blood vessels. Other treatments that have been studied for wet AMD include surgical implantation of corticosteroids,55 intravitreal interferon alfa,56 radiation,57 and other surgical procedures (submacular surgery and macular translocation). However, these therapies have either not been proven to be effective or have limited indications for use because the effects of dry or wet AMD may be irreversible.

## Current Clinical Practice

The clinical standard for identifying presence of impaired visual acuity is by evaluation of distance visual acuity using the Snellen eye chart or another standardized test of visual acuity. Pinhole visual acuity testing can be used to estimate whether impaired visual acuity is due to correctable refractive error (i.e., vision corrects or improves upon pinhole testing).58 Reading distance testing can also be assessed using a handheld card or other screening tool.

Clinically significant cataracts can be visualized via physical examination as change of color or opacities in the lens. Impaired visual acuity due to cataracts should not completely correct with pinhole testing, though partial correction may occur due to decreased light scattering, particularly if myopia related to the cataract is present.59

The Amsler grid consists of evenly spaced horizontal and vertical lines (making squares) on a sheet.60 It is used to detect retinal defects affecting central vision, including AMD, which can be associated with distortion in the boxes on the grid or blank areas in the grid (scotomas). The Amsler grid can also be used by patients as a self-monitoring tool for early signs or progression of macular disease.61,62

Screening questions may be used to elicit self-perceived problems with vision.63 Funduscopic examination can also be performed in order to detect asymptomatic or early AMD or other retinal disease. The frequency with which nonSnellen visual acuity tests, the Amsler grid, vision screening questionnaires, or funduscopic examination is used in primary care is not known.1 Older adults with impaired visual acuity are typically referred to an optometrist or ophthalmologist for further evaluation, correction of refractive error, and other treatments. In a study estimating the level of self-reported access to eye care services, approximately half of U.S. adults older than age 65 years reported receiving an eye examination within the last 12 months.64

Commonplace use of electronic devices, such as smartphones and computers, to view small type for many hours presents a variety of visual demands significantly different from those of printed materials. Therefore, examination procedures and treatment regimens might need to be reconsidered, since an inability to address the effects of these demands could affect individuals’ quality of life.65

## Recommendations of Other Groups

The American Optometric Association recommends an annual eye examination conducted by an optometrist for all adults older than age 60 years, and the American Academy of Ophthalmology recommends a comprehensive examination conducted by an ophthalmologist every 1 to 2 years in patients age 65 years or older (Table 2).34,66 The American Academy of Family Physicians’ recommendation on screening for visual acuity in older adults is in agreement with the 2009 USPSTF recommendation (insufficient evidence).67

Table 2 Recommendations of Other Groups

Organization | Recommendation/Clinical Guidance
American Academy of Ophthalmology34 | Patients age 65 years or older without risk factors for eye disease (e.g. diabetes, glaucoma) should have comprehensive medical eye evaluations every 1 to 2 years.
American Optometric Association66 | Annual eye examination for all adults older than age 60 years.
American Academy of Family Physicians158 | Current evidence is insufficient to assess the balance of benefit and harms of screening for visual acuity for the improvement of outcomes in older adults.