# Appendix Figures

Appendix D1 Gain of 15 Letters or More of Visual Acuity With Use of Vascular Endothelial Growth Factor Inhibitors at 1-Year Followup

Abbreviation: VEGF = vascular endothelial growth factor.

This figure is a forest plot showing gain of 15 letters or more of visual acuity with use of VEGF inhibitors at 1-year followup. Two studies comparing ranibizumab versus sham and 2 studies of pegaptanib versus sham were pooled for a total risk ratio of 2.92 (95% CI, 1.20 to 7.12); I2=76%.

Appendix D2 Loss of 15 Letters or Less of Visual Acuity With Use of Vascular Endothelial Growth Factor Inhibitors at 1-Year Followup

Abbreviation: VEGF = vascular endothelial growth factor.

This figure is a forest plot showing loss of 15 letters or more of visual acuity with use of VEGF inhibitors at 1-year followup. Two studies comparing ranibizumab versus sham and 2 studies of pegaptanib versus sham were pooled for a total risk ratio of 1.46 (95% CI, 1.22 to 1.75); I2=80%.

Appendix D3 Visual Acuity of 20/200 or Better With Use of Vascular Endothelial Growth Factor Inhibitors at 1-Year Followup

Abbreviation: VEGF = vascular endothelial growth factor.

This figure is a forest plot showing visual acuity of 20/200 or better with use of VEGF inhibitors at 1-year followup. Two studies comparing ranibizumab versus sham and 2 studies of pegaptanib versus sham were pooled for a total risk ratio of 1.47 (95% CI, 1.30 to 1.66); I2=42%.