# Evidence and Quality Tables of Published Studies From This Update

Appendix C1 Studies of Diagnostic Test Accuracy Published Since the Prior USPSTF Review

Appendix C2 Quality Assessment of Studies of Diagnostic Test Accuracy Published Since the Prior USPSTF Review

Appendix C3 Studies of Treatment of Uncorrected Refractive Error or Cataracts Published Since the Prior USPSTF Review

Appendix C4 Quality Assessment of Observational Studies of Treatment of Uncorrected Refractive Error or Cataracts Published Since the Prior USPSTF Review

Appendix C5 Systematic Reviews of Age-Related Macular Degeneration Published Since the Prior USPSTF Review

Appendix C6 Quality Assessment of Systematic Reviews of Age-Related Macular Degeneration Published Since the Prior USPSTF Review

Appendix C7 Studies of Supplements for Age-Related Macular Degeneration Published Since the Prior USPSTF Review

Appendix C8 Quality Assessment of Studies of Supplements for Age-Related Macular Degeneration Published Since the Prior USPSTF Review

Appendix C9 Studies of Vascular Endothelial Growth Factor Inhibitors for Age-Related Macular Degeneration Published Since the Prior USPSTF Review

Appendix C10 Quality Assessment of Trials of Vascular Endothelial Growth Factor Inhibitors for Age-Related Macular Degeneration