# Evidence Tables From Prior USPSTF Review

Appendix B1 Studies of Screening for Impaired Visual Acuity Included in the Prior USPSTF Review

Appendix B2 Characteristics of Diagnostic Accuracy Studies Included in the Prior USPSTF Review

Appendix B3 Studies of Diagnostic Accuracy Included in the Prior USPSTF Review

Appendix B4 Trials of Treatment of Uncorrected Refractive Error Included in the Prior USPSTF Review

Appendix B5 Systematic Reviews of Treatment of Uncorrected Refractive Error Included in the Prior USPSTF Review

Appendix B6 Systematic Reviews of Treatment of Cataracts Included in the Prior USPSTF Review

Appendix B7 Trials of Treatment of Cataracts Included in the Prior USPSTF Review

Appendix B8 Systematic Reviews of Age-Related Macular Degeneration Included in the Prior USPSTF Review

Appendix B9 Trials of Age-Related Macular Degeneration Included in the Prior USPSTF Review