# Detailed Methods

## Appendix A1 Search Strategies

### Key Questions 1–2

#### Database: Ovid MEDLINE(R) without Revisions

1. Mass Screening/
2. exp Vision Tests/
3. exp Refractive Errors/
4. exp Macular Degeneration/
5. exp Vision Disorders/
6. exp Vision, Ocular/
7. exp Eye Diseases/
8. Cataract/
9. (presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or armd).mp.
10. or/2–9
11. 1 and 10
12. 11 not (adolescen$ or child$ or pediatric$ or toddler or infant$ or newborn or neonat$ or prematur$).mp.
13. limit 12 to humans
14. limit 13 to english language
15. limit 13 to abstracts
16. 14 or 15

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Mass Screening/
2. exp Vision Tests/
3. exp Refractive Errors/
4. exp Macular Degeneration/
5. exp Vision Disorders/
6. exp Vision, Ocular/
7. exp Eye Diseases/
8. Cataract/
9. (presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or armd).mp.
10. or/2–9
11. 1 and 10
12. 11 not (adolescen$ or child$ or pediatric$ or toddler or infant$ or newborn or neonat$ or prematur$).mp.

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. ((vision or visual) adj5 screen$).mp.
2. (presbyop$ or myop$ or astigmati$ or hyperop$).mp.
3. (macula$ adj3 degenerat$).mp.
4. cataract$.mp.
5. 1 and (or/2–4)
6. 5 not (child$ or pediatr$ or neonat$ or prematur$).mp.

### Key Question 3

#### Database: Ovid MEDLINE(R) without Revisions

1. Vision, Ocular/
2. Vision Disorders/
3. Vision Tests/
4. Refractive Errors/
5. Macular Degeneration/
6. Cataract/
7. Eye Diseases/
8. (presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or armd).mp.
9. vision.mp.
10. or/1–9
11. screen$.mp.
12. 10 and 11
13. “Sensitivity and Specificity”/
14. (specificity or accurac$ or “predictive value”).tw.
15. (sensitiv$ or diagnostic).mp.
16. or/13–15
17. 12 and 16
18. 17 not (adolescen$ or child$ or pediatric$ or toddler or infant or neonat$ or prematur$).mp.
19. limit 18 to humans
20. limit 19 to english language
21. limit 19 to abstracts
22. 20 or 21

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 Vision, Ocular/
2 Vision Disorders/
3 Vision Tests/
4 Refractive Errors/
5 Macular Degeneration/
6 Cataract/
7 Eye Diseases/
8 (presbyop$ or myop$ or astigmati$ or hyperop$ or cataract$ or “macular degeneration” or armd).mp.
10 or/1–9
11 screen$.mp.
12 10 and 11
13 “Sensitivity and Specificity”/
14 (specificity or accurac$ or “predictive value”).tw.
15 (sensitiv$ or diagnostic).mp.
16 or/13–15
17 12 and 16
18 17 not (adolescen$ or child$ or pediatric$ or toddler or infant or neonat$ or prematur$).mp.

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 (presbyop$ or myop$ or astigmati$ or hyperop$).mp.
2 (macula$ adj3 degenerat$).mp.
3 cataract$.mp.
4 visual acuity.mp.
6 (diagno$ adj2 accur$).mp.
7 5 and 6

### Key Questions 4–5

#### Database: Ovid MEDLINE(R) without Revisions

1. exp Refractive Errors/dt, pc, rt, th
2. exp Cataract/dh, dt, pc, rt, th
3. Cataract Extraction/
4. exp Macular Degeneration/dh, dt, pc, rt, su, th
5. exp Vision Disorders/dh, dt, pc, rt, su, th
6. or/1–5
7. 6 not (adolescen$ or child$ or pediatric$ or toddler or infant$ or newborn or neonat$ or prematur$).mp.
8. limit 7 to humans
9. limit 8 to english language
10. limit 8 to abstracts
11. limit 10 to “all aged (65 and over)”
12. limit 11 to yr=“2008 – 2014”

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Refractive Errors/dt, pc, rt, th
2. exp Cataract/dh, dt, pc, rt, th
3. Cataract Extraction/
4. exp Macular Degeneration/dh, dt, pc, rt, su, th
5. exp Vision Disorders/dh, dt, pc, rt, su, th
6. or/1–5
7. 6 not (adolescen$ or child$ or pediatric$ or toddler or infant$ or newborn or neonat$ or prematur$).mp.

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (“age-related macular degeneration” or “age related macular degeneration” or “AMD” or “ARMD”).ti,ab.
2. (“impaired visual acuity” or “impaired vision” or “visual acuity”).ti,ab.
3. cataract$.ti,ab.
4. (presbyop$ or myop$ or astigmati$ or hyperop$).ti,ab.
5. treatment.ti,ab.
6. (or/1–4) and 5
7. 6 not (child$ or pediatr$ or neonat$ or prematur$).mp.
8. limit 7 to new reviews
9. limit 8 to full systematic reviews
10. 9 not diabet$.mp.

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Key Questions 1 & 2. Screening Effectiveness and Harms
Populations | Asymptomatic adults 65 years of age and older without known impaired visual acuity (based on current corrected vision) and who have not sought care for evaluation of vision problems | Known impaired visual acuity based on current corrected vision or who have sought care for evaluation of vision problems
Interventions | Vision screening performed in primary care or community-based settings, including multi-component screening with a distinct vision screening component | Vision screening performed in eye specialty settings
Outcomes | Visual acuity; vision-related quality of life; functional capacity. including ability to drive and driving outcomes; other measures of morbidity; mortality; cognition; harms, including falls and fractures | Reading speed and other tests of vision function
Study designs | Randomized controlled trials and controlled observational studies comparing vision screening to no screening, delayed screening or usual care (i.e. targeted screening.)
Key Question 3. Diagnostic Accuracy
Populations | Asymptomatic adults 65 years of age and older without known impaired visual acuity (based on current corrected vision) and who have not sought care for evaluation of vision problems | Known impaired visual acuity based on current corrected vision or who have sought care for evaluation of vision problems
Interventions | Vision screening tests performed in primary care or community-based settings; questions or questionnaires for impaired visual acuity | Diagnostic tests for vision screening performed in eye specialty settings (including fundoscopic examination performed by an eye professional and specialized diagnostic testing)
Outcomes | Sensitivity, specificity, positive and negative predictive values, areas under the receiver operating curve, other measures of diagnostic test accuracy
Study designs | Studies evaluating diagnostic accuracy of a screening question or diagnostic test compared to a reference standard.
Key Questions 4 & 5. Treatment Effectiveness and Harms
Populations | Asymptomatic adults with vision impairment (current corrected visual acuity worse than 20/40 but better than 20/200) due to uncorrected refractive errors (myopia, hyperopia, astigmatism, or presbyopia), age-related macular degeneration, or cataracts. | Visual acuity worse than 20/200, other causes of vision loss
Interventions | Corrective lenses (eyeglasses and contact lenses), reading aids, photorefractive surgery (LASIK, LASEK, PRK), cataract surgery, vitamins and antioxidants, laser therapy, photodynamic therapy, vascular endothelin growth factor inhibitors
Outcomes | Visual acuity; vision –related quality of life, functional capacity (including ability to drive and driving outcomes), other measures of morbidity; mortality; falls; fractures; other treatment-related harms. | Reading speed and other tests of vision function
Study designs | Randomized controlled trials comparing treatment to no treatment (including sham injection). Controlled observational studies will be included if evidence on harms from randomized trials is insufficient.
All Key Questions
Language | English language
Settings | United States applicable, primary care relevant

Abbreviations: LASEK = laser assisted sub-epithelial keratomileusis; LASIK = laser assisted in situ keratomileusis; PRK = photorefractive keratectomy.

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Other sources include prior reports, references lists, and referrals from experts.

‡ Studies may be included for more than one Key Question.

Abbreviations: AMD = age-related macular degeneration; KQ = key question; SR = systematic review; VEGF = vascular endothelial growth factor.

This figure is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 4,506 abstracts of potentially relevant articles were identified through MEDLINE, Cochrane, and other sources. 273 articles were reviewed at the full-text level after excluding 4,233 nonrelevant abstracts and background articles. From these, 225 were excluded due to: wrong population (55), wrong intervention (30), wrong outcome (23), wrong study design for key question (39), not a study (13), in systematic review and not directly used (26), wrong comparison (23), using original studies instead (14), and screening conducted by an optometrist (1 study in 2 publications). After excluding these studies, 48 publications, including 10 studies and 1 systematic review in the update and 29 studies (in 30 publications) and 7 systematic reviews from the prior report, were included.

## Appendix A4 Excluded Studies

Epidemiological feasibility of cardiovascular primary prevention in general practice: a trial of vitamin E and aspirin. Collaborative group of the Primary Prevention Project. J Cardiovasc Risk. 1995;2(2):137-42. Excluded: wrong outcomes.
A screening update for smokers and ex-smokers. Johns Hopkins Med Lett Health After 50. 2012;24(11):4. Excluded: not a study (letter, editorial, non-systematic review article).
Abraham P, Yue H, Wilson L. Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER study year 2. Am J Ophthalmol. 2010;150(3):315-24.e1. Excluded: wrong population. [pmid: 20598667].
Adams AJ. Visionaries are often out of sight. Optom Vis Sci. 2010;87(5):299. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20440129].
Age-Related Eye Disease Study 2 Research G. Lutein + zeaxanthin and omega-3 fatty acids for age-related macular degeneration: the Age-Related Eye Disease Study 2 (AREDS2) randomized clinical trial. JAMA. 2013;309(19):2005-15. Excluded: wrong comparison (no control group). [pmid: 23644932].
Age-Related Eye Disease Study 2 Research G. Chew EY, Clemons TE, et al. Secondary analyses of the effects of lutein/zeaxanthin on age-related macular degeneration progression: AREDS2 report No. 3. JAMA Ophthalmol. 2014;132(2):142-9. Excluded: wrong comparison (no control group). [pmid: 24310343].
Age-Related Eye Disease Study 2 Research G. Chew EY, SanGiovanni JP, et al. Lutein/zeaxanthin for the treatment of age-related cataract: AREDS2 randomized trial report no. 4. JAMA Ophthalmol. 2013;131(7):843-50. Excluded: wrong comparison (no control group). [pmid: 23645227].
Ahmadi A, Ghanbari H, Soheilian M, et al. The Effect of HESA-A (natural drug) on visual acuity in age related macular degeneration: a randomized double blind controlled clinical trial. Afr J Tradit Complement Altern Med. 2009;6(4):549-53. Excluded: wrong intervention. [pmid: 20606776].
Ahn JK, Moon HJ. Changes in aqueous vascular endothelial growth factor and pigment epithelium-derived factor after ranibizumab alone or combined with verteporfin for exudative age-related macular degeneration. Am J Ophthalmol. 2009;148(5):718-24.e1. Excluded: wrong population. [pmid: 19674731].
Akuffo KO, Beatty S, Stack J, et al. Central Retinal Enrichment Supplementation Trials (CREST): design and methodology of the CREST randomized controlled trials. Ophthalmic Epidemiol. 2014;21(2):111-23. Excluded: wrong study design for Key Question. [pmid: 24621122].
Alliance for Aging Research. Independence for Older Americans: An Investment for Our Nation’s Future. 1999. Excluded: not a study (letter, editorial, non-systematic review article).
American Optometric Association. Adult Vision: Over 60 Years of age. 2013. http://www.aoa.org/patients-and-public/good-vision-throughout-life/adult-vision-19-to-40-years-of-age/adult-vision-over-60-years-of-age. Accessed January 10th, 2014. Excluded: not a study (letter, editorial, non-systematic review article).
Anderson AJ, Shuey NH, Wall M. Rapid confrontation screening for peripheral visual field defects and extinction. Clin Exp Optom. 2009;92(1):45-8. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19125747].
Andonegui J, Berastegui L, Serrano L, et al. Agreement among ophthalmologists and primary care physicians in the evaluation of retinographies of diabetic patients. Arch Soc Esp Oftalmol. 2008;83(9):527-31. Excluded: wrong population. [pmid: 18803124].
Andonegui J, Serrano L, Eguzkiza A, et al. Diabetic retinopathy screening using tele-ophthalmology in a primary care setting. J Telemed Telecare. 2010;16(8):429-32. Excluded: wrong population. [pmid: 20813892].
Andonegui J, Zurutuza A, de Arcelus MP, et al. Diabetic retinopathy screening with non-mydriatic retinography by general practitioners: 2-year results. Prim Care Diabetes. 2012;6(3):201-5. Excluded: wrong population. [pmid: 22285305].
Anstey KJ, Horswill MS, Wood JM, et al. The role of cognitive and visual abilities as predictors in the Multifactorial Model of Driving Safety. Accid Anal Prev. 2012;45:766-74. Excluded: wrong outcomes. [pmid: 22269568].
Antoszyk AN, Tuomi L, Chung CY, et al. Ranibizumab combined with verteporfin photodynamic therapy in neovascular age-related macular degeneration (FOCUS): year 2 results. Am J Ophthalmol. 2008;145(5):862-74. Excluded: wrong intervention. [pmid: 18321465].
Applegate W, Miller S, Elam J, et al. Impact of cataract surgery with lens implantatioin on vision and physical function in elderly patients. JAMA. 1987;257:1064-6. Excluded: in systematic review, not directly used. [pmid: 3806895].
AREDS Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E and beta carotene for age-related cataract and vision loss: AREDS report no. 9. Arch Ophthalmol. 2001;119(10):1439-52. Excluded: in systematic review, not directly used. [pmid: 11594943].
Armbrecht AM, Aspinall P, Dhillon B. A prospective study of visual function and quality of life following PDT in patients with wet age related macular degeneration. Br J Ophthalmology. 2004;88:1270-3. Excluded: wrong study design for Key Question.
Arnold C, Winter L, Frohlich K, et al. Macular xanthophylls and [omega]-3 long-chain polyunsaturated fatty acids in age-related macular degeneration: a randomized trial. JAMA Ophthalmol. 2013;131(5):564-72. Excluded: wrong outcomes. [pmid: 23519529].
Asbell PA, Dualan I, Mindel J, et al. Age-related cataract. Lancet. 2005;365:599-609. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 15708105].
Askew D, Schluter PJ, Spurling G, et al. Diabetic retinopathy screening in general practice: a pilot study. Aust Fam Physician. 2009;38(8):650-6. Excluded: wrong population. [pmid: 19893789].
Attebo K, Ivers RQ, Mitchell P. Refractive errors in an older population: the Blue Mountains Eye Study. Ophthalmology. 1999;106(6):1066-72. Excluded: wrong outcomes. [pmid: 10366072].
Au Eong KG, Chan EW, Luo N, et al. Validity of EuroQOL-5D, time trade-off, and standard gamble for age-related macular degeneration in the Singapore population. Eye. 2012;26(3):379-88. Excluded: wrong outcomes. [pmid: 22222257].
Avery RL, Ho AC. Good News for Anti-VEGF Therapy. 2008. Available at: http://www.retinatoday.com/issues/0308/0308_01.php. Accessed November, 2008. Excluded: not a study (letter, editorial, non-systematic review article).
Axer-Siegel R, Bor E, Bourla DH, et al. Intravitreal bevacizumab treatment for exudative age-related macular degeneration with good visual acuity. Retina. 2012;32(9):1811-20. Excluded: wrong study design for Key Question. [pmid: 22825407].
Azab M, Boyer DS, Bressler NM, et al. Verteporfin therapy of subfoveal minimally classic choroidal neovascularization in age-related macular degeneration: 2-year results of a randomized clinical trial. Arch Ophthalmol. 2005;123(4):448-57. Excluded: in systematic review, not directly used. [pmid: 15824216].
Baker ML, Wang JJ, Rogers S, et al. Early age-related macular degeneration, cognitive function, and dementia: the Cardiovascular Health Study. Arch Ophthalmol. 2009;127(5):667-73. Excluded: wrong study design for Key Question. [pmid: 19433718].
Barbazetto I, Saroj N, Shapiro H, et al. Dosing regimen and the frequency of macular hemorrhages in neovascular age-related macular degeneration treated with ranibizumab. Retina (Philadelphia, Pa). 2010;30(9):1376-85. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication).
Bartlett HE, FAE. Effect of lutein and antioxidant dietary supplementation on contrast sensitivity in age-related macular degeneration: a randomized controlled trial. Eur J Clin Nutr. 2001;61(9):1121-7. Excluded: in systematic review, not directly used. [pmid: 17268417].
Bergman B, Nilsson-Ehle H, Sjostrand J. Ocular changes, risk markers for eye disorders and effects of cataract surgery in elderly people: a study of an urban Swedish population followed from 70 to 97 years of age. Acta Ophthalmol Scand. 2004;82(2):166-74. Excluded: wrong study design for Key Question. [pmid: 15043535].
Bernth-Petersen P. Outcome of cataract surgery. A prospective, observational study. Acta Ophthalmol. 1982;60:235-42. Excluded: wrong study design for Key Question. [pmid: 7136534].
Blaha M, Rencova E, Langrova H, et al. Rheohaemapheresis in the treatment of nonvascular age-related macular degeneration. Atheroscler Suppl. 2013;14(1):179-84. Excluded: wrong intervention. [pmid: 23357162].
Bourne RRA, French KA, Chang L, et al. Can a community optometrist-based referral refinement scheme reduce false-positive glaucoma hospital referrals without compromising quality of care? The community and hospital allied network glaucoma evaluation scheme (CHANGES). Eye. 2010;24(5):881-7. Excluded: wrong intervention. [pmid: 19648892].
Boyer D, Heier J, Brown DM, et al. Vascular endothelial growth factor Trap-Eye for macular edema secondary to central retinal vein occlusion: six-month results of the phase 3 COPERNICUS study. Ophthalmology. 2012;119(5):1024-32. Excluded: wrong population. [pmid: 22440275].
Bragge P, Gruen RL, Chau M, et al. Screening for presence or absence of diabetic retinopathy: a meta-analysis. Arch Ophthalmol. 2011;129(4):435-44. Excluded: wrong population. [pmid: 21149748].
Brenner M, Curbow B, Javitt J, et al. Vision change and quality of life in the elderly; response to cataract surgery and treatment of other chronic ocular conditions. Arch Opthalmol. 1993;111:680-5. Excluded: in systematic review, not directly used.
Bressler NM, Boyer DS, Williams DF, et al. Cerebrovascular accidents in patients treated for choroidal neovascularization with ranibizumab in randomized controlled trials. Retina. 2012;32(9):1821-8. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 23011184].
Bressler NM, Chang TS, Fine JT, et al. Improved vision-related function after ranibizumab vs photodynamic therapy: a randomized clinical trial. Arch Ophthalmol. 2009;127(1):13-21. Excluded: wrong comparison (no control group). [pmid: 19139332].
Bressler NM, Chang TS, Suner IJ, et al. Vision-related function after ranibizumab treatment by better- or worse-seeing eye: clinical trial results from MARINA and ANCHOR. Ophthalmology. 2010;117(4):747-56.e4. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 20189654].
Brown DM, Campochiaro PA, Bhisitkul RB, et al. Sustained benefits from ranibizumab for macular edema following branch retinal vein occlusion: 12-month outcomes of a phase III study. Ophthalmology. 2011;118(8):1594-602. Excluded: wrong population. [pmid: 21684606].
Brown DM, Campochiaro PA, Singh RP, et al. Ranibizumab for macular edema following central retinal vein occlusion: six-month primary end point results of a phase III study. Ophthalmology. 2010;117(6):1124-33.e1. Excluded: wrong population. [pmid: 20381871].
Brown DM, Heier JS, Clark WL, et al. Intravitreal aflibercept injection for macular edema secondary to central retinal vein occlusion: 1-year results from the phase 3 COPERNICUS study. Am J Ophthalmol. 2013;155(3):429-37.e7. Excluded: wrong population. [pmid: 23218699].
Brown DM, Kaiser PK, Michels M, et al. Ranibizumab versus verteporfin for neovascular age-related macular degeneration. New Engl J Med. 2006;355(14):1432-44. Excluded: wrong comparison (no control group). [pmid: 17021319].
Brown DM, Michels M, Kaiser PK, et al. Ranibizumab versus verteporfin photodynamic therapy for neovascular age-related macular degeneration: Two-year results of the ANCHOR study. Ophthalmology. 2009;116(1):57-65.e5. Excluded: wrong comparison (no control group). [pmid: 19118696].
Burlina P, Freund DE, Dupas B, et al. Automatic screening of age-related macular degeneration and retinal abnormalities. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:3962-6. Excluded: wrong intervention. [pmid: 22255207].
Burr JM, Mowatt G, Hernandez R, et al. The clinical effectiveness and cost-effectiveness of screening for open angle glaucoma: a systematic review and economic evaluation. Health Technol Assess. 2007;11(41):iii-iv. ix. x. 1. 190. Excluded: wrong population. [pmid: 17927922].
Campochiaro PA, Heier JS, Feiner L, et al. Ranibizumab for macular edema following branch retinal vein occlusion: six-month primary end point results of a phase III study. Ophthalmology. 2010;117(6):1102-12.e1. Excluded: wrong population. [pmid: 20398941].
Carneiro AM, Falcao MS, Brandao EM, et al. Intravitreal bevacizumab for neovascular age-related macular degeneration with or without prior treatment with photodynamic therapy: one-year results. Retina. 2010;30(1):85-92. Excluded: wrong comparison (no control group). [pmid: 20010320].
Casparis H, Lindsley K, Kuo IC, et al. Surgery for cataracts in people with age-related macular degeneration. Cochrane Database Syst Rev. 2012;(7). Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication).
Caudill SP, Schleicher RL, Pirkle JL. Multi-rule quality control for the age-related eye disease study. Stat Med. 2008;27(20):4094-106. Excluded: wrong outcomes. [pmid: 18344178].
Chang JR, Koo E, Agron E, et al. Risk factors associated with incident cataracts and cataract surgery in the Age-related Eye Disease Study (AREDS): AREDS report number 32. Ophthalmology. 2011;118(11):2113-9. Excluded: wrong study design for Key Question. [pmid: 21684602].
Cheng KC, Wu WC, Lin CJ. Intravitreal triamcinolone acetonide for patients with macular oedema due to central retinal vein occlusion in Taiwan. Eye. 2009;23(4):849-57. Excluded: wrong population. [pmid: 18535613].
Chew EY, Clemons TE, Bressler SB, et al. Randomized trial of a home monitoring system for early detection of choroidal neovascularization home monitoring of the Eye (HOME) study. Ophthalmology. 2014;121(2):535-44. Excluded: wrong population. [pmid: 24211172].
Chiu CJ, Klein R, Milton RC, et al. Does eating particular diets alter the risk of age-related macular degeneration in users of the Age-Related Eye Disease Study supplements?. Br J Ophthalmol. 2009;93(9):1241-6. Excluded: wrong intervention. [pmid: 19508997].
Cho E, Stampfer MJ, Seddon JM, et al. Prospective study of zinc intake and the risk of age-related macular degeneration. Ann Epidemiol. 2001;11(5):328-36. Excluded: wrong study design for Key Question. [pmid: 11399447].
Chong EW, Wong TY, Kreis AJ, et al. Dietary antioxidants and primary prevention of age related macular degeneration: systematic review and meta-analysis. BMJ. 2007;335(7623):755. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 17923720].
Christen W, Glynn R, Manson JE, et al. Effects of multivitamin supplement on cataract and age-related macular degeneration in a randomized trial of male physicians. Ophthalmology. 2014;121(2):525-34. Excluded: wrong population. [pmid: 24268861].
Christen WG, Glynn RJ, Chew EY, et al. Low-dose aspirin and medical record-confirmed age-related macular degeneration in a randomized trial of women. Ophthalmology. 2009;116(12):2386-92. Excluded: wrong population. [pmid: 19815293].
Clemons TE, Rankin MW, McBee WL. Cognitive impairment in the Age-Related Eye Disease Study: AREDS report no. 16. Arch Ophthalmol. 2006;124(4):537-43. Excluded: wrong outcomes. [pmid: 16606880].
Cohen S-Y, Bourgeois H, Corbe C, et al. Randomized clinical trial France DMLA2: effect of trimetazidine on exudative and nonexudative age-relatedmacular degeneration. Retina. 2012;32(4):834-43. Excluded: wrong intervention. [pmid: 21822162].
Creuzot-Garcher C, Malvitte L, Sicard AC, et al. How to improve screening for diabetic retinopathy: the Burgundy experience. Diabetes Metab. 2010;36(2):114-9. Excluded: wrong study design for Key Question. [pmid: 20116317].
Cuadros J, Bresnick G. EyePACS: an adaptable telemedicine system for diabetic retinopathy screening. J Diabetes Sci Technol. 2009;3(3):509-16. Excluded: wrong outcomes. [pmid: 20144289].
Cumming RG, Ivers R, Clemson L, et al. Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175-81. Excluded: screening conducted by an optometrist. [pmid: 17302652].
Curriero FC, Pinchoff J, van Landingham SW, et al. Alteration of travel patterns with vision loss from glaucoma and macular degeneration. JAMA Ophthalmol. 2013;131(11):1420-6. Excluded: wrong study design for Key Question. [pmid: 24030033].
Curtis LH, Hammill BG, Qualls LG, et al. Treatment patterns for neovascular age-related macular degeneration: analysis of 284 380 Medicare beneficiaries. Am J Ophthalmol. 2012;153(6):1116-24.e1. Excluded: wrong study design for Key Question. [pmid: 22321802].
Curtis LH, Hammill BG, Schulman KA, et al. Risks of mortality, myocardial infarction, bleeding, and stroke associated with therapies for age-related macular degeneration. [Erratum appears in Arch Ophthalmol. 2010 Dec;128(12):1623]. Arch Ophthalmol. 2010;128(10):1273-9. Excluded: wrong comparison (no control group). [pmid: 20937996].
Davis MD, Sheetz MJ, Aiello LP, et al. Effect of ruboxistaurin on the visual acuity decline associated with long-standing diabetic macular edema. Invest Ophthalmol Vis Sci. 2009;50(1):1-4. Excluded: wrong population. [pmid: 18708615].
Day L, Fildes B, Gordon I, et al. Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. Excluded: wrong intervention. [pmid: 12130606].
Day S, Acquah K, Mruthyunjaya P, et al. Ocular complications after anti-vascular endothelial growth factor therapy in Medicare patients with age-related macular degeneration. Am J Ophthalmol. 2011;152(2):266-72. Excluded: wrong study design for Key Question. [pmid: 21664593].
de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. Excluded: wrong outcomes. [pmid: 11197445].
de Monchy I, Gendron G, Miceli C, et al. Combination of the Schirmer I and phenol red thread tests as a rescue strategy for diagnosis of ocular dryness associated with Sjogren’s syndrome. Invest Ophthalmol Vis Sci. 2011;52(8):5167-73. Excluded: wrong population. [pmid: 21546532].
de Saint Sardos A, Kamdeu Fansi A, Chagnon M, et al. Intraocular pressure adjusted for central corneal thickness as a screening tool for open-angle glaucoma in an at-risk population. Can J Ophthalmol. 2009;44(5):571-5. Excluded: wrong intervention. [pmid: 19789594].
de Silva SR, Riaz Y, Evans JR. Phacoemulsification with posterior chamber intraocular lens versus extracapsular cataract extraction (ECCE) with posterior chamber intraocular lens for age-related cataract. Cochrane Database Syst Rev. 2014;(1). Excluded: wrong intervention.
Dehghan MH, Ahmadieh H, Ramezani A, et al. A randomized, placebo-controlled clinical trial of intravitreal triamcinolone for refractory diabetic macular edema. Int Ophthalmol. 2008;28(1):7-17. Excluded: wrong population. [pmid: 17589809].
Desapriya E, Wijeratne H, Subzwari S, et al. Vision screening of older drivers for preventing road traffic injuries and fatalities. Cochrane Database Syst Rev. 2011;(3):CD006252. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 21412894].
Diabetic Retinopathy Clinical Research N. Randomized clinical trial evaluating intravitreal ranibizumab or saline for vitreous hemorrhage from proliferative diabetic retinopathy. JAMA Ophthalmol. 2013;131(3):283-93. Excluded: wrong population. [pmid: 23370902].
Diabetic Retinopathy Clinical Research N. Beck RW, Edwards AR, et al. Three-year follow-up of a randomized trial comparing focal/grid photocoagulation and intravitreal triamcinolone for diabetic macular edema. Arch Ophthalmol. 2009;127(3):245-51. Excluded: wrong population. [pmid: 19273785].
Diabetic Retinopathy Clinical Research N. Elman MJ, Aiello LP, et al. Randomized trial evaluating ranibizumab plus prompt or deferred laser or triamcinolone plus prompt laser for diabetic macular edema. Ophthalmology. 2010;117(6):1064-77.e35. Excluded: wrong population. [pmid: 20427088].
Diabetic Retinopathy Clinical Research N. Elman MJ, Qin H, et al. Intravitreal ranibizumab for diabetic macular edema with prompt versus deferred laser treatment: three-year randomized trial results. Ophthalmology. 2012;119(11):2312-8. Excluded: wrong population. [pmid: 22999634].
Dupas B, Walter T, Erginay A, et al. Evaluation of automated fundus photograph analysis algorithms for detecting microaneurysms, haemorrhages and exudates, and of a computer-assisted diagnostic system for grading diabetic retinopathy. Diabetes Metab. 2010;36(3):213-20. Excluded: wrong intervention. [pmid: 20219404].
Eandi CM, Giansanti F, Virgili G. Macular translocation for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;(4):CD006928. Excluded: wrong intervention. [pmid: 18843739].
Epstein DL, Algvere PV, von Wendt G, et al. Benefit from bevacizumab for macular edema in central retinal vein occlusion: twelve-month results of a prospective, randomized study. Ophthalmology. 2012;119(12):2587-91. Excluded: wrong population. [pmid: 22902212].
Evans J. Antioxidant supplements to prevent or slow down the progression of AMD: a systematic review and meta-analysis. Eye. 2008;22(6):751-60. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 18425071].
Evans JR. Ginkgo Biloba extract for age-related macular degeneration. Cochrane Database Syst Rev. 2013;1. Excluded: wrong intervention.
Evans JR, Sivagnanavel V, Chong V. Radiotherapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2010;(5). Excluded: wrong intervention.
Falck A, Kuoppala J, Winblad I, et al. The Pyhajarvi Cataract Study. I. Study design, baseline characteristics and the demand for cataract surgery. Acta Ophthalmol (Oxf). 2008;86(6):648-54. Excluded: wrong study design for Key Question.
Farley TF, Mandava N, Prall FR, et al. Accuracy of primary care clinicians in screening for diabetic retinopathy using single-image retinal photography. Ann Fam Med. 2008;6(5):428-34. Excluded: wrong population. [pmid: 18779547].
Fies P, Dienel A. Ginkgo extract in impaired vision - treatment with special extract EGb 761 of impaired vision due to dry seinle macular degneration. Wiener Medizinische Wochenschrift. 2002;152(15–16):423-6. Excluded: in systematic review, not directly used. [pmid: 12244891].
Fisher JB, Jacobs DA, Markowitz CE, et al. Relation of visual function to retinal nerve fiber layer thickness in multiple sclerosis. Ophthalmology. 2006;113(2):324-32. Excluded: wrong study design for Key Question. [pmid: 16406539].
Forte R, Cennamo G, Finelli ML, et al. Combination of flavonoids with Centella asiatica and Melilotus for diabetic cystoid macular edema without macular thickening. J Ocul Pharmacol Ther. 2011;27(2):109-13. Excluded: wrong population. [pmid: 21314440].
Francis BA, Varma R, Vigen C, et al. Population and high-risk group screening for glaucoma: the Los Angeles Latino Eye Study. Invest Ophthalmol Vis Sci. 2011;52(9):6257-64. Excluded: wrong population. [pmid: 21245400].
Frei A, Woitzek K, Wang M, et al. The chronic care for age-related macular degeneration study (CHARMED): study protocol for a randomized controlled trial. Trials. 2011;12:221. Excluded: wrong study design for Key Question. [pmid: 21985296].
French DD, Margo CE. Age-related macular degeneration, anti-vascular endothelial growth factor agents, and short-term mortality: a postmarketing medication safety and surveillance study. Retina. 2011;31(6):1036-42. Excluded: wrong study design for Key Question. [pmid: 21836410].
Friberg TR, Brennen PM, Freeman WR, et al. Prophylactic treatment of age-related macular degeneration report number 2: 810-nanometer laser to eyes with drusen: bilaterally eligible patients. Ophthalmic Surg Lasers Imaging. 2009;40(6):530-8. Excluded: wrong study design for Key Question. [pmid: 19928717].
Funk M, Karl D, Georgopoulos M, et al. Neovascular age-related macular degeneration: intraocular cytokines and growth factors and the influence of therapy with ranibizumab. Ophthalmology. 2009;116(12):2393-9. Excluded: wrong outcomes. [pmid: 19815292].
Funk M, Schmidinger G, Maar N, et al. Angiogenic and inflammatory markers in the intraocular fluid of eyes with diabetic macular edema and influence of therapy with bevacizumab. Retina. 2010;30(9):1412-9. Excluded: wrong population. [pmid: 20711086].
Garas A, Kothy P, Hollo G. Accuracy of the RTVue-100 Fourier-domain optical coherence tomograph in an optic neuropathy screening trial. Int Ophthalmol. 2011;31(3):175-82. Excluded: wrong population. [pmid: 21424554].
Garway-Heath DF, Lascaratos G, Bunce C, et al. The United Kingdom Glaucoma Treatment Study: a multicenter, randomized, placebo-controlled clinical trial: design and methodology. Ophthalmology. 2013;120(1):68-76. Excluded: wrong intervention. [pmid: 22986112].
Gehlbach P, Li T, Hatef E. Statins for age-related macular degeneration. Cochrane Database Syst Rev. 2012;(3). Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication).
Geltzer A, Turalba A, Vedula SS. Surgical implantation of steroids with antiangiogenic characteristics for treating neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2013;(1). Excluded: wrong intervention.
Gilles MC, Walton R, Arnold J, et al. Comparison of outcomes from a phase 3 study of age-related macular degeneration with a matched, observational cohort. Ophthalmology. 2014;121(3):676-81. Excluded: wrong comparison (no control group). [pmid: 24290801].
Gillies MC, Islam FMA, Larsson J, et al. Triamcinolone-induced cataract in eyes with diabetic macular oedema: 3-year prospective data from a randomized clinical trial. [Erratum appears in Clin Experiment Ophthalmol. 2010 Oct; 38(7):741. Clin Experiment Ophthalmol. 2010;38(6):605-12. Excluded: wrong population. [pmid: 20528977].
Gillies MC, McAllister IL, Zhu M, et al. Pretreatment with intravitreal triamcinolone before laser for diabetic macular edema: 6-month results of a randomized, placebo-controlled trial. Invest Ophthalmol Vis Sci. 2010;51(5):2322-8. Excluded: wrong population. [pmid: 20019369].
Grahn BH, Paterson PG, Gottschall-Pass KT, et al. Zinc and the eye. J Am Coll Nutr. 2001;20(2 Suppl):106-18. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 11349933].
Gritz DC, Srinivasan M, Smith SD, et al. The Antioxidants in Prevention of Cataracts Study: effects of antioxidant supplements on cataract progression in South India. Br J Ophthalmol. 2006;90(7):847-51. Excluded: wrong population. [pmid: 16556618].
Group AR. Chew EY, Clemons T, et al. The Age-Related Eye Disease Study 2 (AREDS2): study design and baseline characteristics (AREDS2 report number 1). Ophthalmology. 2012;119(11):2282-9. Excluded: wrong comparison (no control group). [pmid: 22840421].
Group TA-REDSR. The Age-Related Eye Disease Study: a clinical trial of zinc and antioxidants--Age-Related Eye Disease Study Report No. 2. J Nutr. 2000;130(5S Suppl):1516S-9S. Excluded: in systematic review, not directly used. [pmid: 10801969].
Guymer RH, Baird PN, Varsamidis M, et al. Proof of concept, randomized, placebo-controlled study of the effect of simvastatin on the course of age-related macular degeneration. PLoS ONE. 2013;8(12):e83759. Excluded: wrong intervention. [pmid: 24391822].
Guymer RH, Dimitrov PN, Varsamidis M, et al. Can HMG Co-A reductase inhibitors (“statins”) slow the progression of age-related macular degeneration? The age-related maculopathy statin study (ARMSS). Clin Interv Aging. 2008;3(3):581-93. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18982929].
Haller JA, Bandello F, Belfort R Jr, et al. Randomized, sham-controlled trial of dexamethasone intravitreal implant in patients with macular edema due to retinal vein occlusion. Ophthalmology. 2010;117(6):1134-46.e3. Excluded: wrong population. [pmid: 20417567].
Haran MJ, Cameron ID, Ivers RQ, et al. Effect on falls of providing single lens distance vision glasses to multifocal glasses wearers: VISIBLE randomised controlled trial. BMJ. 2010;340:c2265. Excluded: wrong comparison (no control group). [pmid: 20501583].
Haritoglou C, Gerss J, Hammes HP, et al. Alpha-lipoic acid for the prevention of diabetic macular edema. Ophthalmologica. 2011;226(3):127-37. Excluded: wrong population. [pmid: 21811051].
Haritoglou C, Gerss J, Sauerland C, et al. Effect of calcium dobesilate on occurrence of diabetic macular oedema (CALDIRET study): randomised, double-blind, placebo-controlled, multicentre trial. Lancet. 2009;373(9672):1364-71. Excluded: wrong population. [pmid: 19376452].
Heier JS, Campochiaro PA, Yau L, et al. Ranibizumab for macular edema due to retinal vein occlusions: long-term follow-up in the HORIZON trial. Ophthalmology. 2012;119(4):802-9. Excluded: wrong population. [pmid: 22301066].
Heijl A, Bengtsson B, Oskarsdottir SE. Prevalence and severity of undetected manifest glaucoma: results from the early manifest glaucoma trial screening. Ophthalmology. 2013;120(8):1541-5. Excluded: wrong comparison (no control group). [pmid: 23631945].
Hollands H, Johnson D, Hollands S, et al. Do findings on routine examination identify patients at risk for primary open-angle glaucoma? The rational clinical examination systematic review. JAMA. 2013;309(19):2035-42. Excluded: wrong population. [pmid: 23677315].
Honaker JA, Shepard NT. Use of the Dynamic Visual Acuity Test as a screener for community-dwelling older adults who fall. J Vestib Res. 2011;21(5):267-76. Excluded: wrong intervention. [pmid: 22101297].
Hornan DM, Madhusudhana KC, Newsom RSB. Optometric telemedicine: community-based screening for choroidal neovascularisation. Br J Ophthalmol. 2010;94(3):393-4. Excluded: wrong comparison (no control group). [pmid: 20215388].
Hudson HL, Lane SS, Heier JS, et al. Implantable miniature telescope for the treatment of visual acuity loss resulting from end-stage age-related macular degeneration: 1-year results. Ophthalmology. 2006;113(11):1987-2001. Excluded: wrong population. [pmid: 16989902].
Huna-Baron R, Glovinsky Y, Habot-Wilner Z. Comparison between Hardy-Rand-Rittler 4th edition and Ishihara color plate tests for detection of dyschromatopsia in optic neuropathy. Graefes Arch Clin Exp Ophthalmol. 2013;251(2):585-9. Excluded: wrong population. [pmid: 22688625].
Ichhpujani P, Rome JE, Jindal A, et al. Comparative study of 3 techniques to detect a relative afferent pupillary defect. J Glaucoma. 2011;20(9):535-9. Excluded: wrong population. [pmid: 20852433].
Ip MS, Oden NL, Scott IU, et al. SCORE Study report 3: study design and baseline characteristics. Ophthalmology. 2009;116(9):1770-7.e1. Excluded: wrong population. [pmid: 19619896].
Johnson EJ, Chung H-Y, Caldarella SM, et al. The influence of supplemental lutein and docosahexaenoic acid on serum, lipoproteins, and macular pigmentation. Am J Clin Nutr. 2008;87(5):1521-9. Excluded: wrong outcomes. [pmid: 18469279].
Joussen AM, Wong D, Walter P, et al. Surgical management of subfoveal choroidal neovascular membranes in age-related macular degeneration by macular relocation: experiences of an early-stopped randomised clinical trial (MARAN Study). Eye. 2010;24(2):284-9. Excluded: wrong intervention. [pmid: 19478822].
Kaiser PK. VIO Study Group. Verteporfin PDT for subfoveal occult CNV in AMD: two-year results of a randomized trial. Curr Med Res Opin. 2009;25(8):1853-60. Excluded: in systematic review, not directly used. [pmid: 19530976].
Kamdeu Fansi AA, Li G, Harasymowycz PJ. The validity of screening for open-angle glaucoma in high-risk populations with single-test screening mode frequency doubling technology perimetry (FDT). J Glaucoma. 2011;20(3):167-71. Excluded: wrong comparison (no control group). [pmid: 20436361].
Kemp A, Preen DB, Morlet N, et al. Myocardial infarction after intravitreal vascular endothelial growth factor inhibitors: a whole population study. Retina. 2013;33(5):920-7. Excluded: wrong comparison (no control group). [pmid: 23492942].
Kerr NM, Chew SSL, Eady EK, et al. Diagnostic accuracy of confrontation visual field tests. Neurology. 2010;74(15):1184-90. Excluded: wrong intervention. [pmid: 20385890].
Khandekar R, Al Raisi A. Oman Eye Study 2005: validity of screening tests used in the glaucoma survey. East Mediterr Health J. 2008;14(6):1360-4. Excluded: wrong population. [pmid: 19161111].
Khandekar R, Zutshi R, Ali M, et al. Influence of diabetes on the validity glaucoma screening by frequency doubling perimetry: a hospital-based study in Oman. Diabetes Technol Ther. 2008;10(4):278-82. Excluded: wrong intervention. [pmid: 18715201].
Kinge B, Stordahl PB, Forsaa V, et al. Efficacy of ranibizumab in patients with macular edema secondary to central retinal vein occlusion: results from the sham-controlled ROCC study. Am J Ophthalmol. 2010;150(3):310-4. Excluded: wrong population. [pmid: 20591399].
Klein R, Klein BE, Jensen SC, et al. Age-related maculopathy in a multiracial United States population: the National Health and Nutrition Examination Survey III. Ophthalmology. 1999;106(6):1056-65. Excluded: in systematic review, not directly used. [pmid: 10366071].
Koo E, Chang JR, Agron E, et al. Ten-year incidence rates of age-related cataract in the Age-Related Eye Disease Study (AREDS): AREDS report no. 33. Ophthalmic Epidemiol. 2013;20(2):71-81. Excluded: wrong outcomes. [pmid: 23510310].
Koss MJ, Kurz P, Tsobanelis T, et al. Prospective, randomized, controlled clinical study evaluating the efficacy of Rheopheresis for dry age-related macular degeneration. Dry AMD treatment with Rheopheresis Trial-ART. Graefes Arch Clin Exp Ophthalmol. 2009;247(10):1297-306. Excluded: wrong intervention. [pmid: 19629514].
Kurita N, Mayama C, Tomidokoro A, et al. Potential of the pentacam in screening for primary angle closure and primary angle closure suspect. J Glaucoma. 2009;18(7):506-12. Excluded: wrong intervention. [pmid: 19745665].
Kwon SI, Baek SU, Park IW. Comparison of natural course, intravitreal triamcinolone and macular laser photocoagulation for treatment of mild diabetic macular edema. Int J Med Sci. 2013;10(3):243-9. Excluded: wrong population. [pmid: 23372430].
Kwon SI, Kim YW, Bang YW, et al. Comparison of natural course, intravitreal triamcinolone, and intravitreal bevacizumab for treatment of macular edema secondary to branch retinal vein occlusion. J Ocul Pharmacol Ther. 2013;29(1):5-9. Excluded: wrong population. [pmid: 23237542].
Landa G, Butovsky O, Shoshani J, et al. Weekly vaccination with Copaxone (glatiramer acetate) as a potential therapy for dry age-related macular degeneration. Curr Eye Res. 2008;33(11):1011-3. Excluded: wrong outcomes. [pmid: 19085384].
Lawrenson JG, Evans JR. Omega 3 fatty acids for preventing or slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2012;(11). Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication).
Lebuisson DA, Leroy L, Rigal G. Treatment of senile macular degeneration with ginkgo biloba extract. A preliminary double-blind drug vs. placebo study. La Press Medicale. 1986;15(31):1556-8. Excluded: in systematic review, not directly used.
Lee BS, Munoz BE, West SK, et al. Functional improvement after one- and two-eye cataract surgery in the Salisbury Eye Evaluation. Ophthalmology. 2013;120(5):949-55. Excluded: wrong population. [pmid: 23357620].
Leffler CT, Davenport B, Rentz J, et al. Clinical predictors of the optimal spectacle correction for comfort performing desktop tasks. Clin Exp Optom. 2008;91(6):530-7. Excluded: wrong study design for Key Question. [pmid: 18537986].
Lim LS, Mitchell P, Seddon JM, et al. Age-related macular degeneration. Lancet. 2012;379(9827):1728-38. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 22559899].
Loewenstein JI, Palmberg PF, Connett JE, et al. Effectiveness of a pinhole method for visual acuity screening. Arch Ophthamol. 1985;103:222-3. Excluded: wrong population.
Loftus JV, Sultan MB, Pleil AM, et al. Changes in vision- and health-related quality of life in patients with diabetic macular edema treated with pegaptanib sodium or sham. Invest Ophthalmol Vis Sci. 2011;52(10):7498-505. Excluded: wrong population. [pmid: 21896838].
Lois N, McBain V, Abdelkader E, et al. Retinal pigment epithelial atrophy in patients with exudative age-related macular degeneration undergoing anti-vascular endothelial growth factor therapy. Retina. 2013;33(1):13-22. Excluded: wrong study design for Key Question. [pmid: 22846802].
Lord SR, Smith ST, Menant JC. Vision and falls in older people: risk factors and intervention strategies. Clin Geriatr Med. 2010;26(4):569-81. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20934611].
Lubinski W, Podboraczynska-Jodko K, Gronkowska-Serafin J, et al. Visual outcomes three and six months after implantation of diffractive and refractive multifocal IOL combinations. Klin Oczna. 2011;113(7–9):209-15. Excluded: wrong study design for Key Question. [pmid: 22256560].
Lubinski W, Podboraczynska-Jodko K, Gronkowska-Serafin J, et al. Visual outcome three and six months after implantation of Acri.LISA 366D lenses. Klin Oczna. 2012;114(4):249-54. Excluded: wrong study design for Key Question. [pmid: 23461149].
Luke M, Ziemssen F, Bartz-Schmidt KU, et al. Quality of life in a prospective, randomised pilot-trial of photodynamic therapy versus full macular translocation in treatment of neovascular age-related macular degeneration--a report of 1 year results. Graefes Arch Clin Exp Ophthalmol. 2007;245(12):1831-6. Excluded: wrong intervention. [pmid: 17347809].
Lundstrom M, Stenevi U, Thorburn W. Cataract surgery in the very elderly. J Cataract Refract Surg. 2000;26(3):408-14. Excluded: wrong study design for Key Question. [pmid: 10713238].
Ma L, Dou H-L, Huang Y-M, et al. Improvement of retinal function in early age-related macular degeneration after lutein and zeaxanthin supplementation: a randomized, double-masked, placebo-controlled trial. Am J Ophthalmol. 2012;154(4):625-34.e1. Excluded: wrong outcomes. [pmid: 22835510].
Macular Photocoagulation Study Group. Argon laser photocoagulation for senile macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1982;100(6):912-8. Excluded: in systematic review, not directly used. [pmid: 7046707].
Macular Photocoagulation Study Group. Krypton laser photocoagulation for neovascular lesions of age-related macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1990;108(6):816-24. Excluded: in systematic review, not directly used. [pmid: 1693496].
Macular Photocoagulation Study Group. Laser photocoagulation of subfoveal recurrent neovascular lesions in age-related macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1991;109(9):1232-41. Excluded: in systematic review, not directly used. [pmid: 1718251].
Macular Photocoagulation Study Group. Laser photocoagulation of subfoveal neovascular lesions in age-related macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1991;109(9):1220-31. Excluded: in systematic review, not directly used. [pmid: 1718250].
Mangione CM, Phillips RS, Lawrence MG, et al. Improved visual function and attenuation of declines in health-related quality of life after cataract extraction. Arch Opthalmol. 1994;112:1419-25. Excluded: wrong study design for Key Question.
Mares-Perlman JA, Klein R, Klein BE, et al. Association of zinc and antioxidant nutrients with age-related maculopathy. Arch Ophthalmol. 1996;114(8):991-7. Excluded: wrong study design for Key Question. [pmid: 8694736].
Mataix J, Desco MC, Palacios E, et al. Photodynamic therapy for age-related macular degeneration treatment: epidemiological and clinical analysis of a long-term study. Ophthalmic Surg Lasers Imaging. 2009;40(3):277-84. Excluded: wrong study design for Key Question. [pmid: 19485292].
Mathew MC, Ervin A-M, Tao J, et al. Antioxidant vitamin supplementation for preventing and slowing the progression of age-related cataract. Cochrane Database Syst Rev. 2012;6:CD004567. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 22696344].
McGwin G Jr, Owsley C, Gauthreaux S. The association between cataract and mortality among older adults. Ophthalmic Epidemiol. 2003;10(2):107-19. Excluded: in systematic review, not directly used. [pmid: 12660859].
McGwin G Jr, Scilley K, Brown J, et al. Impact of cataract surgery on self-reported visual difficulties: comparison with a no-surgery reference group. J Cataract Refract Surg. 2003;29(5):941-8. Excluded: in systematic review, not directly used. [pmid: 12781280].
McNeil JJ, Robman L, Tikellis G, et al. Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75-84. Excluded: in systematic review, not directly used. [pmid: 14711717].
Mekjavic PJ, Kraut A, Urbancic M, et al. Efficacy of 12-month treatment of neovascular age-related macular degeneration with intravitreal bevacizumab based on individually determined injection strategies after three consecutive monthly injections. Acta Ophthalmol (Oxf). 2011;89(7):647-53. Excluded: wrong study design for Key Question.
Melki SA, Safar A, Martin J, et al. Potential acuity pinhole: a simple method to measure potential visual acuity in patients with cataracts, comparison to potential acuity meter. Ophthalmology. 1999;106(7):1262-7. Excluded: wrong outcomes. [pmid: 10406603].
Meuleners LB, Hendrie D, Lee AH, et al. The effectiveness of cataract surgery in reducing motor vehicle crashes: a whole population study using linked data. Ophthalmic Epidemiol. 2012;19(1):23-8. Excluded: wrong study design for Key Question. [pmid: 22273356].
Meuleners LB, Lee AH, Ng JQ, et al. First eye cataract surgery and hospitalization from injuries due to a fall: a population-based study. J Am Geriatr Soc. 2012;60(9):1730-3. Excluded: wrong study design for Key Question. [pmid: 22882171].
Meuleners LB, Ng JQ, Fraser M, et al. Impact of gender on first eye cataract surgery and motor vehicle crash risk for older drivers. Clin Experiment Ophthalmol. 2012;40(6):591-6. Excluded: wrong comparison (no control group). [pmid: 22171634].
Michael Y, Lin J, Gold R, et al. Interventions to Prevent Falls in Older Adults: Systematic Evidence Review for the U.S. Preventative Services Task Force. 2009. Excluded: wrong intervention.
Mitchell P, Korobelnik JF, Lanzetta P, et al. Ranibizumab (Lucentis) in neovascular age-related macular degeneration: evidence from clinical trials. Br J Ophthalmol. 2010;94(1):2-13. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 19443462].
Moradian S, Faghihi H, Sadeghi B, et al. Intravitreal bevacizumab vs. sham treatment in acute branch retinal vein occlusion with macular edema: results at 3months (Report 1). Graefes Arch Clin Exp Ophthalmol. 2011;249(2):193-200. Excluded: wrong population. [pmid: 21337043].
Morris MS, Jacques PF, Chylack LT, et al. Intake of zinc and antioxidant micronutrients and early age-related maculopathy lesions. Ophthalmic Epidemiol. 2007;14(5):288-98. Excluded: wrong outcomes. [pmid: 17994438].
Muether PS, Hermann MM, Koch K, et al. Delay between medical indication to anti-VEGF treatment in age-related macular degeneration can result in a loss of visual acuity. Graefes Arch Clin Exp Ophthalmol. 2011;249(5):633-7. Excluded: wrong study design for Key Question. [pmid: 20865421].
National Eye Institute. Age-Related Eye Disease Study 2 (AREDS2): A Multi-center, randomized Trial of Lutein, Zeaxanthin, and Omega 3 Long-Chain Polyunsaturated Fatty Acids (Docosahexaenoic Acid [DHA] and Eicosapentaenoic Acid [EPA]) in Age-Related Macular Degeneration. 2009. Excluded: wrong comparison (no control group).
Newsome D, MS, NL, et al. Oral zinc in macular degeneration. Arch Ophthalmol. 1988;106(2):192-8. Excluded: in systematic review, not directly used. [pmid: 3277606].
Newsome DA. A randomized, prospective, placebo-controlled clinical trial of a novel zinc-monocysteine compound in age-related macular degeneration. Curr Eye Res. 2008;33(7):591-8. Excluded: in systematic review, not directly used. [pmid: 18600492].
Nongpiur ME, Sharma P. Horizontal Lang two-pencil test as a screening test for stereopsis and binocularity. Indian J Ophthalmol. 2010;58(4):287-90. Excluded: wrong outcomes. [pmid: 20534917].
Nuriyah Y, Ren X-T, Jiang L, et al. Comparison between ophthalmologists and community health workers in screening of shallow anterior chamber with oblique flashlight test. Chin Med Sci J. 2010;25(1):50-2. Excluded: wrong outcomes. [pmid: 20449954].
O’Dell BL. Role of zinc in plasma membrane function. J Nutr. 2000;130(5S Suppl):1432S-6S. Excluded: wrong outcomes. [pmid: 10801956].
Oliveira CM, Cristovao LM, Ribeiro ML, et al. Improved automated screening of diabetic retinopathy. Ophthalmologica. 2011;226(4):191-7. Excluded: wrong intervention. [pmid: 21865671].
Owsley C, McGwin G Jr, Stalvey BT, et al. Educating older African Americans about the preventive importance of routine comprehensive eye care. J Natl Med Assoc. 2008;100(9):1089-95. Excluded: wrong intervention. [pmid: 18807441].
Patino CM, Varma R, Azen SP, et al. The impact of change in visual field on health-related quality of life the los angeles latino eye study. Ophthalmology. 2011;118(7):1310-7. Excluded: wrong study design for Key Question. [pmid: 21458074].
Piermarocchi S, Saviano S, Parisi V, et al. Carotenoids in Age-related Maculopathy Italian Study (CARMIS): two-year results of a randomized study. Eur J Ophthalmol. 2012;22(2):216-25. Excluded: in systematic review, not directly used. [pmid: 22009916].
Prasad AS. Zinc deficiency in humans: a neglected problem. J Am Coll Nutr. 1998;17(6):542-3. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 9853531].
Pulido JS, Winters JL, Boyer D. Preliminary analysis of the final multicenter investigation of rheopheresis for age related macular degeneration (AMD) trial (MIRA-1) results. Transactions of the American Ophthalmological Society Vol. 2006;104:221-31. Excluded: in systematic review, not directly used.
Reddy U, Krzystolik M. Antiangiogenic therapy with interferon alfa for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1. Excluded: wrong intervention.
Rein DB, Wittenborn JS, Zhang X, et al. The cost-effectiveness of three screening alternatives for people with diabetes with no or early diabetic retinopathy. Health Serv Res. 2011;46(5):1534-61. Excluded: wrong study design for Key Question. [pmid: 21492158].
Renaud J, Levasseur M, Gresset J, et al. Health-related and subjective quality of life of older adults with visual impairment. Disabil Rehabil. 2010;32(11):899-907. Excluded: wrong study design for Key Question. [pmid: 19860601].
Renfro MO, Fehrer S. Multifactorial screening for fall risk in community-dwelling older adults in the primary care office: development of the fall risk assessment & screening tool. J Geriatr Phys Ther. 2011;34(4):174-83. Excluded: wrong study design for Key Question. [pmid: 22124417].
Richer S, Stiles W, Statkute L, et al. Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study (Lutein Antioxidant Supplementation Trial). Optometry. 2004;75(4):216-30. Excluded: in systematic review, not directly used. [pmid: 15117055].
Richer SP, Stiles W, Graham-Hoffman K, et al. Randomized, double-blind, placebo-controlled study of zeaxanthin and visual function in patients with atrophic age-related macular degeneration: the Zeaxanthin and Visual Function Study (ZVF) FDA IND #78, 973. Optometry. 2011;82(11):667-80.e6. Excluded: wrong comparison (no control group). [pmid: 22027699].
Rine RM, Roberts D, Corbin BA, et al. New portable tool to screen vestibular and visual function--National Institutes of Health Toolbox initiative. J Rehabil Res Dev. 2012;49(2):209-20. Excluded: wrong population. [pmid: 22773523].
Rogers DL, Neely DE, Chapman JB, et al. Comparison of the MTI Photoscreener and the Welch-Allyn SureSight autorefractor in a tertiary care center. J Aapos. 2008;12(1):77-82. Excluded: wrong population. [pmid: 18314072].
Sacu S, Michels S, Prager F, et al. Randomised clinical trial of intravitreal Avastin vs photodynamic therapy and intravitreal triamcinolone: long-term results. Eye. 2009;23(12):2223-7. Excluded: wrong comparison (no control group). [pmid: 19169239].
Schmidt-Erfurth U, Kaiser PK, Korobelnik JF, et al. Intravitreal aflibercept injection for neovascular age-related macular degeneration: ninety-six-week results of the VIEW studies. Ophthalmology. 2014;121(1):193-201. Excluded: wrong study design for Key Question. [pmid: 24084500].
Skelton DA, Howe TE, Ballinger C, et al. Environmental and behavioural interventions for reducing physical activity limitation in community-dwelling visually impaired older people. Cochrane Database Syst Rev. 2013;6:CD009233. Excluded: wrong intervention. [pmid: 23740610].
Snodderly DM. Evidence for protection against age-related macular degeneration by carotenoids and antioxidant vitamins. Am J Clin Nutr. 1995;62(6 Suppl):1448S-61S. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 7495246].
Solomon SD, Lindsley K, Vedula SS, et al. Anti-vascular endothelial growth factor for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2014;8:CD005139. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 25170575].
Souayah N, Khella SL. A prospective double-blind, placebo-controlled study of thalidomide sensory symptoms in an elderly population with age-related macular degeneration. J Clin Neurosci. 2010;17(5):571-3. Excluded: wrong intervention. [pmid: 20223672].
Stur M, Tittl M, Reitner A, et al. Oral zinc and the second eye in age-related macular degeneration. Invest Ophthalmol Vis Sci. 1996;37(7):1225-35. Excluded: in systematic review, not directly used. [pmid: 8641826].
Swamy B, Cumming RG, Ivers R, et al. Vision screening for frail older people: a randomised trial. Br J Ophthalmol. 2009;93(6):736-41. Excluded: screening conducted by an optometrist. [pmid: 18614568].
Swanson MW, Bodner E, Sawyer P, et al. Visual acuity’s association with levels of leisure-time physical activity in community-dwelling older adults. J Aging Phys Act. 2012;20(1):1-14. Excluded: wrong study design for Key Question. [pmid: 21945888].
Tan JS, Wang JJ, Flood V, et al. Dietary antioxidants and the long-term incidence of age-related macular degeneration: the Blue Mountains Eye Study. Ophthalmology. 2008;115(2):334-41. Excluded: wrong study design for Key Question. [pmid: 17664009].
Teikari JM, Rautalahti M, Haukka J, et al. Incidence of cataract operations in Finnish male smokers unaffected by alpha tocopherol or beta carotene supplements. J Epidemiol Community Health. 1998;52(7):468-72. Excluded: wrong population. [pmid: 9799882].
Thatch AB, Yau L, Hoang C, et al. Time to clinically significant visual acuity gains after ranibizumab treatment for retinal vein occlusion: BRAVO and CRUISE trials. Ophthalmology. 2014;121(5):1059-66. Excluded: wrong population. [pmid: 24424249].
Tielsch JM, Sommer A, Witt K, et al. Blindness and visual impairment in an American urban population. The Baltimore Eye Survey. Arch Ophthalmol. 1990;108(2):286-90. Excluded: wrong outcomes. [pmid: 2271016].
Tseng VL, Yu F, Lum F, et al. Risk of fractures following cataract surgery in Medicare beneficiaries. JAMA. 2012;308(5):493-501. Excluded: wrong population. [pmid: 22851116].
Tufail A, Patel PJ, Egan C, et al. Bevacizumab for neovascular age related macular degeneration (ABC Trial): multicentre randomised double masked study. Bmj. 2010;340. Excluded: wrong comparison (no control group).
Vallance JH, Johnson B, Majid MA, et al. A randomised prospective double-masked exploratory study comparing combination photodynamic treatment and intravitreal ranibizumab vs intravitreal ranibizumab monotherapy in the treatment of neovascular age-related macular degeneration. Eye (London, England). 2010;24(10):1561-7. Excluded: wrong comparison (no control group).
van der Made S, Kelly ER, Berendschot TT, et al. Consuming a buttermilk drink containing lutein-enriched egg yolk daily for 1 year increased plasma lutein but did not affect serum lipid or lipoprotein concentrations in adults with early signs of age-related macular degeneration. J Nutr. 2014;144(9):1370-7. Excluded: wrong outcomes. [pmid: 24991045].
van Leeuwen R, Boekhoorn S, Vingerling JR, et al. Dietary intake of antioxidants and risk of age-related macular degeneration. JAMA. 2005;294(24):3101-7. Excluded: wrong study design for Key Question. [pmid: 16380590].
VandenLangenberg GM, Mares-Perlman JA, Klein R, et al. Associations between antioxidant and zinc intake and the 5-year incidence of early age-related maculopathy in the Beaver Dam Eye Study. Am J Epidemiol. 1998;148(2):204-14. Excluded: wrong study design for Key Question. [pmid: 9676703].
Vedula SS, Krzystolik MG. Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;(2). Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication).
VIM Study Group. Verteporfin therapy in subfoveal minimally classis choroidal neovascularization in age-related macular degeneration. Arch Ophthalmol. 2005;123:448-57. Excluded: in systematic review, not directly used. [pmid: 15824216].
VIP Study Group. Photodynamic therapy of subfoveal choroidal neovascularization in pathologic myopia with verteporfin. Ophthalmology. 2001;108:841-52. Excluded: in systematic review, not directly used. [pmid: 11320011].
Vishwanathan R, Chung M, Johnson EJ. A systematic review on zinc for the prevention and treatment of age-related macular degeneration. Invest Ophthalmol Vis Sci. 2013;54(6):3985-98. Excluded: using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication). [pmid: 23652490].
Weigert G, Kaya S, Pemp B, et al. Effects of lutein supplementation on macular pigment optical density and visual acuity in patients with age-related macular degeneration. Invest Ophthalmol Vis Sci. 2011;52(11):8174-8. Excluded: in systematic review, not directly used. [pmid: 21873668].
West SK, Rubin GS, Broman AT, et al. How does visual impairment affect performance on tasks of everyday life? The SEE Project. Salisbury Eye Evaluation. Arch Ophthalmol. 2002;120(6):774-80. Excluded: wrong study design for Key Question. [pmid: 12049583].
Wolf S, Holz FG, Korobelnik J-F, et al. Outcomes following three-line vision loss during treatment of neovascular age-related macular degeneration: subgroup analyses from MARINA and ANCHOR. Br J Ophthalmol. 2011;95(12):1713-8. Excluded: wrong outcomes. [pmid: 21951567].
Writing Committee for the UKA-RMDEMRUG. The neovascular age-related macular degeneration database: multicenter study of 92976 ranibizumab injections: report 1: visual acuity. Ophthalmology. 2014;121(5):1092-101. Excluded: wrong comparison (no control group). [pmid: 24461586].
Writing Group for the ARG. Effect of long-chain -3 fatty acids and lutein + zeaxanthin supplements on cardiovascular outcomes: results of the Age-Related Eye Disease Study 2 (AREDS2) randomized clinical trial. JAMA Intern Med. 2014;174(5):763-71. Excluded: wrong comparison (no control group). [pmid: 24638908].
Yehoshua Z, de Amorim Garcia Filho CA, Nunes RP, et al. Systemic complement inhibition with eculizumab for geographic atrophy in age-related macular degeneration: the COMPLETE study. Ophthalmology. 2014;121(3):693-701. Excluded: wrong outcomes. [pmid: 24289920].

## Appendix A5 USPSTF Quality Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The Methods Work Group for the US Preventive Services Task Force (USPSTF) developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria, and the associated definitions of quality categories, that relate to internal validity at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter. Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used.
- Standard appraisal of included studies.
- Validity of conclusions.
- Recency and relevance are especially important for systematic reviews.

#### Definition of ratings from above criteria

Good: | Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.
Fair: | Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.
Poor: | Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### Randomized Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variables.

#### Definition of ratings based on criteria above

Good: | Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
Fair: | Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
Poor: | Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, adequately described.
- Study uses a credible reference standard, performed regardless of test results.
- Reference standard interpreted independently of screening test.
- Handles indeterminate results in a reasonable manner.
- Spectrum of patients included in study.
- Sample size.
- Administration of reliable screening test.

#### Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: | Has fatal flaw such as: Uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum of patients.

Source: Procedure Manual. U.S. Preventive Services Task Force Procedure Manual. Available at: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.

## Appendix A6 Expert Reviewers of the Draft Report

### Content Experts

- Neil M. Bressler, MD
  Professor of Ophthalmology, Chief, Retina Division, Wilmer Eye Institute, Johns Hopkins University School of Medicine, Baltimore, Maryland
- Zahra Jessa, PhD, BSc, MCOptom
  Moorfields Eye Hospital, Action for Blind People, Royal National Institute of Blind People, London, England
- Liam Smeeth, MBChB, FRCGP, FFPH, FRCP, MSc, PhD
  Professor, London School of Hygiene and Tropical Medicine, London, England
- Gianni Virgili, MD
  Associate Professor of Ophthalmology, Careggi Hospital Eye Clinic, University of Florence, Italy
- Nancy Weintraub, MD
  Health Science Professor, Geriatric Medicine Fellowship Director, David Geffen School of Medicine at University of California at Los Angeles, California

### Federal Partners

- Food and Drug Administration/Center for Drug Evaluation and Research
- National Institute on Aging/National Institutes of Health
- Veteran’s Health Administration