# References

1 Wolfe JN. Breast patterns as an index of risk for developing breast cancer. AJR Am J Roentgenol. 1976;126(6):1130-7. [pmid: 179369].
2 Byng JW, Boyd NF, Fishell E, Jong RA, Yaffe MJ. The quantitative analysis of mammographic densities. Phys Med Biol. 1994;39(10):1629-38. [pmid: 15551535].
3 Burnside ES, Sickles EA, Bassett LW, Rubin DL, Lee CH, Ikeda DM, et al. The ACR BI-RADS experience: learning from history. J Am Coll Radiol. 2009;6(12):851-60. [pmid: 19945040].
4 American College of Radiology. Breast Imaging Reporting and Data System (BI-RADS). Reston, VA. American College of Radiology. 1992.
5 Sickles E, D'Orsi C, Bassett LW, et al. ACR BI-RADS® Mammography. ACR BI-RADS® Atlas, Breast Imaging and Reporting Data System. Reston, VA. American College of Radiology. 2013.
6 Vachon CM, van Gils CH, Sellers TA, Ghosh K, Pruthi S, Brandt KR, et al. Mammographic density, breast cancer risk and risk prediction. Breast Cancer Res. 2007;9(6):217. [pmid: 18190724].
7 Sprague BL, Gangnon RE, Burt V, Trentham-Dietz A, Hampton JM, Wellman RD, et al. Prevalence of mammographically dense breasts in the United States. J Natl Cancer Inst. 2014;106(10). [pmid: 25217577].
8 Kerlikowske K, Zhu W, Tosteson AN, Sprague BL, Tice JA, Lehman CD, et al. Identifying women with dense breasts at high risk for interval cancer: a cohort study. Ann Intern Med. 2015;162(10):673-81. [pmid: 25984843].
9 Mousa A, Ryan E, Mello-Thoms C, Brennan P. What effect does mammographic breast density have on lesion detection in digital mammography?. Clin Radiol. 2014;69(4):333-41. [pmid: 24424328].
10 Boyd NF, Byng JW, Jong RA, Fishell EK, Little LE, Miller AB, et al. Quantitative Classification of Mammographic Densities and Breast Cancer Risk: Results From the Canadian National Breast Screening Study. J Natl Cancer Inst. 1995;87(9):670-5. [pmid: 7752271].
11 Boyd NF, Lockwood GA, Byng JW, Tritchler DL, Yaffe MJ. Mammographic densities and breast cancer risk. Cancer Epidemiol Biomarkers Prev. 1998;7(12):1133-44. [pmid: 9865433].
12 Byrne C, Schairer C, Wolfe J, Parekh N, Salane M, Brinton LA, et al. Mammographic features and breast cancer risk: effects with time, age, and menopause status. J Natl Cancer Inst. 1995;87(21):1622-9. [pmid: 7563205].
13 McCormack VA, dos Santos Silva I. Breast Density and Parenchymal Patterns as Markers of Breast Cancer Risk: A Meta-analysis. Cancer Epidemiol Biomarkers Prev. 2006;15(6):1159-69. [pmid: 16775176].
14 Price ER, Hargreaves J, Lipson JA, Sickles EA, Brenner RJ, Lindfors KK, et al. The California breast density information group: a collaborative response to the issues of breast density, breast cancer risk, and breast density notification legislation. Radiology. 2013;269(3):887-92. [pmid: 24023072].
15 Pettersson A, Graff RE, Ursin G, Santos Silva ID, McCormack V, Baglietto L, et al. Mammographic density phenotypes and risk of breast cancer: a meta-analysis. J Natl Cancer Inst. 2014;106(5). [pmid: 24816206].
16 Gierach GL, Ichikawa L, Kerlikowske K, Brinton LA, Farhat GN, Vacek PM, et al. Relationship between mammographic density and breast cancer death in the Breast Cancer Surveillance Consortium. J Natl Cancer Inst. 2012;104(16):1218-27. [pmid: 22911616].
17 Carmona-Sanchez E, Cuadros Lopez JL, Cuadros Celorrio AM, Perez-Roncero G, Gonzalez Ramirez AR, Fernandez Alonso AM. Assessment of mammographic density in postmenopausal women during long term hormone replacement therapy. Gynecol Endocrinol. 2013;29(12):1067-70. [pmid: 24004297].
18 Hou N, Hong S, Wang W, Olopade OI, Dignam JJ, Huo D. Hormone replacement therapy and breast cancer: heterogeneous risks by race, weight, and breast density. J Natl Cancer Inst. 2013;105(18):1365-72. [pmid: 24003037].
19 Tice JA, Cummings SR, Smith-Bindman R, Ichikawa L, Barlow WE, Kerlikowske K. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337-47. [pmid: 18316752].
20 Del Carmen MG, Hughes KS, Halpern E, Rafferty E, Kopans D, Parisky YR, et al. Racial differences in mammographic breast density. Cancer. 2003;98(3):590-6. [pmid: 12879477].
21 McCormack VA, Perry N, Vinnicombe SJ, Silva Idos S. Ethnic variations in mammographic density: a British multiethnic longitudinal study. Am J Epidemiol. 2008;168(4):412-21. [pmid: 18621673].
22 Centers for Disease Control and Prevention. Breast Cancer Rates by Race and Ethnicity. 2014. March 3, 2015. Available from: http://www.cdc.gov/cancer/breast/statistics/race.htm.
23 Kuhl CK, Schrading S, Strobel K, Schild HH, Hilgers RD, Bieling HB. Abbreviated Breast Magnetic Resonance Imaging (MRI): First Postcontrast Subtracted Images and Maximum-Intensity Projection-A Novel Approach to Breast Cancer Screening With MRI. J Clin Oncol. 2014;32(22):2304-10. [pmid: 24958821].
24 Saslow D, Boetes C, Burke W, Harms S, Leach MO, Lehman CD, et al. American Cancer Society guidelines for breast screening with MRI as an adjunct to mammography. CA Cancer Journal for Clinicians. 2007;57(2):75-89. [pmid: 17392385].
25 Mainiero MB, Lourenco A, Mahoney MC, Newell MS, Bailey L, Barke LD, et al. ACR Appropriateness Criteria Breast Cancer Screening. J Am Coll Radiol. 2013;10(1):11-4. [pmid: 23290667].
26 Lee SH, Im RJ, Yoon CS, Hur MH, Lee HK, Kang SS, et al. Initial experience of breast specific gamma imaging (BSGI) in Asia. European Journal of Cancer, Supplement. 2010;8(3):238.
27 Gur D, Zuley ML, Anello MI, Rathfon GY, Chough DM, Ganott MA, et al. Dose reduction in digital breast tomosynthesis (DBT) screening using synthetically reconstructed projection images: an observer performance study. Acad Radiol. 2012;19(2):166-71. [pmid: 22098941].
28 Feng SS, Sechopoulos I. Clinical digital breast tomosynthesis system: dosimetric characterization. Radiology. 2012;263(1):35-42. [pmid: 22332070].
29 Olgar T, Kahn T, Gosch D. Average glandular dose in digital mammography and breast tomosynthesis. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2012;184(10):911-8. [pmid: 22711250].
30 Skaane P, Bandos AI, Gullien R, Eben EB, Ekseth U, Haakenaasen U, et al. Comparison of digital mammography alone and digital mammography plus tomosynthesis in a population-based screening program. Radiology. 2013;267(1):47-56. [pmid: 23297332].
31 Gur D, Zuley ML, Anello MI, Rathfon GY, Chough DM, Ganott MA, et al. Dose reduction in digital breast tomosynthesis (DBT) screening using synthetically reconstructed projection images: an observer performance study. Acad Radiol. 2012;19(2):166-71. [pmid: 22098941].
32 Zuley ML, Guo B, Catullo VJ, Chough DM, Kelly AE, Lu AH, et al. Comparison of Two-dimensional synthesized Mammograms versus Original Digital Mammograms alone and in combination with Tomosynthesis images. Radiology. 2014;271(3):664-71. [pmid: 24475859].
33 Skaane P, Bandos AI, Eben EB, Jebsen IN, Krager M, Haakenaasen U, et al. Two-View Digital Breast Tomosynthesis Screening with Synthetically Reconstructed Projection Images: Comparison with Digital Breast Tomosynthesis with Full-Field Digital Mammographic Images. Radiology. 2014;271(3):655-63. [pmid: 24484063].
34 National Comprehensive Cancer Network (NCCN). Breast Cancer Screening and Diagnosis. 2014. October 10, 2014. Available from: http://www.nccn.org/professionals/physician_gls/pdf/breast-screening.pdf.
35 American Cancer Society (ACS). American Cancer Society Recommendations for Early Breast Cancer Detection in Women Without Breast Symptoms. 2014. October 7, 2014. Available from: http://www.cancer.org/cancer/breastcancer/moreinformation/breastcancerearlydetection/breast-cancer-early-detection-acs-recs.
36 American College of Obstetricians and Gynecologists. Committee Opinion No. 625: Management of Women With Dense Breasts Diagnosed by Mammography. Obstet Gynecol. 2015;125(3):750-1. [pmid: 25730253].
37 Are you Dense? Advocacy. D.E.N.S.E. ® State Efforts. 2014. October 7, 2014. Available from: http://www.areyoudenseadvocacy.org/dense/.
38 77th Oregon Legislative Assembly. SB 420. 2013. January 2015. Available from: https://olis.leg.state.or.us/liz/2013R1/Downloads/MeasureDocument/SB420/Enrolled.
39 Illinois General Assembly. (215 ILCS 5/356g) Sec. 356g. Mammograms; mastectomies. October 10, 2014. Available from: http://www.ilga.gov/legislation/ilcs/documents/021500050k356g.htm.
40 The State of Connecticut. Public Act No. 09.41. An Act Requiring Communication of Mammographic Breast Density Information to Patients. 2009. October 10, 2014. Available from: http://www.cga.ct.gov/2009/ACT/PA/2009PA-00041-R00SB-00458-PA.htm.
41 New Jersey 215th Legislature. An Act Concerning Mammograms, amending P.L. 1991, c.279 and P.L.2004, c.86, and supplementing Title 26 of the Revised Statutes and P.L.2003, c.193. 2014. October 10, 2014. Available from: http://www.njleg.state.nj.us/2012/Bills/PL13/196_.PDF.
42 Indiana 118th General Assembly. Senate Enrolled Act No. 414. An Act to amend the Indiana Code concerning insurance. 2013. October 10, 2014. Available from: http://www.in.gov/legislative/bills/2013/PDF/SE/SE0414.1.pdf.
43 Alkhenizan A, Hussain A, Alsayed A. The sensitivity and specificity of screening mammography in primary care setting in Saudi Arabia. J Clin Oncol. 2013;31(15). PMID:.
44 Allen MW, Hendi P, Bassett L, Phelps ME, Gambhir SS. A study on the cost effectiveness of sestamibi scintimammography for screening women with dense breasts for breast cancer. (Structured abstract). Breast Cancer Res Treat. [serial on the Internet]. [cited Database Search. 1999;55(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-21999001689/frame.html.
45 Screening for breast cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(10):716-26. w-236. [pmid: 19920272].
46 U.S. Food and Drug Administration. Radiation-Emitting Products: MQSA National Statistics. 2015. January 29, 2015. Available from: http://www.fda.gov/Radiation-EmittingProducts/MammographyQualityStandardsActandProgram/FacilityScorecard/ucm113858.htm.
47 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
48 U.S. Preventive Services Taskforce. U.S. Preventive Services Taskforce Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. 2013.
49 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
50 Lucas NP, Macaskill P, Irwig L, Bogduk N. The development of a quality appraisal tool for studies of diagnostic reliability (QAREL). J Clin Epidemiol. 2010;63(8):854-61. [pmid: 20056381].
51 Clopper CJ, Pearson ES. The Use of Confidence or Fiducial Limits Illustrated in the Case of the Binomial. Biometrika. 1934;26(4):404-13.
52 Brown LD, Cai TT, DasGupta A. Interval Estimation for a Binomial Proportion. Statistical Science. 2001;16(2):101-17.
53 Melnikow J, Fenton J, DL M, Whitlock E, Weyrich M. Screening for Breast Cancer with Digital Breast Tomosynthesis. Rockville MD. Agency for Healthcare Research and Qualityin press.
54 Miglioretti D, Lange J, van Ravesteyn N, van den Broek J, Lee C, Melnikow J, et al. Radiation-Induced Breast Cancer and Breast Cancer Death from Mammography Screening. Rockville, MD. Agency on Healthcare Research and Quality in press.
55 Harvey JA, Gard CC, Miglioretti DL, Yankaskas BC, Kerlikowske K, Buist DS, et al. Reported mammographic density: film-screen versus digital acquisition. Radiology. 2013;266(3):752-8. [pmid: 23249570].
56 Spayne MC, Gard CC, Skelly J, Miglioretti DL, Vacek PM, Geller BM. Reproducibility of BI-RADS breast density measures among community radiologists: a prospective cohort study. Breast J. 2012;18(4):326-33. [pmid: 22607064].
57 Gard CC, Bowles EJA, Miglioretti DL, Taplin SH, CM R. Misclassification of Breast Imaging Reporting and Data System (BI-RADS) mammographic density and implications for breast density reporting legislation. Breast J. 2015. epub ahead of print.
58 Redondo A, Comas M, Macia F, Ferrer F, Murta-Nascimento C, Maristany MT, et al. Inter-and intraradiologist variability in the BI-RADS assessment and breast density categories for screening mammograms. Br J Radiol. 2012;85(1019):1465-70. [pmid: 22993385].
59 Bernardi G, Cavallaro G, Indinnimeo M, Fiore A, Basso L, D'Ermo G, et al. Usefulness of ultrasounds in the management of breast phyllodes tumors. Il Giornale di chirurgia. 2012;33(3):81-5. [pmid: 22525552].
60 Spayne MC, Gard CC, Skelly J, Miglioretti DL, Vacek PM, Geller BM. Reproducibility of BI-RADS breast density measures among community radiologists: a prospective cohort study. Breast Journal. 2012;18(4):326-33. [pmid: 22607064].
61 Berg WA, Zhang Z, Lehrer D, Jong RA, Pisano ED, Barr RG, et al. Detection of breast cancer with addition of annual screening ultrasound or a single screening MRI to mammography in women with elevated breast cancer risk. JAMA. 2012;307(13):1394-404. [pmid: 22474203].
62 Corsetti V, Houssami N, Ghirardi M, Ferrari A, Speziani M, Bellarosa S, et al. Evidence of the effect of adjunct ultrasound screening in women with mammography-negative dense breasts: interval breast cancers at 1 year follow-up. Eur J Cancer. 2011;47(7):1021-6. [pmid: 21211962].
63 Hooley RJ, Greenberg KL, Stackhouse RM, Geisel JL, Butler RS, Philpotts LE. Screening US in patients with mammographically dense breasts: initial experience with Connecticut Public Act 09-41. Radiology. 2012;265(1):59-69. [pmid: 22723501].
64 Leong LC, Gogna A, Pant R, Ng FC, Sim LS. Supplementary breast ultrasound screening in Asian women with negative but dense mammograms-a pilot study. Ann Acad Med Singapore. 2012;41(10):432-9. [pmid: 23138139].
65 Youk JH, Kim EK, Kim MJ, Kwak JY, Son EJ. Performance of hand-held whole-breast ultrasound based on BI-RADS in women with mammographically negative dense breast. Eur Radiol. 2011;21(4):667-75. [pmid: 20853108].
66 Kelly KM, Dean J, Comulada WS, Lee SJ. Breast cancer detection using automated whole breast ultrasound and mammography in radiographically dense breasts. Eur Radiol. 2010;20(3):734-42. [pmid: 19727744].
67 Giuliano V, Giuliano C. Improved breast cancer detection in asymptomatic women using 3D-automated breast ultrasound in mammographically dense breasts. Clin Imaging. 2013;37(3):480-6. [pmid: 23116728].
68 Kriege M, Brekelmans CT, Obdeijn IM, Boetes C, Zonderland HM, Muller SH, et al. Factors affecting sensitivity and specificity of screening mammography and MRI in women with an inherited risk for breast cancer. Breast Cancer Res Treat. 2006;100(1):109-19. [pmid: 16791481].
69 Brancato B, Bonardi R, Catarzi S, Iacconi C, Risso G, Taschini R, et al. Negligible advantages and excess costs of routine addition of breast ultrasonography to mammography in dense breasts. Tumori. 2007;93(6):562-6. [pmid: 18338490].
70 Girardi V, Tonegutti M, Ciatto S, Bonetti F. Breast ultrasound in 22,131 asymptomatic women with negative mammography. Breast. 2013;22(5):806-9. [pmid: 23558244].
71 Parris T, Wakefield D, Frimmer H. Real world performance of screening breast ultrasound following enactment of Connecticut Bill 458. Breast J. 2013;19(1):64-70. [pmid: 23240937].
72 Venturini E, Losio C, Panizza P, Rodighiero MG, Fedele I, Tacchini S, et al. Tailored breast cancer screening program with microdose mammography, US, and MR Imaging: short-term results of a pilot study in 40-49-year-old women. Radiology. 2013;268(2):347-55. [pmid: 23579052].
73 Weigert J, Steenbergen S. The connecticut experiment: the role of ultrasound in the screening of women with dense breasts. Breast J. 2012;18(6):517-22. [pmid: 23009208].
74 Brem RF, Tabar L, Duffy SW, Inciardi MF, Guingrich JA, Hashimoto BE, et al. Assessing improvement in detection of breast cancer with three-dimensional automated breast US in women with dense breast tissue: The somoinsight study. Radiology. 2015;274(3):663-73. [pmid: 25329763].
75 McCarthy AM, Kontos D, Synnestvedt M, Tan KS, Heitjan DF, Schnall M, et al. Screening outcomes following implementation of digital breast tomosynthesis in a general-population screening program. J Natl Cancer Inst. 2014;106(11). [pmid: 25313245].
76 Haas BM, Kalra V, Geisel J, Raghu M, Durand M, Philpotts LE. Comparison of tomosynthesis plus digital mammography and digital mammography alone for breast cancer screening. Radiology. 2013;269(3):694-700. [pmid: 23901124].
77 Rose SL, Tidwell AL, Bujnoch LJ, Kushwaha AC, Nordmann AS, Sexton R Jr. Implementation of breast tomosynthesis in a routine screening practice: an observational study. AJR American Journal of Roentgenology. 2013;200(6):1401-8. [pmid: 23701081].
78 Ciatto S, Houssami N, Bernardi D, Caumo F, Pellegrini M, Brunelli S, et al. Integration of 3D digital mammography with tomosynthesis for population breast-cancer screening (STORM): a prospective comparison study. The Lancet Oncology. 2013;14(7):583-9. [pmid: 23623721].
79 Kriege M, Brekelmans CT, Boetes C, Besnard PE, Zonderland HM, Obdeijn IM, et al. Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. 2004;351(5):427-37. [pmid: 15282350].
80 Bottorff JL, Ratner PA, Johnson JL, Hislop TG, Buxton JA, Zeisser C, et al. Women's responses to information on mammographic breast density. Can J Nurs Res. 2007;39(1):38-57. [pmid: 17450704].
81 Nelson HD, Cantor A, Humphrey L, Fu R, Pappas M, Daeges M, et al. Screening for Breast Cancer: A Systematic Reviw to Update the 2009. U.S. Preventive Services Task Force Recommendation. Rockville, MD. Agency For Healthcare Research and Quality. 2015.
82 Crownover BK, Bepko JL. Appropriate and safe use of diagnostic imaging. Am Fam Physician. 2013;87(7):494-501. [pmid: 23547591].
83 Perazella MA. Current status of gadolinium toxicity in patients with kidney disease. Clin J Am Soc Nephrol. 2009;4(2):461-9. [pmid: 19201920].
84 Besheli LD, Aran S, Shaqdan K, Kay J, Abujudeh H. Current status of nephrogenic systemic fibrosis. Clin Radiol. 2014;69(7):661-8. [pmid: 24582176].
85 American College of Radiology. ACR Statement on Reporting Breast Density in Mammography Reports and Patient Summaries. April. 24. 2012. October 10, 2014. Available from: http://www.acr.org/About-Us/Media-Center/Position-Statements/Position-Statements-Folder/Statement-on-Reporting-Breast-Density-in-Mammography-Reports-and-Patient-Summaries.
86 Schousboe JT, Kerlikowske K, Loh A, Cummings SR. Personalizing mammography by breast density and other risk factors for breast cancer: analysis of health benefits and cost-effectiveness. Ann Intern Med. 2011;155(1):10-20. [pmid: 21727289].