# Discussion

## Summary of Evidence

We conducted this systematic review to assist the USPSTF in consideration of a recommendation regarding supplemental breast cancer screening after negative mammography for women found to have dense breasts (Table 23). While there are other important risk factors for breast cancer, some with higher relative risks, breast density is unique in that many states have mandated direct-to-consumer communication of mammographic breast density findings. This raises questions for women and their doctors about the interpretation of screening results and the need for additional testing. This review examined the accuracy and reproducibility of BI-RADS determination of breast density. Evidence was also reviewed on test performance characteristics and breast cancer detection rates, interval cancer rates, and rates of recall and biopsy for specific supplemental screening modalities (hand-held ultrasound [HHUS], automated whole breast ultrasound [ABUS], magnetic resonance imaging [MRI], and digital breast tomosynthesis [DBT]). The sparse evidence on the harms associated with breast density notification was summarized.

Table 23 Summary of the Evidence

Key Question(s) | # of Studies (k) | Design | Major Limitations | Consistency | Applicability | Overall Evidence | Summary of Findings
KQ 1. What is the accuracy and inter-rater reliability of BI-RADS determination of breast density? | k=5 | Registry-based studies; test sets | Community practice data may be criticized for representing older practice Some of the reclassifications found in the registry data may appropriately reflect actual physiological changes reflected in breast density, however it is unlikely given selection criteria and relatively short time frames for re-examination | Relatively consistent | Two studies were conducted in Spain and Italy One U.S.-based study was conducted within a single healthcare system, so results may underestimate variability in a more diverse population of radiologists | 2 good; 3 fair Overall: Fair to good | Results suggest that 1 in 5 women would be categorized into a different BI-RADS density category (dense to non-dense) by the same radiologist after the second screening exam, while 1 in 3 would be recategorized after a second exam read by a different radiologist Reducing variability through the use of double reading with consensus, along with introducing standards and quality measures, may minimize possible harms associated with variation in breast density categorizations
KQ 2. What are the test performance characteristics of newer technologies for breast cancer screening when used as supplemental tests after a negative screening mammography exam in women found to have dense breasts and how do these performance characteristics differ by age and risk factors? | HHUS k=5 | Test performance | Most studies not exclusively screening populations Only 1 good-quality study from the US Some had unclear followup protocols for negative results | 2 good-quality studies gave more consistent estimates of sensitivity and specificity, fair-quality studies had more variability | HHUS is somewhat operator dependent which may limit generalizability of results | 2 good; 3 fair Overall: fair | From good-quality studies for invasive breast cancer: Sens.: 77.8 – 82.4% Spec.: 86.4 – 94.5% PPV: 3 – 7.5% NPV: 99.8 – 99.9%
| ABUS k=1 | Test performance | Only 1 study, 20% loss to followup Study authors had financial conflict of interest | N/A | Multi-site United States study | 1 fair Overall: Insufficient | All breast cancer: Sens: 67.6% Spec: 91.6% PPV: 4.1% NPV: 99.8%
| MRI k=3 | Test performance | Only 1 good-quality study from the US. Study populations were high risk beyond breast density, even with subgroup analysis family history still an important risk factor | Good-quality studies Small numbers, variable findings | 2 European studies, 1 from United States, all focused on high risk women | 3 good but small studies of high risk women Overall: fair | From 2 good-quality studies for invasive breast cancer: Sens: 100% Spec: 78.1 – 93.2% PPV: 7.7 – 22.2% NPV: 100%
KQ 3. When performed after a negative screening mammogram in women found to have dense breasts, what is the effectiveness of supplemental screening with breast ultrasound, MRI, or DBT on proximate clinical outcomes, including cancer detection rates, DCIS detection rates, stage at diagnosis, recall rates, biopsy rates, and interval cancer rates? | HHUS k=10 | Test performance; cohort Mostly single patient pre-post designs, only 1 study compared 2 cohorts with and without screening | Many studies had no f/u of negative results or reports of interval cancers Many were unclear in how patients were selected for screening Recall for additional imaging not consistently reported | 2 good-quality studies (United States, Italy) with consistent cancer detection rates. | Only good-quality of screening population from Italy | 2 good, 8 fair Overall: fair | From 2 good-quality studies for invasive CDR: 3.9 to 4.1 per 1,000 exams Biopsy rates: 5.9% (Italy)
| ABUS k=3 | Test performance; cohort | Loss to followup only reported in 2 studies (12-20%) | Limited, only 3 fair-quality studies | Limited by unclear reporting on study population and design | 3 fair Overall: Insufficient | Invasive CDR: 1.8 – 12.3 per 1,000 women/exams Recall rates: 1.5 – 13.5%
| MRI k=3 | Test performance | Higher risk women, small studies | Good-quality studies Small numbers, variable findings | 2 European studies, 1 from United States, all focused on high risk women | 3 good but small studies Overall: Fair | All breast CDR: 3.5 to 26.8 per 1,000 exams Invasive CDR: 18 to 19 per 1,000 women/exams Recall rates: 8.6 – 23.4%
| DBT k=4 | Cohorts with comparison group, Single patient pre-post | No f/u of negative tests, unclear study details with regard to invasive cancer detection, recall and biopsy rates | 4 fair-quality studies | Screening populations; 3 from the United States and 1 from Italy | 4 fair Overall: Fair | All breast cancer detection: 4.7 to 6.9 per 1,000 exams Recall rates: 6.6 – 10.8%
KQ 4. What are the harms associated with being identified as having dense breasts, including, psychological and quality of life impacts and harms associated with supplemental screening evaluation, including evaluation of false positive results? | k=1 | RCT | Examined only effect of notification without recommendation for supplemental testing | N/A | Canadian women in organized screening program | 1 good Overall: Insufficient | No measurable psychological harms from breast density notification Other harms: General risk of nephrogenic systemic sclerosis from use of gadolinium contrast in MRI for those with CKD 4-5 DBT as currently performed results in >2 times radiation as for standard digital mammogram

Abbreviations: ABUS=automated whole breast ultrasound; CDR=cancer detection rate; DBT=digital breast ultrasound; HHUS=hand-held ultrasound.

### BI-RADS Breast Density Determinations

We examined the reproducibility of categorical BI-RADS breast density determinations in U.S. clinical-community practices since this is the system recommended by American College of Radiology and is written into most of the legislative mandates. The reproducibility of sequential categorizations of breast density by the same radiologist was better than that for different readers, but still lower than desirable. Best estimates from these data suggest about one in five women would be categorized into a different BI-RADS density category (a, b, c, d) by the same radiologist after the second screening exam, while one in three would be categorized differently after a second exam read by a different radiologist. Re-interpretation of breast density findings can occur due to multiple factors stemming from the woman being examined, the qualitative nature of the technique, and the expertise of the radiologist interpreting the exams. While radiologists' breast density readings are an important part of the screening examination, the impact of variability in exam readings may have unintended consequences through direct-to-consumer communications. Reclassifications from one category to another may undermine women's confidence in the screening process and leave them uncertain about their risk for breast cancer, but would not necessarily result in changes in recommended clinical actions or the content of mandated communications depending on individual state mandates. The American College of Radiology has publically expressed similar concerns.85 A smaller but still sizeable proportion of women (about 13 to 19 percent, depending on whether the second exam was read by the same or a different radiologist) would be reclassified into a different overall combined category (i.e., from “non-dense” to “dense” or vice versa). In these instances, different mandated communications about elevated breast cancer risk and/or the need for additional clinical screenings could occur for the same woman in the span of 2 to 3 years. Finally, estimates based on overall programmatic-level reclassifications could be magnified in certain circumstances. Test-retest reproducibility among individual community-based radiologists suggests the potential for even greater reclassification impacts, particularly given outlier performers.. For example, in one test set read by U.S.-based radiologists, of the 145 mammograms read as “non-dense” (a or b) by the majority of readers, 83 percent were interpreted as dense by at least one radiologist. Similarly, almost half (47%) of the 187 mammograms read as “dense” by the majority were read as “non-dense” by at least one radiologist. In fact, almost all (93%) of the mammograms were interpreted as dense (c or d) by at least one radiologist.57

Valid and reliable breast density calculations could also be important in the development of more personalized breast cancer screening recommendations. A recent model examining average-risk as well as higher-risk women (i.e., those with family or personal history of breast cancer or previous breast biopsy) found optimal screening strategies vary based on BI-RADS density determinations as well as age.86 These modeled results suggest that, depending on the selected threshold for decision-making and the woman's age, BI-RADS category, and history, optimal mammography screening would start at age 40 or 50, with repeat screenings every 2 to 3 or 4 years, and reassessment at each decade through age 70 years. Clearly, valid and reproducible BI-RADs breast density classification would be important for implementation of such personalized screening approaches.

Our findings are consistent with cautions from the American College of Radiology about benefits, possible harms, and unintended consequences for the communication of breast density assessments to women.85 While some of the reclassifications may appropriately reflect actual physiological changes in breast density over time, it is unlikely that the majority of findings reflect true breast density differences due to design of the studies and the consistency of findings. The community practice data may also be criticized for representing relatively “older” practice (i.e., radiologist readings primarily from 2000 to 2009). However, concerns about the reproducibility of BI-RADS breast density determinations are not new, and have been a major impetus for research examining other more objective methods for assigning breast density such as ultrasonographic assessments, automated volumetric estimations, or other computer-assisted methods. Although variability is reduced by use of double readings, which is widely practiced in Europe,78 this approach may not be practical in the United States due to workforce requirements. The introduction of standards and quality measures related to breast density categorization could help to minimize potential harms associated with variable breast density categorizations.

### Supplemental Test Performance and Outcomes for Women With Dense Breasts and a Negative Mammogram

There was limited evidence on the test performance characteristics of potential supplemental screening modalities for women identified as having dense breasts. Two good-quality studies of HHUS were relatively consistent in estimates of sensitivity, specificity, and positive predictive value. Smaller good-quality studies of high risk women suggest that the sensitivity of MRI for women with dense breasts is likely somewhat higher than HHUS. Specificity of these modalities is similar, and PPV is low, resulting in many false positive recalls and biopsies (Table 21). No summary is possible for the other modalities, with only a single study of ABUS and no studies of DBT. We found no studies of any supplemental test that examined the effect of age and other breast cancer risk factors on test performance characteristics in women with dense breasts.

Evidence on important clinical outcomes of supplemental screening among women with dense breasts was also limited. No studies examined the most important outcomes: breast cancer recurrence rates and mortality rates with and without supplemental screening. In general, supplemental screening consistently found additional breast cancers not identified by mammography. The substantial majority of breast cancers identified by MRI and HHUS were invasive. Invasive cancer detection rates were lower in the two good-quality studies of HHUS (3.9 and 4.1 per 1,000 exams)61, 62 than in three good-quality studies of breast MRI (3.4 to 12.3 per 1,000 exams)23, 61, 68 (Table 21) but this may reflect a higher baseline risk in the women recruited to MRI studies. Recall rates and biopsy rates were markedly increased by supplemental screening with HHUS and MRI. Limited evidence on DBT suggested that recall rates for additional imaging are reduced in women with dense breasts; however, it is unclear if this results in fewer overall breast biopsies. Evidence on ABUS in women with dense breasts was limited; both U.S. studies were industry-funded.

### Harms of Breast Density Notification and Supplemental Testing

Evidence on harms of breast density notification and harms resulting from supplemental screening were very limited. Only one trial was identified which suggested little behavioral or psychological impact of breast density notification at six months of followup. Additional studies of the effects of breast density notification are needed.

No studies of supplemental screening addressed the important potential risks of overdiagnosis with the associated harms of unnecessary treatment. Additional studies in U.S. populations are needed. False positive tests, and their associated harms, including anxiety and unnecessary biopsies are increased by supplemental HHSU and MRI; evidence on ABUS and DBT is too limited to draw any conclusions.

## Limitations of the Review

### Limitations Due to Our Approach

We reviewed only studies published in English. It is possible that studies published in other languages would have met our inclusion criteria, although applicability to U.S. practice may have been reduced, particularly for BI-RADS density reproducibility studies. For applicability as well as feasibility concerns, we did not review other approaches to breast density assessment. We are aware of additional studies of supplemental screening of women with dense breasts with MRI or ABUS that are in process (Appendix B), but we were limited to the published literature.

### Limitations Due to the Evidence Base

Current evidence suggests that the use of BI-RADS categorization to classify breast density in women results in clinically important reclassifications with repeat imaging. This raises questions about whether women are being appropriately selected for supplemental screening. The number, quality, and rigor of studies of test characteristics and clinical outcomes were quite limited. We identified no long term followup comparative studies of the clinical outcomes or harms of supplemental screening for women with dense breasts. Many studies did not apply a complete reference standard or a clear description of followup, so we were unable to calculate test performance characteristics. Only one comparative study of cohorts with and without supplemental screening adjusted for differences between cohorts. Most studies assessed short-term incremental impact among women undergoing screening mammography and supplemental screening. Many studies included women at increased breast cancer risk due to risk factors other than breast density, limiting the generalizability of findings in these studies to the general screening population of women with dense breasts. Studies of breast MRI focused on women with multiple risk factors; very little data were available for women with dense breasts and no other major risk factors for breast cancer. Literature on ABUS and breast tomosynthesis for women with dense breasts was very limited and more studies are needed before any conclusions can be reached. Literature on harms related to identification of women as having dense breasts or other potential harms related to supplemental screening was very sparse.

## Future Research Needs

BI-RADS breast density categorization is a subjective assessment and no clear objective reference standard for breast density has been established. The effect of double-reading with consensus and other quality measures on reproducibility of readings should be studied. Automated computer assessments of BI-RADS density have been developed but none have come into widespread clinical use in the United States. A research base to establish clinically applicable approaches, including automated systems, would require both internal consistency and reliability, predictive association with breast cancer risk, as well as reasonable correlation with the BI-RADS density assessments of experienced breast radiologists.

Longer term studies with comprehensive followup, preferably randomized trials, are needed to understand the impact of supplemental testing in women with dense breasts on important breast cancer outcomes including morbidity and mortality. Only with RCTs and longer term followup can the risks of length time bias (earlier detection of cancer not resulting in improved outcomes) as well as the impact of overdiagnosis (leading to unnecessary treatment) be evaluated.

Such studies could evaluate the impact of supplemental screening for women with dense breasts on breast cancer stage at diagnosis, recurrence rates, mortality and overdiagnosis rates. Studies are especially needed among general populations of women with dense breasts who are not otherwise selected for elevated breast cancer risk. Rigorous documentation of the effects of supplemental testing on interval breast cancer rates, recurrence rates, and recall and biopsy rates with repeated screening would assist in elucidating the benefits and harms of supplemental screening for women with dense breasts.

## Conclusion

Good-quality studies with U.S. radiologists show important reclassification between dense and non-dense breasts in at least 12.6 to 18.7 percent of women undergoing sequential screening examinations. Reclassification of breast density may introduce confusion or reduce confidence among women receiving mandated breast density notifications. Moving from a “dense” to a “non-dense” breast categorization will result in different mandated communications in many states with breast density legislation as well as differences in recommended or considered supplemental screening approaches. As risk-based personalized screening approaches develop, valid and reproducible breast density categorization will be required.

Existing limited evidence suggests that more breast cancers will be detected by supplemental HHUS and MRI screening of women with dense breasts, and that most detected breast cancers will be invasive. Whether diagnosis of additional breast cancers leads to improved clinical outcomes, or what proportion of the cancers diagnosed represent overdiagnosis has not been evaluated. However, supplemental testing of women with dense breasts with HHUS or MRI is clearly associated with a marked increase in recall rates for diagnostic investigation among women who do not have breast cancer. DBT may not increase recall rates, but evidence is too limited for definitive conclusions. There is a critical need for well-designed, long-term comparative studies of supplemental screening of women with dense breasts, so that meaningful clinical outcomes of supplemental screening of women with dense breasts can be characterized.