# Results

## Literature Search

Our literature search yielded 2,067 unique citations. From these, we provisionally accepted 128 articles for review based on titles and abstracts (Appendix A Figure 1). After screening the full-text articles, 24 unique articles were determined to have met the inclusion criteria. The remaining 104 full-text articles were excluded (Appendix C).

We identified 5 studies (2 good-quality) that met inclusion criteria for KQ 1 (BI-RADS breast density determination reproducibility), 8 studies (5 good-quality) that met inclusion criteria for KQ 2 (test performance characteristics), 19 studies (5 good-quality) that met inclusion criteria for KQ 3 (proximate breast cancer outcomes), and 1 study (good-quality) that met inclusion criteria for KQ 4 (harms of density notification).

## Key Question 1 What Is the Accuracy and Reproducibility of BI-RADS Determination of Breast Density?

### Summary of Results

Since there is no recognized gold standard for breast density determination, we did not find studies that evaluated the accuracy of BI-RADS breast density determinations in screening mammography. We identified five studies that reported statistical measures for the reproducibility of categorical BI-RADS breast density classification among more than 440,000 women predominantly or exclusively receiving two sequential screening mammograms. We required that breast density categories in all included studies be based on the four BI-RADS categories, with or without percent density descriptions (Table 1), to reflect current U.S. practice. The majority of the evidence came from three studies set in the United States, with two based on data from the Breast Cancer Screening Consortium (BCSC)55, 56 and the other from a set of community radiologists conducting repeated readings of a large screening test set.57 Two additional studies were based on much smaller samples or test sets from mammographic screening programs in Spain58 or Italy.59 All of the U.S.-based studies reflected community practice, by virtue of evaluating clinical readings from community screening programs or test set readings by practicing community radiologists without additional training.

Best estimates from these data suggest about one in five women would be categorized into a different BI-RADS density category (a, b, c, d) by the same radiologist after the second screening exam, while one in three would be categorized differently after a second exam read by a different radiologist. At a programmatic level, this translates into an estimated 12.6 to 18.7 percent of women being reclassified into a different overall combined breast density category (i.e. from “dense” [c or d] to “non-dense” [a or b] or vice-versa) after a second screening mammogram. These average estimates do not reflect some of the extremes seen when examining test-retest reproducibility among individual community-based radiologists. Breast density categorizations based on sequential screening mammograms read by different radiologists showed lower overall agreement (kappas from 0.49 to 0.56, indicating moderate agreement) and a much greater range of inter-rater disagreements (kappas from 0.02 to 0.72) than seen with sequential readings by the same radiologist. Findings are most applicable to post-menopausal women or those aged 50 years and older, since these women comprised the bulk of those whose exams were studied.

### Study Details

Two BCSC studies in the United States were in large population-based samples and represented community-assigned breast density readings between 1996 and 2009. The first good-quality study55 evaluated breast density readings by a broad set of community radiologists of 871,502 digital or film-screen (FS) mammograms taken from 435,751 women aged 40 years and older, about a quarter of whom (28%) were 40 to 49 years of age. To be included, women had at least two screening mammograms conducted less than 36 months apart between January 1, 2000 and December 31, 2009.^55^ The second fair-to-good-quality BCSC study evaluated the performance of 34 regional community radiologists who had interpreted at least 100 pairs of FS mammograms taken from 11,755 post-menopausal women with two or more screenings within a 3 to 24 month period between 1996 and 2006.^56^ These two large community-based studies examining consistency of clinical readings were supplemented by a fair-quality study of 19 experienced community radiologists from a single U.S. integrated health care system who assigned BI-RADS breast density ratings to a test set of 341 FS mammograms on two occasions six-months apart in 2001 to 2002 in women of unspecified ages.57 All three studies excluded women with history of breast cancer or augmentation, while the two BCSC studies also excluded women with recent hormonal medication use or other medical conditions that might introduce confounding due to physiologic changes in breast density between exams.55, 56 The main risk of bias was due to unclear information about rater methods, including radiologist blinding to clinical information or other non-clinical cues.

Table 3 illustrates the relative consistency of breast density determinations for sequential examinations or readings at the population level. However, consistency in the distribution of BI-RADS density categorizations at the population level or measures of reproducibility (i.e., percent agreement, kappa) across all exams in a set can be misleading when considering individual patients. Even with the moderate or substantial agreement (kappas of 0.4 to 0.8) between readings, as seen across these large U.S. studies, 23 to 32 percent of women were assigned a different BI-RADS breast category in a sequential examination55, 60 or when the community interpretation was compared to that of the majority of radiologists.57

Table 3 U.S. Studies of BI-RADS Density Categories and Consistency of Population Categorization

Study Time between assessments | Exam/Reading | a^*^ (%) | b^†^ (%) | c^‡^ (%) | d^§^ (%) | % of women categorized in the same BI-RADS breast density category at both assessments (4 categories) | Kappa Statistic Interpretation: Intraobserver | Kappa Statistic Interpretation: Interobserver
Harvey, 2013^55^ <36 months | Exam 1 | 9.4 | 45.2 | 37.9 | 7.5 | 68.1 | | Interobserver K: 0.49 to 0.56 (Moderate Agreement)
Harvey, 2013^55^ <36 months | Exam 2 | 10.2 | 45.1 | 37.2 | 7.2 | 68.1 | | Interobserver K: 0.49 to 0.56 (Moderate Agreement)
Spayne, 2012^56^ 3-24 months | Exam 1 | 9.8 | 61.0 | 26.6 | 2.5 | 77.2 | Intraobserver K: Weighted, 0.70 (Substantial Agreement)
Spayne, 2012^56^ 3-24 months | Exam 2 | 9.2 | 60.2 | 28.1 | 2.5 | 77.2 | Intraobserver K: Weighted, 0.70 (Substantial Agreement)
Gard, in press57 6 months | Reading 1 | 6.1 | 44.3 | 38.3 | 11.4 | 71.4 | Intraobserver K: 0.50 to 0.81 (Moderate to Almost Perfect Agreement) | Interobserver K: 0.02 to 0.72 (Slight to Substantial Agreement)
Gard, in press57 6 months | Reading 2 | 4.5 | 39.2 | 47.0 | 9.3 | 71.4 | Intraobserver K: 0.50 to 0.81 (Moderate to Almost Perfect Agreement) | Interobserver K: 0.02 to 0.72 (Slight to Substantial Agreement)

* Breast density category a = almost entirely fat.

† Breast density category b = scattered fibroglandular densities.

‡ Breast density category c = heterogeneously dense.

§ Breast density category d = extremely dense.

Abbreviation: BI-RADS=Breast Imaging-Reporting and Data System.

In the largest study,55 the acquisition method (digital vs FS) overall, or in repeated exams (FS-FS, FS-digital, digital-FS, digital-digital), did not markedly affect the percentage of women for whom the radiologists assigned a different breast density from the first to second reading (i.e., increased or decreased at least one category). This allowed analyses to focus on the complete dataset, regardless of mammogram acquisition type, and reproducibility of categorical BI-RADS determinations by different radiologists between first and second examinations. Measures of agreement in BI-RADS categorization were high between readers of sequential mammograms (67% to 71%), and there was moderate overall interobserver agreement (kappa 0.49 to 0.56). The lowest reproducibility of sequential BI-RADS breast density categorization occurred in the group initially assigned to the highest breast density category: BI-RADS d. In this relatively small group (7.5% of all women categorized as having “extremely dense” breasts on the first exam), just 57 percent were categorized the same after the second exam, with another 37 percent classified as “heterogeneously dense” (category c), 5 percent as “scattered fibroglandular densities” (category b), and under 1 percent as “almost entirely fatty” (category a) (data not shown). Although the majority of women (68.1%) were categorized in the same BI-RADS breast density category at both exams, almost one-third (31.9%) were categorized differently, with about one in five (18.7%) women reclassified into the opposite overall breast density category at their next screening exam (Table 4). Among the almost one-third of women categorized into a different BI-RADS density category on second exam (31.9%) (Table 4), breast density was reported in a lower category in 16.7 percent of women, and in a higher category in 14.7 percent of women (data not shown).

Table 4 U.S. Studies of Potential Misclassification of BI-RADS Density Categorization for Women and by Density Categories

Study | % of women receiving a different breast density classification at 2^nd^ exam (4 categories) | % of women receiving an opposite breast density classification at 2^nd^ exam (2 categories) | Proportion of dense exams reclassified as non-dense^*^ (c or d) to (a or b) | Proportion of dense exams reclassified as non-dense † (c) to (a or b) | Proportion of dense exams reclassified as non-dense ‡ (c) to (b) | Proportion of non-dense exams reclassified as dense § (a or b) to (c or d) | Proportion of non-dense exams reclassified as dense ║ (b) to (c or d) | Proportion of non-dense exams reclassified as dense ¶ (b) to (c)
Harvey,55 2013 | 31.9 | 18.7 | 0.217 | 0.208 | 0.200 | 0.163 | 0.160 | 0.154
Spayne, 2012^56^ | 22.8 | 12.6 | 0.191 | 0.186 | 0.182 | 0.100 | 0.097 | 0.095
Gard, in press57 | 28.6 | 16.9 | 0.103 | 0.103 | 0.103 | 0.234 | 0.234 | 0.228

* Categorized as “heterogeneously dense” or “extremely dense” at first exam and “almost entirely fat” or “scattered fibroglandular densities” at second exam.

† Categorized as “heterogeneously dense” at first exam and “almost entirely fat” or “scattered fibroglandular densities” at second exam.

‡ Categorized as “heterogeneously dense” at first exam and “scattered fibroglandular densities” at second exam.

§ Categorized as “almost entirely fat” or “scattered fibroglandular densities” at first exam and “heterogeneously dense” or “extremely dense” at second exam.

║ Categorized as “scattered fibroglandular densities” at first exam and “heterogeneously dense” or “extremely dense” at second exam.

¶ Categorized as “scattered fibroglandular densities” at first exam and “heterogeneously dense” at second exam.

Abbreviation: BI-RADS=Breast Imaging-Reporting and Data System.

The probability of reclassification depended somewhat on the initial BI-RADS categorization. Of all those with a combined “dense breast” classification (c or d) on first exam, 21.7 percent were reclassified as “non-dense” (a or b) on second exam, while the percent reclassified from “non-dense” to “dense” was somewhat lower (16.3 percent). By far the largest proportion of reclassifications was between categories b and c. While these and other recategorizations primarily represented single category shifts, shifts between b and c are more critical since they represent a change in overall density categorization (i.e., between non-dense and dense). Overall, this study's findings suggest that almost one in three women receiving breast density information would be told they were in different categories (i.e., a or b or c or d) after sequential screening exams less than three years apart. Considering the consequences of assigning women to different breast density categories according to legislative mandates, (i.e., from “dense” to “non-dense” or vice-versa), these data suggest that about 18.7 percent of women would receive discordant mandated notification suggesting different breast cancer risks and/or recommended actions within 36 months or less. Although changes in assigned breast density could reflect actual changes, these are less likely given the relatively short interval between exams (95% re-examined after fewer than 30 months) and control of medication use and other factors in the study population that would increase the likelihood of physiologic changes in breast density.

The second population-based BCSC study56 focused on the reproducibility of individual community radiologists' breast density readings among 11,755 post-menopausal women (mean age 66 years) receiving repeated FS mammographic screenings 3 to 24 months apart. Across all radiologists, percent agreement (77.2%, 95% CI 74.5 to 79.5) and intrarater reliability was moderate to substantial (kappa 0.58, 95% CI 0.55 to 0.61; weighted kappa 0.70, 95% CI 0.68 to 0.73). Reproducibility did not appear to vary by characteristics of the woman (i.e., age, change in BMI), by time between rescreening, or by changes in BI-RADS density definitions before and after the 4^th^ edition (November 2003 to May 2004). However, individual radiologists demonstrated considerable variability in the reproducibility of their breast density readings in the same women, with 18 percent (6/34) having only slight or fair agreement, 59 percent (20/34) exhibiting moderate agreement, and 24 percent (8/34) with substantial agreement.

Although the distribution of women within breast density categories was quite similar for the first and second screening exams at the population level (Table 3), many individual women were recategorized from first to second screening. The breast density of 22.8 percent of all women was categorized differently by the same radiologist at the second screening exam, with the highest proportion of women receiving a different density rating among those categorized initially in the lowest and highest breast density categories (i.e., 45% and 50% respectively). Considering potential actions based on the first exam, 19.1 percent of women categorized as having dense breasts initially (c or d) would not be notified of dense breasts with their second exam results (a or b). Similarly, 10 percent not classified as having dense breasts on first exam (a or b) would have been notified that they had dense breasts (c or d) after the second exam. Given the distribution of results (i.e. most women were assigned breast density b or c initially), the largest number of reclassifications were between categories b and c, which are single category changes but represent an important change in the overall density categorization. This study's results suggest that, overall, about one in five women would be categorized into a different BI-RADS breast density category in a sequential screening mammogram by the same radiologist; 12.6 percent of all women screened would potentially be advised differently according to legislative mandates (Table 4).

A fair-quality U.S. study examined both inter-rater and intra-rater reliability among 19 experienced radiologists from a single integrated U.S. health care system. The study compared repeated readings of a test set of FS mammograms six months apart (2001 to 2002); films represented screening exams in 341 women from the same institution.57 BI-RADS density determinations for each woman's films were compared between pairs of radiologists (and between repeated readings for each radiologist). Inter-rater agreement was fair (mean kappa 0.46; 95% CI, 0.36 to 0.55) and varied widely between pairs of radiologists, from slight to substantial; one radiologist displayed only slight agreement with any other. Agreement between radiologists did not vary by radiologist experience, time spent reading mammograms/breast imaging, or findings (cancer versus not). Intra-rater agreement was higher, with substantial mean agreement (mean kappa 0.69, 95% CI 0.63 to 0.73) and no less than moderate agreement for repeated breast density readings by any individual radiologist; radiologists with more than 10 years of experience interpreting mammograms had higher reproducibility of their own breast density readings (increased mean kappa 0.10; 95% CI, 0.01 to 0.24).

When the original clinical breast density readings were compared to the majority opinion of all readers, 29 percent of women were categorized into a different BI-RADS density category (a, b, c, d) (Table 4). As with other studies, the majority of exams reclassified from “dense” to “non-dense” represented changes in categorization from b to c (or vice versa), but those initially designated to the highest and lowest categories a or d by the original clinical readers were the least stable. Although many (55%) of the BI-RADS category a classifications assigned during the original clinical readings were re-rated category b by the majority of radiologists, none were assigned categories c or d. Similarly, many (40%) of the category d original clinical readings were reassigned category c by the majority of radiologists, but none moved to a “non-dense” (a or b) group. In contrast, 25.9 percent of films originally categorized as b on the clinical reading were re-categorized as c by the majority of readers, with a smaller percentage (13.4%) being re-categorized from c to b by the majority. Based on these re-categorizations, an estimated 17 percent of screened women would have been reassigned to the opposite breast density category (“dense” vs “non-dense” by the majority of radiologists).

This study illustrates the high potential for misclassification when breast density is assigned by single readers and there are outlier performers, as occurred among these 19 radiologists. Among 145 examinations classified as “non-dense” (a or b) by the majority of readers, 83 percent were interpreted as “dense” (c or d) by at least one radiologist. Similarly, at least one radiologist interpreted almost half (47%) of the 187 examinations interpreted as “dense” by the majority as “non-dense.” Almost all (93%, n=316) exams were interpreted as “dense” (c or d) by at least one radiologist. These data illustrate the clear potential for misclassification of breast density after a single reading by a community radiologist.

Two studies outside the United States examined the reproducibility of BI-RADS breast density classifications among experienced radiologists reading test sets of 100 digital or FS mammograms from screening programs in Spain and Italy (data not shown in tables). Both programs provided initial training to calibrate performance among the 21 experienced radiologists58 or to orient six otherwise experienced radiologists not currently using the BI-RADS system for breast density.59 After calibration, a good-quality study of 21 radiologists found moderate to substantial inter-rater agreement across all four breast density categories (kappa 0.44; weighted kappa 0.73); intra-rater agreement was higher (kappa 0.64; weighted kappa 0.82). Nonetheless, among pairs of radiologists, 15.1 percent of mammograms (3,180/20,694) classified as “non-dense” by one reader were classified as “dense” by another. Within individual radiologists, repeat classification of the same image between non-dense and dense categorization was less often divergent (i.e., 10.4%). Among six Italian radiologists newly oriented to using the BI-RADS four categories for breast density classification, agreement between pairs of radiologists across all four categories was substantial or better (weighted kappas ranging from 0.61 to 0.87); agreement was slightly improved across collapsed categories (“non-dense” vs “dense”) with weighted kappas ranging from 0.64 to 0.94. Nonetheless, depending on radiologist pairs, 6 to 15 percent of women were allocated differently to breast density categories after different single-readers.

## Key Question 2 What Are the Test Performance Characteristics of Newer Technologies for Breast Cancer Screening When Used as Supplemental Tests After a Negative Screening Mammography Exam in Women Found to Have Dense Breasts? How Do These Performance Characteristics Differ by Age and Risk Factors?

### Summary of Results

We identified and reviewed studies of diagnostic test characteristics (with defined reference standards) for hand held breast ultrasound (HHUS), automated whole breast ultrasound (ABUS), and breast magnetic resonance imaging (MRI) among women with dense breasts and negative screening mammography. We did not identify any studies of the diagnostic test characteristics of digital breast tomosynthesis (DBT) for women with dense breasts, which is a relatively new technology with limited research. We excluded studies that did not followup negative test results for a minimum of one year as part of the reference standard. Most included studies had cohort designs, assessing the accuracy of supplemental test results within a group of women undergoing supplemental screening in addition to screening mammography. When possible, we assessed the performance of supplemental tests among women with negative screening mammography. In these studies, the reference standard was either tissue sampling for women recommended for biopsy or a minimum of one year clinical followup for women with either negative supplemental screening results or who were not recommended for biopsy. Incremental sensitivity was calculated based on cancers detected by the supplemental screening test and interval cancers. Cancers detected by mammography were not included in the calculation of sensitivity, as the focus was on supplemental testing in women found to have dense breasts after a negative mammogram.

Two good-quality studies (one from the United States61 and one from Italy62) and three fair-quality studies (one each from the United States,63 Singapore64 and South Korea65) reported on HHUS (Tables 5 and 9); one fair-quality study from the United States reported on ABUS (Tables 6 and 10);66, 67 three good-quality studies (one each from the United States,61 Germany,23 and the Netherlands68) reported on MRI (Tables 7 and 11). Some studies focused exclusively on women with BI-RADS density c to d, while others reported on mixed populations including women with elevated risk due to BRCA 1/2 mutations, a personal history of breast cancer, or family history of breast cancer. Of these, we included only studies in which a majority of women had dense breasts, and in some cases we were able to isolate a subgroup with dense breasts without a personal history of breast cancer or BRCA 1/2 mutation carriage. In two good-quality studies,23, 61 the authors provided unpublished data for the subgroup of women with dense breasts, and removed the women with BRCA 1/2 mutations, histories of chest irradiation, and/or personal histories of breast cancer from the subgroup. We found no studies reporting how the performance of these modalities varies by patient age and other risk factors for breast cancer among women with dense breasts.

Table 5 Supplemental HHUS Screening for Breast Cancer in Women With Dense Breasts: Study and Population Characteristics

Author, Year USPSTF Quality | Location and Study dates | Design and Setting | Study Population | Subgroup Population | Patient Characteristics
Berg, 2012^61^ Good | United States 1/2004 - 2009 | Diagnostic accuracy Multiple academic medical centers | Asymptomatic women with a negative mammogram, dense breasts and elevated risk for breast cancer N=2,262 women (7,473 exams) | Women without a personal history of breast cancer, BRCA 1/2 mutation carriers and women with a history of chest, mediastinal or axillary irradiation N=1,216 women (3,414 exams) | Mean age: 55.2 y^*^ Personal hx of breast cancer: 53.1%^*^ History of chest, mediastinal or axillary irradiation:0.3%^*^ BRCA 1/2 mutation: 0.9%^*^
Corsetti, 2011^62^ Good | Italy 2001 - 2006 | Diagnostic accuracy Charity funded breast cancer screening service | Asymptomatic women with a negative mammogram N=5509 women (12,504 exams) | Women with BI-RADS c or d density and a negative mammogram undergoing HHUS N=3,356 women (7,224 exams) | Age distribution: <50 y: 55% ≥50 y: 45%
Hooley, 2012^63^ Fair | Connecticut, United States 10/2009 – 9/2010 | Diagnostic accuracy Single academic health system | Women with dense breasts receiving HHUS N=935 women | Women heterogeneous or extremely dense breasts and a negative mammogram N=648 women | Mean age: 52 y^*^ Lifetime risk (based on Gail model) Low/average: 66%^*^ Intermediate: 15.9%^*^ High: 9.35%^*^ Unknown: 9%^*^
Leong, 2012^64^ Fair | Singapore 9/2002 – 11/2004 | Diagnostic accuracy General hospital radiology practice | Women with heterogeneous or extremely dense breasts and a negative mammogram N=141 women | Women with heterogeneous or extremely dense breasts and a negative mammogram and complete followup N=106 women | Mean age: 45.1 y Family hx of BC: 20.9% Personal hx of BC: 5%
Youk, 2011^65^ Fair | South Korea 7/2001 – 6/2005 | Diagnostic accuracy Single academic medical center | Women with negative mammogram and dense breasts N=1,046 women (1,507 exams) | Women with BI-RADS c or d density, no prior history of breast cancer and a negative mammogram N=446 exams | Mean age: 47.5 y^*^ Personal hx of BC: 61.8%^*^
Parris, 2013^71^ Fair | Connecticut, United States 10/2009 – 9/2010 | Cohort Single mammography outpatient facility | Women undergoing HHUS after reporting law passed. Included women with negative mammograms and HHUS findings from women with abnormal mammograms included for breast quadrants in which mammogram was negative N=5,519 women | NA | Mean age: 53.6 y Heterogeneous (>50% density) or very dense breasts: 89% Family hx of BC: 42% Personal hx of BC: 6%
Weigert, 2012^73^ Fair | Connecticut, United States 11/2009 – 11/2010 | Cohort 6 radiology practices with 12 sites | Women with 50% or more dense breast tissue and a negative mammogram N=8,647 women (8,647 exams) | NA | Mean age: 54.4 y
Girardi, 2013^70^ Fair | Italy | Cohort Single breast clinic | Asymptomatic women with a negative mammogram N=22,131 women | Women with BI-RADS c or d density and a negative N=9,960 women | Mean age: 51.2y^*^ Pre-menopausal: 50%^*^ Personal hx of breast cancer: 9.8%^*^
Venturini, 2013^72^ Fair | Italy | Cohort | Women undergoing screening mammography N=1,666 women | Women with BI-RADS c or d density or implants N=826 women | Age Distribution: 40-44 y: 44.1.1%^*^ 45-49 y: 55.9%^*^ Family hx of BC: 24%^*^ Previous benign biopsy: 3.8% Pre-menopausal: 64%
Brancato, 2007^69^ Fair | Italy | Cohort Single large breast screening clinic | Asymptomatic women with BI-RADS c or d density and a negative mammogram N=5,227 women | NA | Age Distribution: <40 y: 4.5% 40-49 y: 68% 50-59 y: 19%

* Data are representative of entire study population, not necessarily the subgroup abstracted.

Abbreviations: BC=breast cancer; BI-RADS=Breast Imaging-Reporting and Data System; HHUS = hand held ultrasound; hx = history; NA=not applicable.

Table 6 Supplemental ABUS Screening for Breast Cancer in Women With Dense Breasts: Study and Population Characteristics

Author, Year USPSTF Quality | Location and Study Dates | Design and Setting | Study Population | Subgroup Population | Patient Characteristics
Brem, 2015^74^ Fair | United States 2009 – 2011 | Cohort Breast screening centers, including academic health systems | Asymptomatic women ages 25 years or older with dense breasts, no previous diagnosis of breast cancer in the past year, no prior breast surgeries or percutaneous procedures in the past year N=15,318 women | N/A | Mean age: 53.3 y Premenopausal: 38.1% Family hx or BC: 44.8% Personal hx of BC: 3.6% BRCA 1/2 carriers: 1% Hormonal therapy (any use): 31.2%
Kelly, 2010^66^ Fair | United States 1/2003 – 7/2007 | Diagnostic accuracy 8 breast radiology facilities across the United States | Asymptomatic women with either dense breasts, family or personal history, and/or breast implants who had mammography and ABUS N=4,419 women (6,425 exams) | N/A | Mean age: 53 y^*^ Dense Breasts: 68% Family hx of BC: 30%^*^ Personal hx of BC: 10%^*^ Breast Implants: 11%^*^ BRCA 1/2 carriers: 0.1%^*^
Giuliano, 2013^67^ Fair | United States 1/2009 – 5/2011 | Cohort Academic medical center | Women presenting for breast cancer screening N=7,497 women | Women with >50% breast density (Wolf classification) who received ABUS in addition to mammography N=3,418 women | “…no pre-existing predictors of breast cancer, such as personal or family history or BRCA gene positive.”

* Data are representative of entire study population, not necessarily the subgroup abstracted.

Abbreviations: ABUS=automated whole breast ultrasound; BC=breast cancer; BI-RADS=Breast Imaging-Reporting and Data System; CG=control group; IG=intervention group.

Table 7 Supplemental MRI Screening for Breast Cancer in Women With Dense Breasts: Study and Population Characteristics

Author, Year USPSTF Quality | Location and Study Dates | Design and Setting | Study Population | Subgroup Population | Patient Characteristics
Berg, 2012^61^ Good | United States 4/2004 - 2009 | Diagnostic accuracy Multiple academic medical centers | Asymptomatic women with a negative mammogram, dense breasts and elevated risk for breast cancer who underwent 3 rounds of ultrasound screening and 1 round or MRI screening N=612 exams | Women without a personal history of breast cancer, BRCA 1/2 mutation carriers and women with a history of chest, mediastinal or axillary irradiation. N=334 exams | Mean age: 56.8 y Dense breasts: 100% BRCA 1/2 mutation: 0.5-0.8%^*^
Kuhl, 2014^23^ Good | Germany 1/2009 – 6/2010 | Diagnostic accuracy One university hospital | Women with a negative mammogram at high risk for breast cancer (based on family and/or personal history) (443 women) | Women with BI-RADS c or d density without family or personal history of breast cancer (105 women) | Mean age: 53.2 y
Kriege, 2006^68^ Good | Netherlands 11/1999 – 10/2003 | Diagnostic accuracy Six familial cancer clinics | Women aged 25-70 years with a lifetime cancer risk > 15% (1,779 women/4,134 exams) | Women with BI-RADS c or d dense breasts who were not BCRA mutation carriers (1,723 exams) | Mean age: 40 y^*^ Family hx of BC: 100%^*^ Pre-menopausal: 76.6%^*^ Using hormonal therapy: 4%^*^

* Data are representative of entire study population, not necessarily the subgroup abstracted.

Abbreviations: BC=breast cancer; BI-RADS=Breast Imaging-Reporting and Data System; US=ultrasound.

Table 8 Supplemental DBT Screening for Breast Cancer in Women With Dense Breasts: Study and Population Characteristics

Author, Year USPSTF Quality | Location and Study Dates | Design and Setting | Study Population | Subgroup Population | Patient Characteristics
McCarthy, 2014^75^ Fair | Philadelphia, PA 9/2010 – 2/2013 | Cohort University health system | Asymptomatic women, including those with implants and large breasts requiring multiple images N=18,220 women | Asymptomatic women with dense breasts DBT+DM (IG) = 5,056 exams DM only (CG) = 3,489 exams | Age: 70% of patients ages 50 years and older
Haas, 2013^76^ Fair | New Haven, Connecticut 10/2011 – 9/2012 | Cohort Outpatient radiology clinics, mobile mammography van, tertiary care hospital | Women presenting for screening, including women with a personal history of breast cancer, undergoing DBT plus mammography DBT+DM (IG) = 6,100 women DM only (CG) = 7,058 women | Asymptomatic women with dense breasts N=4,794 exams | Dense Breasts (c or d): 43.2%^*^ Age:^*^ <40 y: 2.7% 40-49 y: 30.6% 50-59 y: 33.3% 60-69 y: 23.3% >70 y: 10.1% Personal history of BC: 5.5%^*^
Rose, 2013^77^ Fair | Houston, TX 2010 – 2012 | Retrospective cohort One cancer center | Asymptomatic women DBT+DM (IG) = 9,499 exams DM only (CG) =13,856 exams | Asymptomatic women with BI-RADS 3-4 density DBT+DM (IG) = 4,666 exams DM only (CG) =7,009 exams | IG:^*^ Mean age: 54.5 y <50 y: 37.5% 50-64 y: 46.8% >64 y: 17.5% CG: Mean age: 53.8 y <50 y: 38.5% 50-64 y: 45.4% >64 y: 16.1%
Ciatto, 2013^70^ Fair | Italy 9/2011 – 6/2012 | Prospective cohort Multiple breast screening programs | Asymptomatic women undergoing digital mammography followed by DBT N=7,294 women | Asymptomatic women with BI-RADS 3-4 density N=1,215 women | Median age: 58 y^*^ Age range: 48 – 71 y^*^

* Data are representative of entire study population, not necessarily the subgroup abstracted.

Abbreviations: BC=breast cancer; BI-RADS=Breast Imaging-Reporting and Data System; CG=control group; DBT=digital breast tomosynthesis; DM=digital mammography; IG=intervention group.

Table 9 Supplemental HHUS Screening for Breast Cancer in Women With Dense Breasts: Screening Test Characteristics

Author, Year USPSTF Quality | Supplemental Test and Comparison | # Screening Rounds (per woman) | Followup Period and LTFU | Readers | Reference Standard
Berg, 2012^61^ Good | Negative mammogram followed by HHUS | 3 | 12+ months LTFU < 3% | Ultrasounds done by technologists and read by radiologists across 12 sites | Biopsy and/or one year clinical followup
Corsetti, 2011^62^ Good | Negative mammogram followed by HHUS in women with BI-RADS 3-4 breast density | 2 (mean) | 12 months LTFU estimated at <5% | 6 radiologists; single read | Biopsy or 1-year followup with search of all hospital registries in catchment region for breast cancer cases
Hooley, 2012^63^ Fair | Negative mammogram followed by HHUS | 1-2 per woman | 15+ months 19% LTFU | 8 breast radiologists with 2-32 years' experience | Biopsy or a followup mammogram with or without US within 15 months
Leong, 2012^64^ Fair | Negative mammogram followed by HHUS | NR | 12-24 months 35 women (25%) LTFU | 3 sonographers with 4-12 years of US experience performed the exams. 4 radiologists with 3-15 years of breast US experience reviewed the exams | Biopsy or chart review if negative assessment at 2 years
Youk, 2011^65^ Fair | Negative mammogram followed by HHUS | 1-4 | 24 months (Excluded patients without followup) | 9 radiologists with fellowships or 408 years clinical experience in breast imaging | Biopsy or documented 2-year followup
Parris, 2013^71^ Fair | Negative mammogram followed by HHUS | 1 | NR | 6 board certified radiologists with 4-32 years' experience | No comprehensively applied reference standard
Weigert, 2012^73^ Fair | Negative mammogram followed by HHUS | 1 per woman | NR | Ultrasounds done by technologists and read by radiologists across 12 sites | No comprehensively applied reference standard
Girardi, 2013^70^ Fair | Negative mammogram followed by HHUS | 1 per woman | 12 months LTFU NR | 5 radiologists 6-34 years' experience in breast ultrasound | No comprehensively applied reference standard
Venturini, 2013^72^ Fair | Negative mammogram followed by HHUS | 1 per woman | NR | 4 readers with 10-20 years' experience | No comprehensively applied reference standard
Brancato, 2007^69^ Fair | Negative mammogram followed by HHUS (within one month) | NR | NR | Radiologists with 3-15 years breast US experience and at least 500 US performed annually | No comprehensively applied reference standard

Abbreviations: HHUS=hand-held ultrasound; LTFU=lost to followup; NR=not reported; US=ultrasound.

Table 10 Supplemental ABUS Screening for Breast Cancer in Women With Dense Breasts: Screening Test Characteristics

Author, Year USPSTF Quality | Supplemental Test and Comparison | # Screening Rounds (per woman) | Followup Period and LTFU | Readers | Reference Standard
Brem, 2015^74^ Fair | Mammography with ABUS compared to mammography alone | 1 per woman | 12 months 12% LTFU | 39 radiologists at 11 sites | No comprehensively applied reference standard
Kelly, 2010^66^ Fair | Mammography with ABUS compared to mammography alone | 1 or more per woman | 12 months 20% LTFU | 10 radiologists with at least ten years' experience in breast US | Biopsy or one year followup with mammography
Giuliano, 2013^67^ Fair | Digital mammography with ABUS (IG) compared to digital mammography alone (CG) | 1 per woman | 12 months LTFU not reported | 2 radiologists with more than ten years' experience in breast ultrasound and two years' experience in ABUS. All images double read | No comprehensively applied reference standard

Abbreviations: ABUS=automated whole breast ultrasound; LTFU=lost to followup; NR=not reported.

Table 11 Supplemental MRI Screening for Breast Cancer in Women With Dense Breasts: Screening Test Characteristics

Author, Year USPSTF Quality | Supplemental Test and Comparison | # Screening Rounds (per woman) | Followup Period and LTFU | Readers | Reference Standard
Berg, 2012^61^ Good | 3 rounds of negative mammogram and ultrasound followed by MRI | 1 | 12 months 15 women LTFU | Multiple radiologists who completed skills testing for mammographic and ultrasound interpretation | Biopsy and/or one year clinical followup
Kuhl, 2014^23^ Good | Negative mammogram followed by MRI | 1-2 | 24 months 2% LTFU overall, 0% in subgroup | 2 readers with 6-18 years' experience with an annual caseload of approximately 800 MRI images | Biopsy of positive results and two years of followup for negative results
Kriege, 2006^68^ Good | Negative mammogram followed by MRI | 2.3 (mean)^*^ | 12 months | NR | Biopsy and one year followup for negative results

* Data are representative of entire study population, not necessarily the subgroup abstracted.

Abbreviations: LTFU=lost to followup; NR=not reported.

Table 12 Supplemental DBT Screening for Breast Cancer in Women With Dense Breasts: Screening Test Characteristics

Author, Year USPSTF Quality | Supplemental Test and Comparison | # Screening Rounds (per woman) | Followup Period and LTFU | Readers | Reference Standard
McCarthy, 2014^75^ Fair | Digital mammography alone compared to digital mammography and DBT | 1-2 | No followup except on biopsy results | 6 radiologists with 3-22 years' experience and formal training in DBT | No comprehensively applied reference standard
Haas, 2013^76^ Fair | Digital mammography alone compared to digital mammography and DBT | NR | No followup except on biopsy results | 8 radiologists with 2-23 years' experience and certification in DBT | No comprehensively applied reference standard
Rose, 2013^77^ Fair | Digital mammography alone (CG) compared to digital mammography and DBT (IG) | 1 | No followup except on biopsy results | 6 radiologists with 2-32 years' experience | No comprehensively applied reference standard
Ciatto, 2013^70^ Fair | Digital mammography followed by DBT | 1 | No followup except on biopsy results | 8 radiologists with 3-13 years' experience in mammography and basic training in DBT | No comprehensively applied reference standard

Abbreviations: CG=control group; DBT=digital breast tomosynthesis; IG=intervention group; LTFU=lost to followup.

In two good- quality studies, the sensitivity of HHUS for detecting any breast cancer (including invasive breast cancer and DCIS) among women with dense breasts after recent negative screening mammography ranged from 80.0 percent (95% CI, 64.5 to 91.0)62 to 83.3 percent (95% CI, 58.6 to 96.4)61 and for invasive breast cancer, the sensitivity ranged from 77.8 percent (95% CI, 60.9 to 89.9)62 to 82.4 percent61 (95% CI, 56.6 to 96.2) (Table 13; Figures 2-5). Specificity ranged from 86.4 percent (95% CI, 85.2 to 87.5 percent)61 to 94.5 percent (95% CI, 94.0 to 95 percent)62 for all breast cancer and from 86.4 percent (95% CI, 85.2 to 87.5)61 to 94.5 percent (95% CI, 94.0 to 95.0)62 for invasive breast cancer. Positive predictive value (PPV) ranged from 3.0 percent61 to 6.6 percent62 for invasive cancer. Negative predictive value (NPV) was uniformly high, ranging from 99.8 percent61 to 99.9 percent.62

Table 13 Supplemental HHUS Screening for Breast Cancer in Women With Dense Breasts: Test Performance Characteristics

Study, Year USPSTF Quality | Study N | Subgroup N | Study/Subgroup characteristics | Breast Cancer Type | Sensitivity (95% CI) | Specificity (95% CI) | Positive Predictive Value | Negative Predictive Value
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 1,216 women 3,414 exams | Mean age: 55.2^*^ Personal hx of BC: 53.1%^*^ Hx of chest, mediastinal or axillary irradiation: 0.3% BRCA 1/2 mutation: 0.9%^*^ | All Breast Cancer | 0.833 (0.586 to 0.964) | 0.864 (0.852 to 0.875) | 0.032 | 0.998
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 1,216 women 3,414 exams | Mean age: 55.2^*^ Personal hx of BC: 53.1%^*^ Hx of chest, mediastinal or axillary irradiation: 0.3% BRCA 1/2 mutation: 0.9%^*^ | Invasive Breast Cancer | 0.824 (0.566 to 0.962) | 0.864 (0.852 to 0.875) | 0.030 | 0.999
Corsetti, 2011^62^ Good | 5,509 women 12,504 exams | 3,356 women 7,224 exams | Age distribution: <50 years: 55% ≥50 years: 45% | All Breast Cancer | 0.800 (0.645 to 0.910) | 0.945 (0.940 to 0.950) | 0.075 | 0.999
Corsetti, 2011^62^ Good | 5,509 women 12,504 exams | 3,356 women 7,224 exams | Age distribution: <50 years: 55% ≥50 years: 45% | Invasive Breast Cancer | 0.778 (0.609 to 0.899) | 0.945 (0.940 to 0.950) | 0.066 | 0.999
Hooley, 2012 63 Fair | 935 women | 648 women | Mean age: 52 y^*^ Lifetime risk (based on Gail model) Low/average: 66%^*^ Intermediate: 15.9%^*^ High: 9.35%^*^ Unknown: 9%^*^ | All Breast Cancer | 1.000 (0.292 to 1.000) | 0.767 (0.733 to 0.798) | 0.020 | 1.000
Hooley, 2012 63 Fair | 935 women | 648 women | Mean age: 52 y^*^ Lifetime risk (based on Gail model) Low/average: 66%^*^ Intermediate: 15.9%^*^ High: 9.35%^*^ Unknown: 9%^*^ | Invasive Breast Cancer | 1.000 (0.158 to 1.000) | 0.766 (0.732 to 0.798) | 0.013 | 1.000
Leong, 2012^64^ Fair | 141 women | 106 women | Mean age: 45.1 y Family hx of BC: 20.9% Personal hx of BC: 5% | All Breast Cancer | 1.000 (0.158 to 1.000) | 0.789 (0.697 to 0.862) | 0.083 | 1.000
Leong, 2012^64^ Fair | 141 women | 106 women | Mean age: 45.1 y Family hx of BC: 20.9% Personal hx of BC: 5% | Invasive Breast Cancer | 1.000 (0.025 to 1.000) | 0.800 (0.714 to 0.865) | 0.045 | 1.000
Youk, 2011^65^ Fair | 1,046 women 1,507 exams | 446 exams | Mean age: 47.5 y^*^ Personal history of BC: 61.8%^*^ | All Breast Cancer | 1.000 (0.715 to 1.000) | 0.717 (0.672 to 0.759) | 0.082 | 1.000

* Data are representative of entire study population, not the subgroup with dense breasts abstracted.

Abbreviations: BC=breast cancer; BI-RADS=Breast Imaging-Reporting and Data System; HHUS=hand-held ultrasound; hx=history.

Figure 2 Sensitivity of Supplemental HHUS, ABUS, and MRI in Detecting All Breast Cancer

Note: DCIS cases are included as “All Breast Cancer.”

* Good-quality study .

Abbreviations: ABUS=automated whole breast ultrasound; HHUS=hand-held ultrasound.

Figure 2 is a forest plot depicting the sensitivity of supplemental hand-held ultrasound, automated whole breast ultrasound, and MRI in detecting breast cancer, including DCIS. This figure is discussed in the Results section.

Figure 3 Specificity of Supplemental HHUS, ABUS, and MRI in Detecting All Breast Cancer

Note: DCIS cases are included as “All Breast Cancer.”

* Good-quality study .

Abbreviations: ABUS=automated whole breast ultrasound; HHUS=hand-held ultrasound.

Figure 3 is a forest plot depicting the specificity of supplemental hand-held ultrasound, automated whole breast ultrasound, and MRI in detecting breast cancer, including DCIS. This figure is discussed in the Results section.

Figure 4 Sensitivity of Supplemental HHUS and MRI in Detecting Invasive Breast Cancer

* Good-quality study.

Abbreviation: HHUS=hand-held ultrasound.

Figure 4 is a forest plot depicting the sensitivity of supplemental hand-held ultrasound, automated whole breast ultrasound, and MRI in detecting invasive breast cancer. This figure is discussed in the Results section.

Figure 5 Specificity of Supplemental HHUS and MRI in Detecting Invasive Breast Cancer

* Good-quality study.

Abbreviation: HHUS=hand-held ultrasound.

Figure 5 is a forest plot depicting the specificity of supplemental hand-held ultrasound, automated whole breast ultrasound, and MRI in detecting invasive breast cancer. This figure is discussed in the Results section.

One fair-quality study from the United States reported on screening women (68% had dense breasts) with ABUS.66 For the entire group, the sensitivity of ABUS after negative mammography was 67.6 percent (95% CI, 49.5 to 82.6%), specificity was 91.6 percent (95% CI, 91.0 to 92.3%), PPV was 4.1 percent and NPV was 99.8 percent. For invasive cancer only, sensitivity was 66.7 percent (95% CI, 48.2 to 82.0%), specificity was 91.6 percent (95% CI, 90.9 to 92.3%), PPV was 3.9 percent, and NPV was 99.8 percent (Table 14; Figures 2-5). The study's authors had a major financial interest in the ABUS system being evaluated.

Table 14 Supplemental ABUS Screening for Breast Cancer in Women With Dense Breasts: Test Performance Characteristics

Author, Year Quality | Study N | Subgroup N | Study/Subgroup characteristics | Breast Cancer Type | Sensitivity (95% CI) | Specificity (95% CI) | Positive Predictive Value | Negative Predictive Value
Kelly, 2010^66^ Fair | 4,419 women 6,425 exams | NA | Mean age: 53 y^*^ Dense breasts: 68% Family hx of BC: 30%^*^ Personal hx of BC: 10%^*^ Breast implants: 11%^*^ BRCA 1/2 carriers: 0.1%^*^ | All Breast Cancer | 0.676 (0.495 to 0.826) | 0.916 (0.910 to 0.923) | 0.041 | 0.998
Kelly, 2010^66^ Fair | 4,419 women 6,425 exams | NA | Mean age: 53 y^*^ Dense breasts: 68% Family hx of BC: 30%^*^ Personal hx of BC: 10%^*^ Breast implants: 11%^*^ BRCA 1/2 carriers: 0.1%^*^ | Invasive Breast Cancer | 0.667 (0.482 to 0.820) | 0.916 (0.909-0.923) | 0.039 | 0.998

* Data are representative of entire study population, not the subgroup with dense breasts abstracted.

Abbreviations: ABUS=automated whole breast ultrasound; BC=breast cancer; hx=history; NA=not applicable.

Three good-quality studies evaluated supplemental MRI screening among women with dense breasts and a negative screening mammogram. The sensitivity of supplemental MRI screening for all breast cancers (including invasive breast cancer and DCIS) was 100 percent in two good-quality studies23, 61 and 75 percent (95% CI, 34.9 to 96.8%) in a third good-quality study68 (Table 15; Figures 2-5). In two studies,23, 61 the authors provided us with unpublished data for the subgroup of women with dense breasts, excluding women with BRCA 1/2 mutations, histories of chest irradiation, or personal histories of breast cancer. In both of these studies, women had also had recent negative screening with HHUS. Sensitivity of supplemental MRI screening was high in all three studies, but the numbers of incident breast cancers in the analyzed subgroups were small (2 to 8), so sensitivity estimates have substantial uncertainty. In all three studies, most of the cancers detected by MRI were invasive rather than DCIS. Specificity ranged from 78.1 percent (95% CI, 73.2 to 82.5)61 to 93.2 percent23 (95% CI, 86.5 to 97.2), while the PPV of an abnormal MRI result ranged from 3.0 percent68 to 22.2 percent.23 Negative predictive values were very high in all three studies (99.9-100%).23, 61, 68

Table 15 Supplemental MRI Screening for Breast Cancer in Women With Dense Breasts: Test Performance Characteristics

Study, Year USPSTF Quality | Study N | Subgroup N | Study/Subgroup characteristics | Breast Cancer Type | Sensitivity (95% CI) | Specificity (95% CI) | Positive Predictive Value | Negative Predictive Value
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 334 exams | Mean age: 56.8 y Dense breasts: 100% BRCA 1/2 mutation: 0.5%-0.8%^*^ | All Breast Cancer | 1.000 (0.590 to 1.000) | 0.781 (0.732 to 0.825) | 0.090 | 1.000
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 334 exams | Mean age: 56.8 y Dense breasts: 100% BRCA 1/2 mutation: 0.5%-0.8%^*^ | Invasive Breast Cancer | 1.000 (0.541 to 1.000) | 0.788 (0.729 to 0.822) | 0.077 | 1.000
Kuhl, 2014^23^ Good | 443 women | 105 women | Mean age: 53.2 y | All Breast Cancer | 1.000 (0.292 to 1.000) | 0.941 (0.876 to 0.978) | 0.333 | 1.000
Kuhl, 2014^23^ Good | 443 women | 105 women | Mean age: 53.2 y | Invasive Breast Cancer | 1.000 (0.158 to 1.000) | 0.932 (0.865 to 0.972) | 0.222 | 1.000
Kriege, 2006^68^ Good | 1,779 women 4,134 exams | 1,723 exams | Mean age: 40 y^*^ Dense breasts; 100% Family hx of BC: 100%^*^ | All Breast Cancer | 0.750 (0.349 to 0.968) | 0.887 (0.872 to 0.902) | 0.030 | 0.999

* Data are representative of entire study population, not the subgroup with dense breasts abstracted.

Abbreviations: BC=breast cancer; hx=history.

In summary, most studies of diagnostic test performance of supplemental screening tests for women with dense breasts included women selected for elevated breast cancer risk, though women with BRCA 1/2 mutations, chest wall irradiation, and a personal history of breast cancer were excluded for the subgroups we analyzed. In these study subgroups, the sensitivity of supplemental MRI screening after negative screening mammography is likely to be higher than HHUS screening, but few studies to date have compared sensitivity of these screening modalities among women with dense breasts. Specificity of these modalities is similar, and PPV is low. No summary is possible for ABUS and DBT, with only a single study of ABUS and no studies of DBT identified for review. We found no studies of any supplemental test that examined the effect of age and other breast cancer risk factors on diagnostic test performance characteristics in women with dense breasts.

### Study Details

#### HHUS

One good-quality prospective diagnostic accuracy study from the United States reported on one to three rounds of HHUS screening at 12 month intervals following negative mammography in women with at least one breast quadrant identified as dense and at least one other risk factor for breast cancer.61 In this study, 7,473 exams were performed on 2,662 women (mean age 55.2 years). The reference standard was defined as the most severe biopsy results or clinical followup for 1 year. Loss to followup was less than 3 percent. Because 53 percent of participants had a personal history of breast cancer, the study authors provided us with supplemental unpublished data on the subgroup of 1,216 women undergoing 3,414 exams after excluding BRCA 1/2 mutation carriers, those with a history of breast cancer, or prior chest, mediastinal or axillary irradiation. In this subgroup, three interval cancers were identified on clinical followup. The incremental sensitivity of HHUS following negative mammography for all breast cancer was 83.3 percent (95% CI, 58.6 to 96.4), while specificity was 86.4 percent (95% CI, 85.2 to 87.5), PPV was 3.0 percent, and NPV was 99.0 percent. For invasive cancer, sensitivity was 82.4 percent (95% CI, 56.6 to 96.2), specificity was 86.4% (95% CI, 85.2 to 87.5), PPV was 3.0 percent, and NPV was 99.9 percent. Of note, in this subgroup, 334 women underwent MRI screening after 3 negative mammograms and 3 negative HHUS exams over a 24-month period, and an additional 7 cancers (6 invasive) were identified (see MRI section for additional details).

A good-quality retrospective study from an Italian charity breast screening clinic included 3,556 women with BI-RADS c to d density undergoing 7,224 HHUS screening exams following a negative screening mammogram.62 Followup for interval cancers included searching clinic archives and data linkage with hospital discharge records; the authors estimated the probability that interval cancers were not identified was less than 5 percent. Eight interval cancers were identified. The incremental sensitivity of HHUS following negative mammography was 80 percent (95% CI, 64.5 to 91.0), specificity was 94.5 percent (95% CI, 94.0 to 95.0), PPV was 7.5 percent and NPV was 99 percent. For invasive cancer, sensitivity was 77.8 percent (95% CI, 60.9 to 89.9%), specificity was 94.5 percent (95% CI, 94.0 to 95.0), PPV was 6.6% and NPV was 99.9%.

A smaller fair-quality diagnostic accuracy study from Connecticut reported on 935 women with heterogeneous or extremely dense breasts undergoing a single round of HHUS, of whom 648 had a recent negative screening mammogram.63 HHUS was performed at a university radiology practice by mammography technologists and read by one of eight breast radiologists who were aware of the prior mammography results. Followup was based on biopsy results or mammography and/or HHUS performed at least 15 months after the initial exam. Nineteen percent were lost to followup. No interval cancers were detected. Among the 648 women with negative mammograms, for all breast cancer, sensitivity was 100 percent (95% CI, 29.2 to 100), specificity was 76.7 percent (95% CI, 73.3 to 79.8), PPV was 2.0 percent and NPV was 100 percent. For invasive breast cancer, sensitivity was 100 percent (95% CI, 15.8 to 100), specificity was 76.6 percent (95% CI, 73.2 to 79.8), PPV was 1.3 percent, and NPV was 100 percent.

Women of Asian ethnicity have been noted to have a higher proportion of BI-RADS c or d breast density in the United States.19, 20 Two fair-quality studies from Asia64, 65 addressed diagnostic test characteristics for women with dense breasts. In a study of 1,046 women with dense breasts undergoing 1,507 HHUS exams at an academic medical center in South Korea, 61.8 percent of participants had a personal history of breast cancer; however outcomes were reported separately for women without a history of breast cancer (446 screening exams).65 Clinical followup extended over 2 years; no interval cancers were identified. In the subgroup of women without a personal history of breast cancer, the incremental sensitivity of screening HHUS was 100 percent (95% CI, 71.5 to 100), specificity was 71.7 percent (95% CI, 67.2 to 75.9), PPV was 8.2 percent and NPV was 100 percent. Breast cancers were not stratified as invasive versus DCIS.

A small study from a general hospital radiology practice in Singapore reported screening HHUS on 141 women with negative mammograms; all had heterogeneous or extremely dense breasts and 5 percent had a personal history of breast cancer.64 Followup consisted of a retrospective review of all breast imaging at two years; 35 women (25%) were lost to followup, leaving 106 women for assessment of diagnostic test characteristics. No interval cancers were identified. For all breast cancer, sensitivity of HHUS after negative mammography was 100 percent (95% CI, 15.8 to 100%), specificity was 78.9 percent (95% CI, 69.7 to 86.2), PPV was 8.3 percent and NPV was 100 percent. For invasive breast cancer, sensitivity was 100 percent (95% CI, 2.5 to 100), specificity was 80 percent (95% CI, 71.4 to 86.5), PPV was 4.5 percent, and NPV was 100 percent.

#### ABUS

One fair-quality diagnostic test performance study from the United States reported screening women with ABUS.66 An important limitation of the study was that the lead author on the study had a majority financial interest in the ABUS technology being studied, and the co-author was also a shareholder. This study reported on a group of 4,419 women underdoing 6,425 ABUS and mammography exams, of which 4,347 exams (67.7%) were performed on women with BI-RADS c to d breast density. Ten percent of participants had a personal history of breast cancer and 30 percent had a family history of breast cancer; 0.1 percent were known BRCA 1/2 mutation carriers. Over one year, 20 percent of the group was lost to followup. For the entire group, ABUS sensitivity for all breast cancer in women with negative mammography was 67.6 percent (95% CI, 49.5 to 82.6), specificity was 91.6 percent (95% CI, 91.0 to 92.3), PPV was 4.1 percent and NPV was 98.8 percent. For invasive breast cancer, sensitivity was 66.7 percent (95% CI, 48.2 to 82.0), specificity was 91.6 percent (95% CI, 90.9 to 92.3), PPV was 3.9 percent and NPV was 99.8 percent.

#### MRI

The largest sample of women with dense breasts receiving supplemental MRI screening derived from the good-quality, multi-center Dutch MRISC study.68 Conducted from 1999 to 2003, MRISC recruited asymptomatic women aged 25 to 70 years who had a lifetime breast cancer risk of ≥15 percent to undergo annual MRI screening in addition to annual mammography screening and screening clinical breast examination every 6 months (mean 2.3 screening rounds). All of the women had a family history of breast cancer. For this review, we abstracted data for a subgroup of women with BI-RADS c or d breast density without BRCA 1/2 gene mutations who underwent 1,723 exams. Among these women, breast cancer was diagnosed in 8 women, and 6 of these cancers were detected by MRI (sensitivity 75% [95% CI, 34.9 to 96.8]). Nearly all women (1,522 of 1,524) with negative MRI screening results remained breast cancer free during the following year. The specificity of screening MRI was 88.8 percent (95% CI, 87.2 to 90.2), PPV was 3.0 percent and NPV was 99.9 percent. In the subgroup of women with dense breasts, sensitivity of supplemental MRI for invasive cancer vs. DCIS was not reported.

Authors of a good-quality, multi-center U.S. study provided us with unpublished subgroup data for 334 asymptomatic women with elevated breast cancer risk and heterogeneously or extremely dense breasts (without BRCA 1/2 mutation, personal history of breast cancer, or history of chest wall irradiation) who underwent a single round of MRI screening following three annual rounds of mammographic and breast ultrasound screening.61 For these women, the most recent mammogram and breast ultrasound were interpreted as normal. Of the 334 women, 7 were diagnosed with breast cancer by MRI screening, and there were no interval cancers in one year of followup, resulting in a sensitivity of 100 percent (95% CI, 59.0 to 100). The screening MRI was read as abnormal in 78 of 334 women, yielding a specificity of 78.1 percent (95% CI, 73.2 to 82.5) and a PPV of 9.0 percent; NPV was 100 percent. Six of the seven cancers were invasive; sensitivity for invasive cancer was 100 percent (95% CI, 54.1 to 100), specificity was 78.8% (95% CI, 72.9 to 82.2), PPV was 7.7 percent and NPV was 100 percent.

In a good-quality single-center German study, a subgroup of 105 asymptomatic women with dense breasts underwent one or two rounds of annual MRI screening following negative screening mammography and screening ultrasound.23 An aim of the study was to demonstrate comparable interpretive results with abbreviated MRI protocol versus a full diagnostic protocol. We report outcomes using the full diagnostic protocol. In the 105 women, 3 breast cancers were diagnosed within two years of screening (2 invasive cancers and 1 DCIS), all of which were MRI detected, yielding a sensitivity of 100 percent (95% CI, 29.2 to 100). There were no interval breast cancers during two years of followup, so the NPV was 100 percent. MRI was read as abnormal in 9 women, yielding a specificity of 94.1 percent (95% CI, 87.6 to 97.8) and a PPV of 33.3 percent. For invasive breast cancer, sensitivity was 100 percent (95% CI, 15.8 to 100%), specificity was 93.2 percent (95% CI, 86.5 to 97.2), PPV was 22.2 percent and NPV was 99.9 percent. Performance was similar with the abbreviated and full diagnostic protocols.

It is notable that the two of three studies on supplemental MRI screening in women with dense breasts targeted women with elevated lifetime breast cancer risk.61, 68 Thus, the subgroup of women with dense breasts in these studies likely had elevated breast cancer risk based on risk factors in addition to breast density (e.g., family history of breast cancer). Only one study included a subgroup that received supplemental MRI screening solely on account of breast density.23

#### DBT

We found no studies of the test performance characteristics of DBT among women with dense breasts.

## Key Question 3 When Performed After a Negative Screening Mammogram in Women Found to Have Dense Breasts, What Is the Effectiveness of Supplemental Screening With Breast Ultrasound, MRI, or DBT on Proximate Clinical Outcomes, Including Cancer Detection Rates, DCIS Detection Rates, Stage at Diagnosis, Recall Rates, Biopsy Rates, and Interval Cancer Rates?

### Summary of Results

We found no RCTs comparing any clinical outcomes with and without supplemental screening. We tended toward broad inclusion of observational studies reporting on clinical outcomes of supplemental screening women with dense breasts to identify as much information as possible, and considered studies reporting breast density based on the BI-RADS density system, Wolf classification (>50% density) or selecting women described as having heterogeneously or extremely dense breasts (Tables 5-8). We identified ten studies of HHUS61-65, 69-73 (two good-quality61, 62), three fair-quality studies of ABUS,57, 66, 67, 74 three good-quality studies of MRI,23, 61, 68 and four fair-quality studies of DBT.75-78 Many studies selected women at higher risk for breast cancer due to risk factors other than increased breast density, such as BRCA 1/2 mutation carriage or personal history of breast cancer. We included studies if we were able to abstract a subgroup with dense breasts on mammography or if factors conferring very high risk for breast cancer were not highly prevalent. In the case of two good-quality studies,23, 61 the authors provided us unpublished data on the study subgroup with dense breasts and excluded women at high risk due to BRCA 1/2 mutations, history of chest wall irradiation, or a personal history of breast cancer. Most studies reported descriptively on incremental impacts on outcomes after supplemental testing among a cohort of women with dense breasts who had recent negative mammography. Two studies of HHUS,61, 62 two studies of ABUS,66, 74 three studies of MRI23, 61, 68 and one of DBT78 compared proximate outcomes from mammography to outcomes in the same group with supplemental testing. One fair-quality study of ABUS67 and three fair-quality studies of DBT compared proximate outcomes among two groups of women, one undergoing mammography and another undergoing mammography as well as supplemental testing. Only one of these studies adjusted for differences between the groups.75

In general, supplemental testing consistently detected additional breast cancers not identified by mammography (Tables 16-20; Figure 6). Findings from good-quality studies for supplemental testing modalities are found in Table 20. The two good-quality studies for HHUS (one each from the U.S. and Italy) were consistent in their estimates of the incremental cancer detection rate of 4.4 (95% CI, 2.5 to 7.2) per 1,000 exams,61, 62 In these two studies, the majority of cancers were invasive: 14/15 (93%)61 and 28/32 (88%).62 In the same groups of women, mammography cancer detection rates were 4.7^61^ in the U.S. study and 2.8^62^ per 1,000 exams in the Italian study. In three good-quality studies of women with dense breasts undergoing supplemental MRI screening, incremental breast cancer detection rates ranged from 3.5 per 1,000 exams (95% CI,1.3 to 7.6)68 to 21.0 per 1,000 exams (95% CI, 8.5 to 42.7).61 Mammography cancer detection rates in two of these studies for women with dense breasts were 4.1^68^ and 7.0^61^ per 1,000 exams. In studies of supplemental MRI screening, MRI detected predominantly small, early-stage invasive breast cancers. However, the overall numbers of detected cancers were small (2 to 7), and women in these studies had higher lifetime breast cancer risk than the general population of women with dense breasts.

Table 16 Supplemental HHUS Screening for Breast Cancer in Women With Dense Breasts: Cancer Detection Outcomes

Author, Year USPSTF Quality | Study N | Subgroup N | Breast Cancer Type | Cancers Detected | Cancer Detection Rate (95% CI) | Recall/Biopsy Rate^*^ (95% CI)
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 1,216 women 3,414 exams | All Breast Cancer | 15/3,414 exams | 4.4 per 1,000 exams (2.5 to 7.2) | Recall: 139 per 1,000 exams (127.7 to 151.2)
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 1,216 women 3,414 exams | Invasive Breast Cancer | 14/3,414 exams | 4.1 per 1,000 exams (2.2 to 6.9) | Recall: 139 per 1,000 exams (127.7 to 151.2)
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 1,216 women 3,414 exams | Interval Cancers | 3/3,414 exams | 0.9 per 1,000 exams (0.2 to 2.6) | Recall: 139 per 1,000 exams (127.7 to 151.2)
Corsetti, 2011^62^ Good | 5,509 women 12,504 exams | 3,356 women 7,224 exams | All Breast Cancer | 32/7,224 exams | 4.4 per 1,000 exams (3.0 to 6.2) | Biopsy: 59 per 1,000 exams (53.7 to 64.7)
Corsetti, 2011^62^ Good | 5,509 women 12,504 exams | 3,356 women 7,224 exams | Invasive Breast Cancer | 28/7,224 exams | 3.9 per 1,000 exams (2.6 to 5.6) | Biopsy: 59 per 1,000 exams (53.7 to 64.7)
Corsetti, 2011^62^ Good | 5,509 women 12,504 exams | 3,356 women 7,224 exams | Interval Breast Cancer | 8/7,224 exams | 1.1 per 1,000 exams (0.5 to 2.2) | Biopsy: 59 per 1,000 exams (53.7 to 64.7)
Hooley, 2012^63^ Fair | 935 women | 648 women | All Breast Cancer | 3/648 women | 4.6 per 1,000 women (1.0 to 13.5) | Recall: 236 per 1,000 women (203.9 to 270.4) Biopsy: 71 per 1,000 women (52.4 to 93.6)
Hooley, 2012^63^ Fair | 935 women | 648 women | Invasive Breast Cancer | 2/648 women | 3.1 per 1,000 women (0.4 to 11.1) | Recall: 236 per 1,000 women (203.9 to 270.4) Biopsy: 71 per 1,000 women (52.4 to 93.6)
Leong, 2012^64^ Fair | 141 women | 106 women | All Breast Cancer | 2/106 women | 18.9 per 1,000 women (1.7 to 50.3) | Recall: 170 per 1,000 women^‡^ Biopsy: 132 per 1,000 women (74.1 to 211.7)^†^
Leong, 2012^64^ Fair | 141 women | 106 women | Invasive Breast Cancer | 1/106 women | 9.4 per 1,000 women (0.2 to 51.4) | Recall: 170 per 1,000 women^‡^ Biopsy: 132 per 1,000 women (74.1 to 211.7)^†^
Leong, 2012^64^ Fair | 141 women | 106 women | Interval Breast Cancer | 0/106 | 0 per 1,000 women | Recall: 170 per 1,000 women^‡^ Biopsy: 132 per 1,000 women (74.1 to 211.7)^†^
Youk, 2011^65^ Fair | 1,046 women 1,507 exams | 446 exams | All Breast Cancer | 11/446 exams | 24.7 per 1,000 exams (12.4 to 43.7) | Recall: 137 per 1,000 exams (106.3 to 172.2) Biopsy: 110 per 1,000 exams (82.4 to 142.6)
Parris, 2013^71^ Fair | 5,519 women | NA | All Breast Cancer | 10/5,519 women | 1.8 per 1,000 women (0.9 to 3.3) | Recall: NR Biopsy: 33 per 1,000 women (28.3 to 37.8)
Parris, 2013^71^ Fair | 5,519 women | NA | Invasive Breast Cancer | 9/5,519 women | 1.6 per 1,000 women (0.7 to 3.1) | Recall: NR Biopsy: 33 per 1,000 women (28.3 to 37.8)
Weigert, 2012^73^ Fair | 8,647 women 8,647 exams | NA | All Breast Cancer | 25/8,647 women | 2.9 per 1,000 women (1.9 to 4.3) | Recall: 138 per 1,000 women (130.8 to 145.4) Biopsy: 48 per 1,000 women (43.9 to 53.1)
Weigert, 2012^73^ Fair | 8,647 women 8,647 exams | NA | Invasive Breast Cancer | 21/8,647 women | 2.4 per 1,000 women (1.5 to 3.7) | Recall: 138 per 1,000 women (130.8 to 145.4) Biopsy: 48 per 1,000 women (43.9 to 53.1)
Girardi, 2013^70^ Fair | 22,131 women | 9,960 women | All Breast Cancer | 22/9,960 women | 2.2 per 1,000 women (1.4 to 3.3) | Recall : NR Biopsy : NR
Venturini, 2013^72^ Fair | 1,666 women | 826 women | All Breast Cancer | 2/826 women | 2.4 per 1,000 women (0.3 to 8.7) | Recall: 95 per 1,000 women (75.4 to 116.5) Biopsy: 12 per 1,000 women (5.8 to 22.2)
Venturini, 2013^72^ Fair | 1,666 women | 826 women | Invasive Breast Cancer | 2/826 women | 2.4 per 1,000 women (0.3 to 8.7) | Recall: 95 per 1,000 women (75.4 to 116.5) Biopsy: 12 per 1,000 women (5.8 to 22.2)
Brancato, 2007^69^ Fair | 5,227 women | NA | All Breast Cancer | 2/5,227 women | 0.4 per 1,000 women (0 to 1.4) | Recall: 21 per 1,000 women (17.3 to 25.3) Biopsy: 12 per 1,000 women (9.6 to 15.8)
Brancato, 2007^69^ Fair | 5,227 women | NA | Invasive Breast Cancer | 2/5,227 women | 0.4 per 1,000 women (0 to 1.4) | Recall: 21 per 1,000 women (17.3 to 25.3) Biopsy: 12 per 1,000 women (9.6 to 15.8)

* Biopsy rate includes needle aspiration, core needle, and open biopsies.

† Data are based on the 106 women with complete followup (out of 141 total).

Abbreviations: CI=confidence interval; HHUS=hand-held ultrasound; NA=not applicable; NR=not reported.

Table 17 Supplemental ABUS Screening for Breast Cancer in Women With Dense Breasts: Cancer Detection Outcomes

Author, Year USPSTF Quality | Study N | Subgroup N | Breast Cancer Type | Cancers Detected | Cancer Detection Rate (95% CI) | Recall/ Biopsy Rate^*^ (95% CI)
Brem, 2015^74^ Fair | 15,318 women | NA | All Breast Cancer | 30/15318 women | 1.9 per 1,000 exams (1.3 to 2.8) | Recall: 135 per 1,000 exams (129.3 to 140.2) Biopsy: 36 per 1,000 exams (34.1 to 40.2)
Brem, 2015^74^ Fair | 15,318 women | NA | Invasive Breast Cancer | 28/15318 women | 1.8 per 1,000 exams (1.2 to 2.6) | Recall: 135 per 1,000 exams (129.3 to 140.2) Biopsy: 36 per 1,000 exams (34.1 to 40.2)
Kelly, 2010^66^ Fair | 4,419 women 6,425 exams | NA | All Breast Cancer | 23/6425 exams | 3.6 per 1,000 exams (2.3 to 5.4) | Recall: 87 per 1,000 exams (80.2 to 94.2)
Kelly, 2010^66^ Fair | 4,419 women 6,425 exams | NA | Invasive Breast Cancer | 22/6425 exams | 3.4 per 1,000 exams (2.1 to 5.2) | Recall: 87 per 1,000 exams (80.2 to 94.2)
Kelly, 2010^66^ Fair | 4,419 women 6,425 exams | NA | Interval Breast Cancers | 11/6425 exams | 1.7 per 1,000 exams (0.9 to 3.1) | Recall: 87 per 1,000 exams (80.2 to 94.2)
Giuliano, 2013^67^ Fair | 7,497 women DM only (CG): 4,076 women | DM+ABUS (IG): 3,418 women | All Breast Cancer | IG: 52/3418 women CG: 19/4076 women | IG: 15.21 per 1,000 women (11.4 to 19.9) CG: 4.7 per 1,000 women (2.8 to 7.3) | Recall: 15 per 1,000 women (11.1 to 19.6)
Giuliano, 2013^67^ Fair | 7,497 women DM only (CG): 4,076 women | DM+ABUS (IG): 3,418 women | Invasive Breast Cancer | IG: 42/3418 women CG: 19/4076 women | IG: 12.3 per 1000 women (8.9 to 16.6) CG: 4.7 per 1,000 women (2.8 to 7.3) | Recall: 15 per 1,000 women (11.1 to 19.6)

* Biopsy rate includes needle aspiration, core needle, and open biopsies.

Abbreviations: ABUS=automated whole breast ultrasound; BC=breast cancer; BI-RADS=Breast Imaging-Reporting Data System; CG=control group; CI=confidence interval; DM=digital mammography; IG=intervention group.

Table 18 Supplemental MRI Screening for Breast Cancer in Women With Dense Breasts: Cancer Detection Outcomes

Author, Year USPSTF Quality | Study N | Subgroup N | Breast Cancer Type | Cancers Detected | Cancer Detection Rate (95% CI) | Recall/Biopsy Rate^*^ (95% CI)
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 334 exams | All Breast Cancer | 7/334 exams | 21 per 1,000 exams (8.5 to 42.7) | Recall: 234 per 1,000 exams (189.2 to 282.7)
Berg, 2012^61^ Good | 2,262 women 7,473 exams | 334 exams | Invasive Breast Cancer | 6/334 exams | 18 per 1,000 exams (6.6 to 38.7) | Recall: 234 per 1,000 exams (189.2 to 282.7)
Kuhl, 2014^23^ Good | 443 women | 105 women | All Breast Cancer | 3/105 women | 28.6 per 1,000 women (5.9 to 81.2) | Recall: 86 per 1,000 women (40.0 to 156.5)
Kuhl, 2014^23^ Good | 443 women | 105 women | Invasive Breast Cancer | 2/105 women | 19 per 1,000 women (2.3 to 67.1) | Recall: 86 per 1,000 women (40.0 to 156.5)
Kriege, 2006^68^ Good | 1,779 women 4,134 exams | 1,723 exams | All Breast Cancer | 6/1723 exams | 3.5 per 1,000 exams (1.3 to 7.6) | Recall: 115 per 1,000 exams (100.2 to 130.9) Biopsy: NR
Kriege, 2006^68^ Good | 1,779 women 4,134 exams | 1,723 exams | Interval Breast Cancer | 2/1723 exams | 1.2 per, 1000 exams (0.1 to 4.2) | Recall: 115 per 1,000 exams (100.2 to 130.9) Biopsy: NR

* Biopsy rate includes needle aspiration, core needle, and open biopsies.

Abbreviations: CI=confidence interval; DCIS=ductal carcinoma in situ; NR=not reported.

Table 19 Supplemental DBT Screening for Breast Cancer in Women With Dense Breasts: Cancer Detection Outcomes

Author, Year USPSTF Quality | Study N | Subgroup N | Breast Cancer Type | Cancers Detected | Cancer Detection Rate (95% CI) | Recall/Biopsy Rate^*^ (95% CI)
McCarthy, 2014^75^ Fair | 18,220 women | DBT+DM (IG) = 5,056 exams DM only (CG) = 3,489 exams | All Breast Cancer | IG: 35/5056 exams CG: 18/3489 exams | IG: 6.9 per 1,000 exams (4.8 to 9.6) CG: 5.2 per 1,000 exams (3.1 to 8.1) | Recall: IG: 108 per 1,000 exams (99.6 to 116.9) CG: 128 per 1,000 exams (117.2 to 139.7)
McCarthy, 2014^75^ Fair | 18,220 women | DBT+DM (IG) = 5,056 exams DM only (CG) = 3,489 exams | Invasive Breast Cancer | IG: 24/5056 exams CG: 12/3489 exams | IG: 4.7 per 1,000 exams (3.0 to 7.0) CG: 3.4 per 1,000 exams (1.8 to 6.0) | Recall: IG: 108 per 1,000 exams (99.6 to 116.9) CG: 128 per 1,000 exams (117.2 to 139.7)
Haas, 2013^76^ Fair | DBT+DM (IG) = 6,100 women DM only (CG) = 7,058 women | DBT+DM IG) = 2,639 exams DM only (CG) = 2,158 exams | All Breast Cancer | NR | NR | Recall: IG: 97 per 1,000 women (86.0 to 108.9) CG: 166 per 1,000 women (150.4 to 182.3)
Rose, 2013^77^ Fair | DBT+DM (IG) = 9,499 exams DM only (CG) = 13,856 exams | DBT+DM (IG) = 4,666 exams DM only (CG) = 7,009 exams | All Breast Cancer | IG: 25/4666 exams CG: 28/7009 exams | IG: 5.4 per 1,000 exams (3.5 to 7.9) CG: 4.0 per 1,000 exams (2.7 to 5.8) | Recall: IG: 69 per 1,000 exams (61.9 to 76.7) CG: 91 per 1,000 exams (84.4 to 110.1)
Ciatto, 2013^70^ Fair | 7,294 exams | 1,215 exams | All Breast Cancer | DBT+DM: 8/1215 exams DM only: 5/1215 exams | DBT+DM: 6.6 per 1,000 exams (2.9 to 12.9) DM only: 4.1 per 1,000 exams (1.3 to 9.6) | Recall: DBT+DM: 66 per 1,000 exams (52.6 to 81.3)) DM only: 72 per 1,000 exams (57.6 to 87.6)

* Biopsy rate includes needle aspiration, core needle, and open biopsies.

Abbreviations: CI=confidence interval; CG=control group; DM=digital mammography; IG=intervention group.

Table 20 Cancer Detection, Recall, and Biopsy Rates of Good-Quality Supplemental Screening Studies

Author, Year USPSTF Quality | Country | Modality | Breast Cancer Detection Rate (95% CI) | Invasive Breast Cancer Detection | Recall Rate | Biopsy Rate^*^
Berg, 2012^61^ Good | United States | HHUS | 4.4 per 1,000 exams (2.5 to 7.2) | 93.3% (14/15) | 138.8 per 1,000 exams (474/3414) | NR
Corsetti, 2011^62^ Good | Italy | HHUS | 4.4 per 1,000 exams (3.0 to 6.2) | 87.5% (28/32) | NR | 59.0 per 1,000 exams (427/7224)
Berg, 2012^61^ Good | United States | MRI | 21.0 per 1,000 exams (8.5 to 42.7) | 85.7% (6/7) | 233.5 per 1,000 exams (78/334) | NR
Kuhl, 2014^23^ Good | Germany | MRI | 28.6 per 1,000 women (5.9 to 81.2) | 66.7% (2/3) | 85.7 per 1,000 women (9/105) | NR
Kriege, 2006^68^ Good | Netherlands | MRI | 3.5 per 1,000 exams (2.0 to 9.1) | NR | 109 per 1,000 exams (199/1458) | NR

* Includes needle aspiration, core needle, and open biopsies.

Abbreviations: HHUS=hand-held ultrasound; NR=not reported.

Figure 6 Breast Cancer Detection Rates of Supplemental HHUS, ABUS, MRI, and DBT

Note: Includes DCIS cases.

* Good-quality study.

Abbreviations: ABUS=automated whole breast ultrasound; DBT=digital breast tomosynthesis; HHUS=hand-held ultrasound.

Figure 6 is a forest plot depicting the breast cancer detection rates of supplemental hand-held ultrasound, automated whole breast ultrasound, MRI, and digital breast tomosynthesis. This figure is discussed in the Results section.

Figure 7 Invasive Breast Cancer Detection Rates of Supplemental HHUS, ABUS, MRI, and DBT

* Good-quality study.

Abbreviations: ABUS=automated whole breast ultrasound; DBT=digital breast tomosynthesis; HHUS=hand-held ultrasound.

Figure7 is a forest plot depicting the invasive breast cancer detection rates of supplemental hand-held ultrasound, automated whole breast ultrasound, MRI, and digital breast tomosynthesis. This figure is discussed in the Results section.

Figure 8 Biopsy Rates of Supplemental HHUS and ABUS

Abbreviations: ABUS=automated breast ultrasound; HHUS=hand-held ultrasound.

Figure 8 is a forest plot depicting the biopsy rates of supplemental hand-held ultrasound and automated whole breast ultrasound. This figure is discussed in the Results section.

Recall rates for supplemental HHUS (after negative mammography) varied in these good quality studies and were reported only in a single U.S. study: 13.9 percent.61 Biopsy rates were 6.9 percent in the in the U.S. study61 compared to 5.9 percent in the Italian study.62 In the good-quality studies of supplemental MRI screening in women with dense breasts, results were interpreted as abnormal at rates ranging from 8.6 percent 68 to 23.4 percent.61 For two studies, data on biopsy rates in subgroups of women with dense breasts in the MRI studies were either not reported68 or were not available.23, 61 However, in a good-quality study in the United States, 7.0 percent of entire population of women undergoing supplemental MRI screening underwent biopsy on account of abnormal MRI results (the incremental biopsy rate) following negative screening mammography and ultrasound.61 Because most studies reported on only 1 (at most 3) rounds of screening, the cumulative effect of recall for additional imaging and biopsy would be greater over time, with additional rounds of screening.

Only fair-quality studies were identified for ABUS and DBT. For ABUS the incremental cancer detection rate ranged from 1.8 per 1,000 exams (95% CI 1.2 to 2.6)74 to 15.1 per 1,000 exams (95% CI, 11.4 to 19.9).67 In one of these studies, the cancer detection rate from mammography was 4.7 per 1000 exams (95% CI, 2.8 to 7.3).66

Four fair-quality studies of DBT reported separately on screening populations of women with dense breasts.75-78 Three of these studies reported on cancer detection rates: detection rates with digital mammography in women with dense breasts were similar (4.0 to 5.2 per 1,000 exams) and were higher with the addition of DBT (5.4 per 1,000 exams [95% CI, 3.5 to 7.9]77 to 6.9 per 1,000 exams [95% CI, 4.8 to 9.6]75) (Table 19). Invasive cancer detection rates for women with dense breasts were reported only for one study: 3.4 per 1,000 exams with digital mammography and 4.7 per 1,000 exams with the addition of DBT.75 Recall rates were reported by all four studies, though recalls for additional imaging were not distinguished from recalls for biopsy. Recall rates declined with the addition of DBT. Recall rates were higher in the U.S. studies, ranging from 9.1 percent77 to 16.6 percent76 for digital mammography compared to 6.9 percent77 to 10.8 percent75 with the addition of DBT. In the Italian study, in which all digital mammograms and DBT images underwent double-reading (i.e., independent interpretation by two radiologists), recall rates declined from 7.2 percent to 6.6 percent with the addition of DBT.70 Biopsy rates were not reported separately for women with dense breasts in any of these studies.

Overall, the evidence indicates that supplemental screening among women with dense breasts and recent negative mammography can consistently identify additional cancers, most of which are invasive, but also leads to additional recalls and biopsies, with the possible exception of DBT, though evidence is quite limited. Studies of proximate screening outcomes among women with dense breasts undergoing supplemental screening tests were predominately designed to estimate the incremental impact of supplemental testing on cancer detection rates and diagnostic testing. Many lacked sufficient followup to identify false negatives, and none compared interval breast cancer rates or potential surrogates for breast cancer mortality among two groups of women with dense breasts undergoing screening mammography with vs. without supplemental testing. Such studies would potentially provide greater insight regarding long-term benefits and harms of supplemental screening. In addition, many study populations were at higher breast cancer risk than would be conferred by increased breast density alone, raising questions about the generalizability of findings to the broad population of women with dense breasts. Variability in breast cancer risk may explain some observed differences in rates of breast cancer detection by mammography and supplemental testing. Other sources of variation may relate to variability in skill and experience among interpreting radiologists, and variation in technology used for supplemental testing. Long terms RCTs or well-designed comparative observational studies could provide much stronger evidence about meaningful outcomes of supplemental screening for women with dense breasts.

### Study Details

#### HHUS

One good-quality prospective diagnostic accuracy study from the United States reported on one to three rounds of HHUS screening at 12 month intervals in women with dense breasts and at least one other risk factor for breast cancer.61 In this study, 7,473 exams were performed on 2,662 women (mean age, 55.2 years). Because 53 percent of participants had a personal history of breast cancer, the authors provided unpublished data on the subgroup of 1,216 women undergoing 3,414 exams, excluding BRCA 1/2 mutation carriers and those with a history of breast cancer chest irradiation. Loss to followup was less than 3 percent. In this subgroup, screening mammography detected 24 cancers (cancer detection rate, 19.7 per 1,000 exams), 15 of which were invasive. Among women with negative mammography, HHUS after negative mammography detected an additional 15 breast cancers (14 invasive, 1 DCIS), for a cancer detection rate of 4.4 per 1,000 exams (95% CI, 2.5 to 7.2). Three interval cancers were identified on clinical followup. The stage distribution for the subgroup was not available. In the overall group for those cancers where nodal staging was available, 1/27 cancers detected by HHUS had positive axillary nodes. The subgroup recall rate was 13.9 percent (95% CI, 12.9 to 14.0) for HHUS. Biopsy rates were not available for the subgroup. In the overall group, 8.8 percent of women underwent biopsy on account of HHUS results during the initial screen, and during subsequent screening rounds, the biopsy rate due to HHUS was 5.5 percent.

A good-quality diagnostic accuracy study from an Italian breast cancer screening program reported on 3,356 asymptomatic women with BI-RADS c to d density undergoing 7,224 HHUS screening exams following a negative screening mammogram.62 Fifty five percent were less than 50 years of age. Based on searches of clinic archives and data linkage with hospital discharge records, the authors estimated the probability that interval cancers were not identified was less than 5 percent. Screening HHUS detected 32 cancers, for an incremental cancer detection rate of 4.4 per 1,000 exams (95% CI, 3.0 to 6.2). Twenty eight of these were invasive (cancer detection rate, 3.9 per 1,000 exams [95% CI, 2.6 to 5.6]). Of the 32 cancers, 4 were in-situ, 24 were Stage I, 3 were Stage II, and one was unknown stage. Mammography in the same group detected 20 breast cancers (cancer detection rate, 2.8 per 1,000 exams); 4 in-situ, 11 Stage I, 1 Stage II, and 4 were unknown stage. There were 8 interval cancers identified within 1 year of screening, 2 were in-situ and 6 were Stage I. The total recall rate was not reported, but the biopsy rate was 5.9 percent (95% CI, 5.4 to 6.5).62

Three fair-quality studies reported on experience with HHUS in Connecticut, where insurance coverage of ultrasound screening for women with dense breasts was mandated in 2005, and breast density reporting to women as part of mammography results was mandated as of October 2009.^63, 71, 73^ A smaller fair-quality diagnostic accuracy study from Connecticut reported on 935 women (mean age, 52 years) with heterogeneous or extremely dense breasts undergoing a single round of HHUS, of whom 648 had a recent negative screening mammogram.63 The incremental cancer detection rate of HHUS was 3/638 or 4.6 per 1,000 exams (95% CI, 1.0 to 13.5). Two of the cancers were invasive and no interval cancers were detected. The overall recall rate was 23.6 percent and the biopsy rate was 7.0 percent. One cohort study reported screening results for a single screening round of 8,647 women undergoing HHUS after a negative screening mammogram at one of 6 radiology practices (mean age, 54.4 years).73 HHUS detected 25 breast cancers (21 invasive, 4 DCIS) among the 8,647 exams with negative mammograms for a cancer detection rate of 2.9 per 1,000 exams (95% CI, 1.9 to 4.3). The overall recall rate was 13.8 percent, with a biopsy rate of 4.8 percent. No comprehensive followup was reported. A single center study reported on findings from 5,519 women (mean age, 53.6 years) undergoing a single screening HHUS following mammography after the mandated reporting law went into effect.71 The study included HHUS findings from some women who had abnormal mammograms but reported only HHUS results from the breast quadrants noted as normal on mammography (the number of these exams included was not recorded). Eighty nine percent had heterogeneous or very dense breasts, and 6 percent had a personal history of breast cancer. HHUS detected 10 breast cancers (9 invasive, 1 DCIS) for a cancer detection rate of 1.8 per 1,000 exams (95% CI, 0.9 to 3.3). The overall biopsy rate for HHUS (biopsy was recommended for suspicious or highly suspicious findings – BI-RADS 4-5) was 3.2 percent (95% CI, 2.8 to 3.8). The number of recommendations for short interval followup was not reported.

Three fair-quality studies from Italy reported on clinical outcomes of HHUS screening in women with dense breasts. In a smaller cohort study of fair-quality, 1,666 women aged 40 to 49 years with an average lifetime risk of 11.6 percent were recruited, of whom 800 underwent one round of screening breast HHUS for BI-RADS c/d breast density, and 26 for breast implants.72 This combined group of 826 had an incremental cancer detection rate of 2.4 per 1,000 exams (95% CI, 0.3 to 8.7) and a recall rate of 9.5 percent (95% CI, 7.5 to 11.6). Ten cancers were detected among the 826 women on mammography; two additional cancers were diagnosed on HHUS, one Stage 1 and one Stage 2. No followup of negative HHUS screens was reported. A study of 5,227 women (68% were aged 40 to 49 years) with BI-RADS density c to d and negative mammography were screened with HHUS within 1 month of the mammogram.69 Two cancers (both invasive) were identified by HHUS, for a cancer detection rate of 0.4 per 1,000 exams (95% CI, 0.0 to 1.4). One cancer was Stage 1, and one was Stage 2. The recall rate was 2.1 percent (95% CI, 1.7 to 2.5) and the biopsy rate was 1.2 percent (95% CI, 1.0 to 1.6). A cohort study from a breast clinic reported on findings of 22,131 women undergoing breast HHUS after negative mammography, of whom 9,960 had BI-RADS c to d dense breasts.70 The cancer detection rate in this group with dense breasts was 2.2 per 1,000 exams (95% CI, 1.4 to 3.3), somewhat higher than the rate of 1.56 per 1,000 reported for women with BI-RADS a to b breast density. No other findings were reported separately for the subgroup with dense breasts.

Two fair-quality retrospective diagnostic accuracy studies from Asia reported on proximate clinical outcomes from HHUS screening of women with dense breasts who had negative mammography.64, 65 These studies may be potentially relevant to women of Asian descent residing in the U.S., who have greater risk of increased breast density.19-21 An academic medical center in South Korea reported outcomes for 1,507 exams on 1,046 women (mean age 47.5 years) with two years followup but 61.8 percent had a personal history of breast cancer and others were undergoing a diagnostic exam; 446 HHUS exams were for screening of women with heterogeneous or extremely dense breasts without a personal history of breast cancer.65 In this subgroup, 11 breast cancers were detected, for a very high cancer detection rate of 24.7 per 1,000 exams (95% CI, 12.4 to 43.7), but study estimates may be biased by loss to followup, since the exams were selected based on availability of two year followup and 60.5 percent (2,313/3,820 exams) originally identified were initially excluded on this basis. The stage distribution was not clearly reported for the subgroup. The recall rate was 13.7 percent (95% CI, 10.6 to 17.2) with a biopsy rate of 10.9 percent (95% CI, 8.2 to 14.3). A Singapore study of 141 women (mean age 45.1 years) with heterogeneously or extremely dense breasts and negative mammograms reported on a single round of HHUS screening at a general hospital radiology practice.64 Followup was by retrospective review of breast imaging records over 24 months following screening: 35 women (25%) were lost to followup, leaving 106 women for analysis. Two breast cancers (one invasive- Stage 1) were diagnosed for an incremental cancer detection rate of 18.9 per 1,000 women (95% CI, 1.7 to 50.3). No interval cancers were reported. The recall rate was 17 percent, and the biopsy rate was 13.2 percent (95% CI, 7.4 to 21.2).

#### ABUS

Three fair-quality cohort studies from the United States reported proximate outcomes of screening women with ABUS. One study from an academic medical center compared proximate outcomes among women with >50 percent density (Wolf classification) on recent mammography: 4,076 were screened with mammography alone and 3,418 were women screened during a later period with both mammography and ABUS.67 All imaging was double-read by two radiologists who interpreted all mammograms and ABUS exams with consensus over disagreements. One round of screening results was reported, but no description of the followup protocol, loss to followup, or interval cancers was provided. ABUS with mammography identified 12.3 invasive breast cancers per 1,000 exams (95% CI, 8.9 to 16.6) relative to 4.7 invasive breast cancers per 1,000 exams identified in the mammography only group. The recall rate in the ABUS with mammography group was 1.5 percent (95% CI, 1.1 to 2.0); the biopsy rate for additional imaging was not reported. No data were provided on the number of short interval followup exams recommended. Breast cancer stage was reported only for the group undergoing both ABUS and mammography. Forty two breast cancers were diagnosed by ABUS, and all were invasive. Thirty five (83%) were Stage I, five (12.5%) were Stage II and two (5%) were Stage III. The interval cancer rate was not reported, though the authors state that patients were followed prospectively for 1 year. Loss to followup was not reported.

A fair-quality study of test performance characteristics from eight radiology breast screening facilities across the United States reported on a group of 4,419 women (mean age, 53 years) undergoing 6,425 ABUS and mammography exams, of which 4,347 exams (67.7%) were performed on women with BI-RADS c to d breast density.66 Most women underwent concurrent mammography and ABUS, but 468 women alternated mammography with ABUS at six month intervals. Ten percent of participants had a personal history of breast cancer and 30 percent had a family history of breast cancer; 0.1 percent were known BRCA 1/2 mutation carriers. Women with large breasts (>7cm compressed breast thickness) were excluded due to “decreased reliability” of ABUS in this group. In the overall study population, 57 breast cancers were diagnosed, 23 of which were identified by screening mammography, and 23 of which were only identified by ABUS for a cancer detection rate of 3.6 per 1,000 exams (95% CI, 2.3 to 5.4). Eleven were interval cancers that were not identified by either modality. Twenty-two of 23 breast cancers identified solely by ABUS were invasive. The stage distribution of cancers detected by ABUS in the entire group was Stage I: 17 (77.2%), Stage II: 4 (18.1%), Stage III: 1 (4.5%). Of the 23 breast cancers identified by mammography, 17 were invasive. The stage distribution of cancers identified by mammography prior to ABUS was: Stage I: 13 (76.4%), Stage II: 4 (23.5%), Stage III: 1 (5.9%). Recall rates for additional imaging were 8.7 percent (95% CI, 8.0 to 9.4) for ABUS and 4.2 percent for mammography. Biopsy rates were 1.2 percent for ABUS and 0.9 percent for mammography. An important limitation of the study was that the lead author on the study had a majority financial interest in the ABUS technology being studied, and the co-author was also a shareholder.

A fair quality multi-site study reported findings on 15, 318 women with heterogeneous or extremely dense breasts underwent concurrent mammography and ABUS.74 Mean age was 53.3 years; 3.6 percent had a personal history of breast cancer, and 21.7 percent had a first degree relative with breast cancer. One percent were known to have a BRCA1 or BRCA2 mutation. Thirty breast cancers (28 were invasive) were detected by ABUS only for a cancer detection rate of 1.9 per 1000 exams (95% CI, 1.3 to 2.8). The recall rate was 13.5% (95% CI, 12.9 to 14.0 percent), and the biopsy rate was 3.6 percent (95% CI, 3.4 to 4.0). This study also had the important limitation that it was funded by the manufacturer of the ABUS system; six authors, including the lead author, were paid consultants for the manufacturer and three authors were shareholders in the company.

#### MRI

From a good-quality, multi-center U.S. prospective cohort study, we obtained unpublished data on proximate breast cancer outcomes among 334 asymptomatic women with elevated breast cancer risk and heterogeneously or extremely dense breasts in at least one mammographic quadrant (without BRCA 1/2 mutations, personal history of breast cancer, or history of chest irradiation) who underwent a single round of MRI screening.61 Elevated breast cancer risk in this subgroup was attributable mainly to family history of breast cancer. Prior to MRI screening, all women had three rounds of mammographic and breast ultrasound screening with recent negative screening mammography and ultrasound. In these 334 women, breast cancer was diagnosed by MRI in 7, including 6 invasive breast cancers and 1 DCIS (breast cancer detection rate, 21.0 cancers per 1,000 exams (95% CI, 8.5 to 42.7). In the overall sample of 8 invasive cancers detected by MRI (including women outside the dense breast subgroup), all of the invasive cancers with nodal staging were node-negative. In the subgroup with dense breasts, there were no interval breast cancers during a one year post-MRI followup period. Biopsy rates were not reported to us for the subgroup, but in the overall study sample, 7.0 percent of women screened with MRI were recommended for biopsy on account abnormal MRI findings.

Authors of a good-quality German single-center prospective cohort study provided data on a subgroup of 105 women with dense breasts undergoing MRI screening on account of dense breasts.23 Prior to MRI screening, all women had had negative screening mammography and HHUS. The reference standard included biopsy results for positive screens and two-year prospective followup; there was no loss to followup. Among these 105 women, MRI screening detected 2 invasive breast cancers and 1 DCIS, (breast cancer detection rate 28.6 per 1,000 exams [95% CI, 5.9 to 81.2]). Both invasive cancers were Stage I. There were no interval breast cancers during the two-year followup period. Biopsy rates were not reported for the overall study sample or the subgroup.

In the good-quality, multi-center Dutch MRISC prospective cohort study, we abstracted proximate breast cancer outcomes among 1,723 elevated- risk women with BI-RADS c or d breast density without BRCA 1/2 gene mutations who underwent supplemental MRI screening along with regular screening mammography and clinical breast examination.68 Among these women, breast cancer was detected by MRI in 6 women, for a cancer detection rate of 3.5 per 1,000 exams (95% CI, 1.3 to 7.6). Cancer stage was not reported for the dense breast subgroup, but in the overall MRISC study, MRI-detected breast cancers were more likely to be localized than among women with incident breast cancer in the general Dutch population.79 Overall 11.5 percent (95% CI, 10.0 to 13.1) of women with dense breasts required additional investigation or biopsy on the basis of abnormal MRI results.

It is notable that the two of three studies on supplemental MRI screening in women with dense breasts targeted women with elevated lifetime breast cancer risk.61, 68 Thus, the subgroup of women with dense breasts in these studies likely has elevated breast cancer risk based on risk factors other than breast density (e.g., family history of breast cancer). Only one study included a subgroup that received supplemental MRI screening solely on account of increased breast density.23 The incidence and prevalence of breast cancer could be lower in the general population of women with dense breasts than the women represented in these studies.

#### DBT

Three fair-quality observational studies from the United States included data on a subgroup of women with BI-RADS c or d density.75-77 These retrospective descriptive studies compared women who had screening digital mammography with those undergoing digital mammography with concurrent DBT. Some outcomes were reported separately for exams of women with dense breasts. One study compared 4,666 exams of women with dense breasts undergoing digital mammography with DBT to a comparison group of 7,009 exams of women with dense breasts undergoing mammography alone.77 Cancer detection rates were 5.4 per 1,000 exams (95% CI, 3.5 to 7.9) for DBT with mammography and 4.0 per 1,000 exams (95% CI, 2.7 to 5.8) in the comparison group. McCarthy et al compared outcomes of 5,056 exams of women with dense breasts undergoing DBT and mammography with a cancer detection rate of 6.9 per 1000 exams to 3,489 exams of women with dense breasts examined with mammography only with a cancer detection rates of 5.2 per 1,000 exams (95% CI, 3.1 to 8.1).75 Invasive cancer detection rates were reported separately for the subgroup of women with dense breasts in this study: 3.4 per 1,000 exams (95% CI, 1.8 to 6.0) for digital mammography and 4.7 per 1,000 exams (95% CI, 3.0 to 7.0) for digital mammography plus DBT.75 Recall rates were reported in all three studies and were generally lower in women examined with both DBT and mammography. Recall rates were 9.1% (95% CI, 8.4 to 11.0) for digital mammography only compared with 6.9 percent (95% CI, 6.2 to 7.7) with DBT and mammography77; 12.8 percent (95% CI, 11.7 to 14.0) for mammography only compared with 10.8 percent (95% CI, 10.0 to 11.7) for DBT with mammography75; and 16.6 percent (95% CI, 15.0 to 18.2) for mammography only compared with 9.7 percent (95% CI, 8.6 to 11.0) with DBT combined with digital mammography.77 Biopsy rates were not reported separately for the subgroup of women with dense breasts, but biopsy rates for the overall group, when reported, were similar for women examined with or without DBT.75, 77

A fair-quality study from Italy compared the results of digital mammography screening with the results of mammography with DBT in a prospective cohort of 7,294 exams of 7,292 women (median age 58 years); 1,215 exams were done on women with dense breasts.70 All exams were read independently by two radiologists. Each read the digital mammogram first and subsequently interpreted mammogram together with the DBT images. Women were recalled for further evaluation if radiologists recommended recall at either mammography or at DBT. In the subgroup of women with dense breasts, cancer detection rates were 4.1 per 1,000 exams (95% CI, 1.3 to 9.6) based on mammography interpretation and 6.6 (95% C I, 2.9 to 12.9) per 1,000 exams based on mammography plus DBT. Recall rates in the subgroup of women with dense breasts were 7.2 percent (95% CI, 5.8 to 8.8) based on digital mammography and declined to 6.6 percent ((95% CI, 5.3 to 8.1) with review of DBT images. Biopsy rates were not reported separately.

## Key Question 4 What Are the Harms Associated With Being Identified as Having Dense Breasts, Including Psychological and Quality of Life Impacts, and Harms Associated With Supplemental Screening Evaluation, Including Evaluation of False-Positive Results?

### Summary of Results

In 24 states, mammography providers are required by law to notify women if they have dense breasts.37 Evidence on the harms of notification of breast density and the harms of supplemental testing for women with dense breasts was sparse.

A single good-quality RCT from Canada examined the effects of notification to women of mammographic findings of dense breasts (defined as greater than 50 percent of breast volume).80 In this study, 285 women randomized to the intervention group received a report of their breast density as part of the letters summarizing their mammography results, as well as pamphlets on breast cancer risk factors (including density). No supplemental screening was recommended. At 4 weeks, more women in the intervention group had statistically significantly increased knowledge of breast density, more perceived themselves to have an elevated breast cancer risk, and more stated that they were very likely to have a clinical breast exam. These differences did not persist at 6 months. There were no differences in psychological distress, breast cancer worry, or preoccupation with breast cancer at 4 weeks or 6 months.

In addition to detecting more cancers, supplemental screening with HHUS, ABUS, and MRI leads to more recalls and biopsies for false positive results, as summarized in KQ's 2 and 3 (Tables 13-19). In women with negative screening mammography, the positive predictive value of HHUS ranged from 3.0 to 8.3 percent, meaning over 90 percent of positive tests were false positive. In good-quality studies, biopsy rates associated with supplemental screening tests ranged from 5.9 to 6.7 percent (Table 16). For ABUS, the PPV in one study was 4.1 percent, and in two studies of ABUS, recall rates were 1.5 percent and 8.7 percent (Table 17). Positive predictive value for three good-quality studies of breast MRI ranged from 3.0 to 33.3 percent, but women in the MRI screening studies were generally selected for elevated breast cancer risk based on family history apart from increased breast density. In these studies, recall rates ranged from 8.6 to 23.4 percent (Table 18).

DBT led to reduced recall rates for women with dense breasts in four fair-quality studies (Table 19), but when added to digital mammography more than doubles the radiation exposure from each screening exam.28, 29, 31 Technology that allows reconstruction of the 2-D breast images can reduce radiation exposure but is not widely disseminated.31

The evidence on harms of recall, biopsy, and overdiagnosis after mammography screening are summarized in Screening for Breast Cancer: Systematic Review to Update the 2009 U.S. Preventive Services Task Force Recommendation.81 Although we found no studies specifically addressing the harms related to false positives and overdiagnosis for supplemental screening for women with dense breasts, they are likely to be very similar to those noted for mammography, with the exception of harms from increased radiation exposure with DBT and gadolinium contrast used in MRI screening.

We found no specific reports of adverse effects of breast MRI, but it does require the administration of gadolinium contrast. Gadolinium contrast media have been associated with nephrogenic systemic fibrosis in patients with acute kidney injury or chronic kidney disease (CKD) Stage 4 and 5, and gadolinium is considered contraindicated in these patients. Nephrogenic systemic fibrosis is characterized by scleroderma-like tissue changes in the skin, internal organs, eyes, and blood vessels,82 is associated with increased mortality and has no effective treatment.83 The American College of Radiology recommends screening with serum creatinine prior to administration of gadolinium for those with meeting any of the following criteria: age over 60 years, history of hypertension, medication use for diabetes mellitus, known history of kidney disease or surgery.84 The need for additional screening for CKD to reduce potential risk of nephrogenic systemic fibrosis is part of the consideration of potential harms related to breast MRI, particularly for older women and women with hypertension and/or diabetes.

Given the sparse literature on harms on notification of dense breasts, and the mandates for notification in nearly half of all states, additional studies of the behavioral impacts of breast density notification in the United States are needed. Longer term studies are also needed on outcomes of supplemental screening, including recall and biopsy rates of recurrent screening, overdiagnosis, and frequency of harms associated with gadolinium contrast administration for breast MRI.

### Study Details

In a good-quality study of possible psychological harms and other effects of breast density notification, the screening mammography program of British Columbia conducted an RCT of notification of breast density findings at the time of mailed notification of screening mammography results (Table 21).80 Women were recruited at the time of appointment scheduling for mammography screening; women with suspicious mammography findings or breast density exceeding 50 percent at the previous exam were excluded from the study. The final sample included 618 women, 333 in the control group and 285 in the intervention group, and provided >90 percent power with alpha<.05 in the a priori sample size calculation. The groups were similar on baseline measures. Women in the intervention group and their primary physicians received information about their breast density with mailed results of their mammogram, along with an educational pamphlet. Supplemental screening was not recommended mentioned in the pamphlet, as it was not routinely available to women in the screening program. Women in the control group and their primary physicians received the usual results letter. Prior to the screening mammogram and at 4 weeks and 6 months following screening, women in both groups were interviewed by telephone about anxiety, depression, breast cancer worry, self-estimates of breast cancer risk, and knowledge of breast density as a risk factor. Women were also queried about whether they had a recent clinical breast exam or had plans to have one, dietary changes, and their intention to return for mammography at the recommended time interval.

Table 21 Harms Associated With Breast Density Notification: Study and Population Characteristics

Author, Year USPSTF Quality | Country | Design | Study Period | Intervention | N Analyzed | Mean age, y | % Dense Breasts | Population Characteristics
Bottorff, 2007^80^ Good | Canada | RCT | 2/2002 – 8/2003 | IG: letter notification of mammograms results with info on breast density and pamphlet on breast cancer risk factors CG: Usual letter notification of mammography results | Total: 618 IG: 285 CG: 333 | IG: 66.1 CG: 65.9 | IG: 100% CG: 100% | Screening population 1^st^ degree relative with BC: IG: 15.7% CG: 18.3% Gail Lifetime Risk: IG: 8.7% CG: 9.1%

Abbreviations: BC=breast cancer; CG=control group; IG=intervention group; RCT=randomized, controlled trial.

Table 22 Harms Associated With Breast Density Notification: Knowledge, Perceived Risk, and Breast Cancer Worry

Study, Year USPSTF Quality | Mean Followup (weeks) | N Analyzed | Treatment Group | Knowledge of breast density as a risk factor | Higher Perceived Lifetime Risk^*^ | Lower Perceived Lifetime Risk Relative to Other Women^†^ | Psychological Distress: Worry Often About Breast Cancer^‡^
Bottorff, 2007^80^ Good | 4 | 265 | IG | 85.3% | 5.5% | 10.5%^§^ | 23.0%
Bottorff, 2007^80^ Good | 4 | 314 | CG | 66.4% | 3.7% | 15.5%^§^ | 20.4%
Bottorff, 2007^80^ Good | 24 | 270 | IG | 89.2% | 4.1% | 10.6% | 19.3%
Bottorff, 2007^80^ Good | 24 | 314 | CG | 63.8% | 2.6% | 16.7% | 20.9%

* Women who rated their own lifetime risk of breast cancer as “high.”

† Women who rated their perceived lifetime risk as “a lot lower” relative to other women.

‡ Women who responded with “often” when asked how often they worry about getting breast cancer.

§ Statistically significant difference at p<0.05.

Abbreviations: CG=control group; IG=intervention group.

Survey completions rates at 4 weeks and 6 months were 93.7 percent and 94.8 percent with no differential loss to followup. No differences were found between groups in psychological measures (the primary study outcome) at 4 weeks or 6 months (Table 22). At 4 weeks, fewer women in the intervention group (10.5%) compared with the control group (15.5%) perceived themselves to be at “a lot lower risk” for breast cancer relative to other women. This difference was statistically significant at 4 weeks, but not at 6 months. At 4 weeks, 24.8 percent of women in the intervention group correctly described breast density, compared with 7.5 percent in the control group (p<.001), and more women in the intervention group knew that it was a risk factor for breast cancer (85.3% vs. 66.4%; p<.001). Twenty-three percent of the intervention group compared with 15.1 percent of the control group indicated intention to have a clinical breast exam at the 4 week interview (p=.03), but at 6 months this difference was not sustained.