# Methods

## Scope and Purpose

This systematic review focused on the accuracy and reliability of breast density categorization, and on supplemental imaging tests for screening for women with dense breasts and negative mammography. The review complements the systematic review on breast cancer screening in the general population. This review summarized the current evidence regarding the reliability of density classification, the test performance characteristics of supplemental tests after a negative screening mammogram, the evidence on clinical outcomes of supplemental screening in women found to have dense breasts, and the harms associated with identification of dense breasts and supplemental screening in this population.

## Key Questions and Analytic Framework

Using the USPSTF's methods47 (detailed in Appendix A), we developed an analytic framework (Figure 1) and four key questions (KQs):

1. What is the accuracy and reproducibility of BI-RADS determination of breast density?
2. What are the test performance characteristics of newer technologies for breast cancer screening when used as supplemental tests after a negative screening mammogram exam in women found to have dense breasts and how do these performance characteristics differ by age and risk factors?
3. When performed after a negative screening mammogram in women found to have dense breasts, what is the effectiveness of supplemental screening with breast ultrasound, MRI, or breast tomosynthesis on proximate clinical outcomes, including cancer detection rates, DCIS detection rates, stage at diagnosis, recall rates, biopsy rates, and interval cancer rates?
4. What are the harms associated with being identified as having dense breasts, including psychological and quality of life impacts and harms associated with supplemental screening evaluation, including evaluation of false positive results?

Figure 1 Analytic Framework

Key Questions:

1. What is the accuracy and reproducibility of BI-RADS determination of breast density?
2. What are the test performance characteristics of newer technologies for breast cancer screening when used as supplemental tests after a negative screening mammography exam in women found to have dense breasts and how do these performance characteristics differ by age and risk factors?
3. When performed after a negative screening mammogram in women found to have dense breasts, what is the effectiveness of supplemental screening with breast ultrasound, MRI, or breast tomosynthesis on proximate clinical outcomes, including cancer detection rates, DCIS detection rates, stage at diagnosis, recall rates, biopsy rates, and interval cancer rates?
4. What are the harms associated with being identified as having dense breasts, including, psychological and quality of life impacts and harms associated with supplemental screening evaluation, including evaluation of false positive results?

Abbreviations: BI-RADS=Breast Imaging-Reporting and Data System; DCIS=ductal carcinoma in situ.

Figure 1 is the analytic framework that depicts the four Key Questions described in the Methods section of the report. In general, the figure illustrates how screening for breast cancer in asymptomatic women age 40 years and older may identify women with dense breasts, and these women may need to undergo additional supplemental screening to identify breast cancer, and how supplemental screening may lead to improved outcomes or potential harms. In addition, it examines the accuracy of breast density determinations by radiologists, as well as the harms associated with being identified as having dense breasts.

## Data Sources and Searches

The literature search for this systematic review included searches of MEDLINE, PubMed, Embase, and the Cochrane library from January 2000 through July 2015. We worked with a medical librarian to develop our search strategy (Appendix A). The literature search results were managed using version X7.1 of EndNote ® (Thomason Reuters, New York, NY).

To ensure the comprehensiveness of our retrieval strategy, we reviewed the reference lists of included studies and relevant systematic reviews to identify relevant articles that were published before the timeframe or not identified in our literature searches. We also supplemented our database searches with suggestions from experts, and searched the grey literature for relevant reports related to supplemental screening of women with dense breasts. We reviewed their references of relevant articles and reports, and searched Clinicaltrials.gov to identify relevant ongoing trials (Appendix B).

## Study Selection

Two reviewers independently reviewed the titles and abstracts of identified articles to determine if studies met the inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated the full-text article(s) of potentially included studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion. Excluded full-text articles and reasons for exclusion are listed in Appendix C.

We developed an a priori set of criteria for inclusion and exclusion criteria of studies based on our understanding of the literature (Appendix A Table 1). For KQ 1 examining the intra-rater concordance and inter-rater reliability of BI-RADS density determination, we considered RCTs, prospective and retrospective cohort studies, case-control studies, cross-sectional studies, and test sets involving multiple blinded readings of digital or film mammography by at least three readers. For KQ 2 examining the test performance characteristics of supplemental screening for dense breasts with MRI, hand-held ultrasound, whole breast ultrasound, and DBT, we considered RCTs, prospective and retrospective cohort studies, and diagnostic accuracy studies. We required that the studies reported on a screening practice with two or more radiologists and that a reference standard of a minimum of 12 months clinical followup be applied to all participants with a negative screen. For KQ 3, examining the proximate clinical outcomes of supplemental breast cancer screening, we considered RCTs, prospective and retrospective cohort studies (including cohort studies reporting on cancer detection rates, stage distribution of detected cancers, recall rates and biopsy rates) and meta-analyses. We required studies to report outcomes from two or more radiologists. Study populations and outcomes reported had to be stratified by breast density in the screened group if women with all breast densities were included, so that rates for women with dense breasts could be calculated. KQ 4 examined the harms of being identified as having dense breasts; we considered RCTs, prospective and retrospective cohort studies, case-control studies, cross-sectional studies, meta-analyses, and modeling studies.

## Quality Assessment and Data Extraction

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF48 and supplemented with the National Institute for Health and Clinical Excellence methodology checklists49 and the QAREL tool50 for assessing diagnostic reliability. Disagreements in quality were resolved by discussion. Each study was given a final quality rating of good, fair, or poor.

Good-quality diagnostic reliability studies used a representative sample of subjects and raters, had blinded assessment of the reference standard (where applicable) and also blinded raters to non-clinical cues and to others ratings, used a varied examination order, an appropriate time interval between repeated measures, appropriate approaches to application and interpretation of the test, and used appropriate statistical measures of agreement. Diagnostic reliability studies were downgraded to fair if they were unable to meet the majority of good-quality criteria. Poor-quality observational studies had multiple threats to internal validity and were excluded from this review (Appendix C).

Good-quality diagnostic accuracy studies applied credible reference standards interpreted independently of the screening test to both positive and negative test results (typically tissue sampling for positive results and minimum 12 month clinical followup for negative results, had low rates of loss to followup, and included at least 100 patients undergoing breast cancer screening. Studies were rated as poor if they did not apply a reference standard to the entire study sample including those with negative tests, had biased ascertainment of the reference standard, a very small sample size or limited the sample to very high risk patients, or had other threats to internal validity. Poor studies were excluded from the review (Appendix C).

Good-quality RCTs had adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar groups at baseline (i.e., small differences between groups in baseline demographics and characteristics), low attrition (≥90% of participants had followup data, with <10 percentage-point differences in loss to followup between groups), and used conservative data substitution methods if missing data were inferred. Poor-quality studies were excluded from the review (Appendix C).

Good-quality observational studies had adequate, unbiased ascertainment of exposed and unexposed groups. These studies addressed a population without the outcome of interest at the beginning of the study, and they had reliable outcome measures, blinded assessment, low attrition, adjustment for potential confounders, and no other important threats to internal validity. Observational studies were downgraded to fair if they were unable to meet the majority of good-quality criteria. Poor-quality observational studies had multiple threats to internal validity and were excluded from this review. Observational studies reviewed for this report often reported on diagnostic test outcomes, so criteria for diagnostic accuracy studies were applied when relevant (Appendix C).

One reviewer extracted data from all included studies rated as fair- or good-quality into a standard evidence table. A second reviewer checked the data for accuracy. For all KQs, elements abstracted included population characteristics (e.g., baseline demographics, breast density, family or personal history of breast cancer), study design (e.g., inclusion/exclusion criteria, followup, screening rounds), and screening test characteristics (e.g., reference standard, number of readers, radiological experience). For KQ 1, we abstracted details of inter- and intra-rater reliability and variability. For KQ 2, we abstracted test performance characteristics, including sensitivity, specificity, negative predictive value, and positive predictive value. For KQ 3, we abstracted proximate health outcomes, including breast cancer detection rates, invasive breast cancer detection rates, recall rates, and biopsy rates. Recall rates were abstracted as including recall for both true and false positive results. Recall rates were not always specified as recall for further imaging separately from biopsy, but biopsy rates were recorded separately when available. For KQ 4, we considered studies on adverse events associated with screening tests, and psychological harms of breast density notification to women.

## Data Synthesis and Analysis

We created summary evidence tables to synthesize data separately for each KQ. The tables were the basis of our qualitative synthesis. In the context of study quality, we examined the range of results and looked for possible associations between study results and population or modality characteristics. Sensitivity, specificity, positive and negative predictive value, cancer detection rates, recall rates, and biopsy rates were calculated for subgroups of women with dense breasts when required. 95% confidence intervals were calculated with the exact method51, 52 for each study estimate of sensitivity, specificity, cancer detection rates, and biopsy rates. In good-quality studies, when reported outcomes data were not stratified for women with dense breasts, we requested from authors study data stratified by breast density to enable inclusion of these studies in our review.

## Expert Review and Public Comment

A draft version of this report was peer-reviewed by five invited content experts as well as federal partners from the National Cancer Institute and the U.S. Department of Veterans Affairs (VA). Comments received during this process were presented to the USPSTF during its deliberation of the evidence and subsequently addressed, as summarized below, in this version of the report. Additionally, a full draft report was posted for public comment on the USPSTF's website from April 20 to May 18, 2015. All comments were reviewed and considered. Most comments related to the report addressed 6 major areas:

1. Clarification on development of the BIRADS density system and other methods of assessing breast density
  Text on the development of the BIRADS density classification system was revised and other approaches to breast density assessment were mentioned in the Introduction.
2. Clarification about the relationship of breast density to breast cancer mortality risk
  A large study finding no difference in breast cancer mortality among women with dense breasts compared to others was discussed and referenced in the report.16
3. Discussion of the risk of overdiagnosis arising from supplemental screening
  Further discussion of the risk of overdiagnosis from supplemental screening was added. Our emphasis is on the need for longer term, comparative studies, which will help to quantify this risk.
4. Clarification to the effect of DBT on the recall rate
  The report was revised to clarify that existing evidence suggests that DBT reduces the recall rate.
5. Inclusion of additional studies of DBT
  All studies of DBT suggested by reviewers and in the public comment section were reviewed. None of these studies report stratified results for the study population of women with dense breasts, rather they report on outcomes of DBT in a general screening population of women. These studies were included in a separate brief report reviewing studies of the test performance characteristics of DBT in the general screening population.53 Two studies mentioned in the public comments were added to this report.
6. Inclusion of data on the risk of radiation exposure from mammography for women with dense breasts
  A separate analysis was conducted to estimate the risk of radiation-induced breast cancer arising from mammography.54

## USPSTF Involvement

This research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. The authors worked with liaisons from the USPSTF at key points throughout the review process to develop and refine the scope, analytic framework, and key questions; to resolve issues around the review process; and to finalize the evidence synthesis. AHRQ had no role in study selection, quality assessment or synthesis. AHRQ staff provided project oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review of content by outside experts.