# Introduction

## Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report, along with the corresponding report on breast cancer screening in the general population, to update its 2009 recommendation on breast cancer screening.

## Background

### Condition Definition

The appearance of the breast on mammography varies due to differences in breast tissue composition. Dense breasts are identified based on mammographic appearance; compared to non-dense breasts, dense breasts have more fibroglandular tissue (resulting in white areas on mammography) and less fatty tissue (which appears as dark areas on mammography). Wolfe first described an association between mammographic density and breast cancer risk in 1976.^1^

Several systems of breast density classification have been developed since Wolfe described a categorization of the degree of breast density, defining four groups based on qualitative assessment of visual appearance. To date, computer assisted assessment of breast density has been used primarily as a research tool.2 In the United States, breast density is generally defined and classified by visual assessment according to the American College of Radiology's (ACR) Breast Imaging-Reporting and Data System (BI-RADS) four-category scale.

Instituted by the American College of Radiology in 1992, BI-RADS provides a lexicon of breast imaging descriptors, a structure for reporting assessment categories and management recommendations, and a framework for data collection and auditing.3 The original BI-RADS document included only a summary of breast density and a statement describing general breast tissue type to address emerging evidence that increased breast density was associated with decreased mammographic sensitivity.3 The first edition of BI-RADS, published in 1992 and updated in 1998, introduced the four category classification of breast density (ranging from “almost entirely fat” [category 1] to “extremely dense” [category 4]) to improve and standardize communication of predicted mammographic performance and breast cancer risk.3, 4 In 2003, the fourth edition of BI-RADS added quartile ranges of percentage dense tissue to each of the four density categories (i.e., 0-25% glandular tissue; approximately 26-50% glandular; approximately 51-75% glandular; >75% glandular tissue). The purpose was to align more closely with research on percent density assessments and to move towards distributing population breast density assessments more evenly across categories.5 Today, the fifth and current edition of the BI-RADS Atlas (2013) reverts to qualitative breast density reporting categories and emphasizes the importance of dense tissue masking some non-calcified cancers as being clinically important (Table 1).5 Breast density is reported as an overall assessment and not separately for each breast.

Table 1 BI-RADS Breast Density Descriptions

2013 BI-RADS Atlas | 2003 BI-RADS Atlas | 1998 BI-RADS Atlas
a = The breasts are almost entirely fatty | 1 = The breast is almost entirely fat (<25% glandular) | 1 = The breast is almost entirely fat
b = There are scattered areas of fibroglandular density | 2 = There are scattered fibroglandular densities (approximately 25% - 50% glandular) | 2 = There are scattered fibroglandular densities
c = The breasts are heterogeneously dense, which may obscure small masses | 3 = The breast tissue is heterogeneously dense, which could obscure detection of small masse (approximately 51% - 75% glandular) | 3 = The breast tissue is heterogeneously dense. This may lower the sensitivity of mammography
d = The breasts are extremely dense, which lowers the sensitivity of mammography | 4 = The breast tissue is extremely dense. This may lower the sensitivity of mammography (>75% glandular) | 4 = The breast tissue is extremely, dense, which could obscure a lesion on mammography

Abbreviation: BI-RADS=Breast Imaging-Reporting and Data System.

The 2013 BI-RADS density terminology classifies levels of breast density and is used to standardize reporting of visual assessment of mammograms.5, 6 The categories employ the letters “a” to “d”, in place of numbers (to avoid confusion with the BI-RADS assessment scores classifying abnormalities) and categorize breast density in the following way:5

a. The breasts are almost entirely fatty
b. There are scattered areas of fibroglandular density
c. The breasts are heterogeneously dense, which may obscure small masses
d. The breasts are extremely dense, which lowers the sensitivity of mammography

Although the descriptions and naming of the categories have changed slightly between versions, the number of categories has been constant and overall distinctions between them have not shifted substantially across versions. All of the research included in this systematic review began before the transition to BI-RADS 2013 density terminology and hence, dense breasts were generally categorized as BI-RADS density 3 and 4; in the report, these are converted to c and d to match the current system.

### Prevalence and Burden of Condition

Based on an analysis of over 3.8 million screening mammograms collected by the Breast Cancer Screening Consortium (BCSC)5 and using both pre- and post-2003 BI-RADS density guidelines, radiologist-assigned distribution of density was designated as:

- 10 percent of patients receiving mammograms are classified as having fatty breasts
- 40 percent as having scattered areas of density
- 40 percent as having heterogeneous density
- 10 percent as having extremely dense breasts

A subsequent analysis of over 1.5 million mammograms in the United States between 2007 and 2010 collected by the BCSC found that 43.3 percent of women aged 40 to 74 years had heterogeneous or extremely dense breasts (BI-RADS categories c or d). In the U.S. population, an estimated 27.6 million women fall into these categories.7

High breast density has two distinct effects. Abnormal areas on mammograms are more difficult to see in areas with dense breast tissue, reducing the sensitivity and specificity of mammography. Abnormalities on mammograms are more difficult to see in areas with dense breast tissue: sensitivity decreased from 81.2 percent to 63.3 percent and specificity decreased from 93.5 percent to 88.7 percent in women aged 40 to 49 years; sensitivity decreased from 90.0 percent to 57.1 percent and specificity from 95.0 percent to 93.8 percent in women aged 70 to 74 years.8 In addition, increased breast density is a significant predictor of increased breast cancer risk,9 with some studies estimating a four- to six-fold increase in lifetime breast cancer risk among women with extremely dense breasts relative to women with entirely fatty breasts.10-13 Comparisons of relative risk between the lowest and highest density categories may be misleading as these categories include only approximately 20 percent of women; more clinically relevant comparisons of relative risk between the two ‘dense’ categories and average breast density estimate increases in lifetime breast cancer risk of only 1.2- and 2.1-fold.14 A recent meta-analysis of 13 case-control studies where density was measured on a computerized estimate of absolute dense area found a summary adjusted odds ratio for breast cancer risk of 1.37 (95% CI, 1.29 to 1.47) per standard deviation increase in absolute dense area on mammography in pre-menopausal women. The odds ratio was adjusted for age, body mass index (BMI), and parity. The summary adjusted odds ratio for the post-menopausal women was similar (OR 1.38; 95% CI, 1.31 to 1.44).15 Increased breast density is not, however, associated with higher breast cancer mortality among women with dense breasts diagnosed with breast cancer.16

### Risk Factors for Dense Breasts

Breast density declines with age and body mass index (BMI), and increases with HRT use. A BCSC study of 764,507 women aged 40 years and older undergoing 1,518,599 mammograms evaluated the relationship between age, BMI and breast density and projected estimates for the population of women potentially eligible for breast cancer screening in the United States. Among the estimated 27.6 million women with dense breasts (BI-RADS c or d) aged 40 to 74 years, nearly 45 percent were between the ages of 40 and 49 years. In the BCSC population, the relative risk of breast cancer for women with dense breasts (BI-RADS c or d) compared to those without dense breasts (BI-RADS a or b) was 1.83 (unpublished data). Twenty five percent of obese women (BMI ≥30) had heterogeneous or extremely dense breasts, compared to 40 percent of overweight women (BMI 25.0 to 29.9) and 58 percent of women with a normal BMI (BMI 18.5 to 24.9).7 HRT use is associated with higher breast density.17 In a separate large study, women on HRT with low/normal BMI and extremely dense breasts were shown to have the highest risk of breast cancer (OR 1.49; 95% CI, 1.21 to 1.83) relative to women not on HRT.18

Few differences in breast density by race/ethnicity have emerged, but evidence is limited. Two studies in the United States have found higher average breast density in Asian women. A study using BCSC data with over one million women found the proportion of Asian women with extremely dense breasts was highest across all age groups.19 A study of over 15,000 women attending breast cancer screening at Massachusetts General Hospital found that breast density on average was higher in Asian women, after adjusting for age and BMI.20 In contrast, a study from the UK of 5,277 mammograms taken from 645 women found that after adjustment for age and BMI, South Asian women had 3.8 percent (95% CI, 1.1 to 6.3) lower average breast density.21 Of note, Asian women in the United States have lower than average incidence of breast cancer.22

## Current Clinical Practice in the United States

### Screening Strategies

Because higher mammographic breast density reduces the sensitivity and specificity of breast cancer screening,8 and increased breast density is also associated with a higher risk of breast cancer,9-13 the use of supplemental breast cancer screening with additional screening modalities has been proposed as a method for better identification of breast cancers.14 The four most common supplemental screening modalities to mammography examined in the literature and implemented in clinical practice are hand-held breast ultrasound, automated whole breast ultrasound, breast MRI, and digital breast tomosynthesis.

Hand-held breast ultrasound (HHUS) is the systematic application of an ultrasound probe over each breast by a radiologist or breast imaging technologist. It is widely available and does not involve exposure to radiation. Automated whole breast ultrasonography (ABUS) involves placement of an ultrasound transducer on the breast by a technologist. The automated probe then moves over the breast in a standard fashion until the breast is scanned, storing 3,000 to 5,000 images for later review by a radiologist. Several systems are FDA approved and their use is becoming more common, but the technology is not widely available.

Breast magnetic resonance imaging (MRI) creates detailed MR images of the breasts. After the injection of IV gadolinium, breast MRI requires scanning of the breasts while lying still inside an MRI scanner. A typical breast MRI lasts 30 to 60 minutes and generates several hundred images.23 Breast MRI has been recommended for annual supplemental screening of women with high (greater than 20%) estimated lifetime risk of breast cancer by the American Cancer Society, the American College of Radiology, and the National Comprehensive Cancer Network.24-26

Digital breast tomosynthesis (DBT) uses a computer algorithm to reconstruct multiple low-dose digital images of the breast into thin “slices” spanning the entire breast. These images can be displayed individually or in cine mode. Use of DBT is expanding as concurrent supplemental screening with mammography. In 2013, the FDA approved the use of synthetic 2-D images to take place of the standard 2-D digital mammogram; although it is currently not known how often synthetic views are used. The use of DBT in addition to standard mammography more than doubles the total radiation exposure. 27-30 Use of newer synthetic 2-D image reconstruction to replace digital mammography eliminates the additional radiation of a digital mammogram, so that the radiation dose is due only the DBT exam.31 Several systems for synthetic 2-D images have been FDA approved, based on studies showing similar performance of synthetic 2-D images with full-field digital mammography32, 33 but these systems are not yet in widespread use.

### Clinical Guidelines

Currently, there are no clinical guidelines explicitly recommending the use of supplemental breast cancer screening in women with dense breasts. The American College of Radiology (ACR)/Society of Breast Imaging26 recommends “considering” supplemental HHUS for women with dense breasts, but notes the concerns about HHUS performance and resource limitations given the large number of women who would be potential candidates for screening. The National Comprehensive Cancer Network (NCCN)34 cites insufficient evidence to recommend its use in women with dense breasts and no other risk factors. The American Cancer Society (ACS)35 and NCCN both cite insufficient evidence to recommend for or against MRI screening as an adjunct to mammography in women with dense breasts. NCCN also cites insufficient evidence to recommend the use of DBT. The American College of Obstetricians and Gynecologists (ACOG) does not recommend the use of any supplemental screening tests in asymptomatic women with dense breasts and no other risk factors.36

### Breast Density Legislation

Legislation in many states requires that providers notify patients regarding breast density, and in some cases, requires insurance coverage of subsequent supplemental screening. Legislation is currently pending in additional states and at the federal level. As of July 2015, twenty-four states, encompassing more than half the population of the United States, have enacted legislation requiring breast density information be included on each patient's mammography results report; an additional six states have introduced similar legislation and another six states are drafting legislation (Table 2).37 Most legislation defines dense breasts are those being categorized as “heterogeneously” or “extremely dense” according to BI-RADS, while other state legislation employ more vague definitions, such as “consistent with current medical evidence”38 or lack a definition altogether. Of the twenty-four states mandating notification, six require that all mammography reports include information about breast density and the patient's BI-RADS density classification, regardless of whether the patient has dense breasts. 37 Of the twenty-four states mandating notification, nineteen states' legislation specifies language that the healthcare provider must use, and usually includes information such as confirmation of dense breast tissue; BI-RADS density classification and explanation; impact of density on mammography-detected breast cancer; suggestions for further supplemental screening. Three states – Illinois,39 Connecticut,40 and New Jersey41 – have enacted legislation mandating that all insurers cover medical examinations and tests for women with dense breasts and Indiana42 mandates such coverage for women covered by state employee health insurance. At the federal level, legislation has been introduced in 2014^43^ and 2015^44^ that would require breast density notification in all mammography reports.

Table 2 Breast Density Legislation in the United States

Status of Legislation^*^ | Legislative Details | States
Pending Legislation | Drafting legislation mandating breast density notification | Florida, Maine, Illinois, Colorado, Vermont, Mississippi
Pending Legislation | Introduced legislation mandating breast density notification^†^ | Washington, Iowa, Indiana, Kentucky, South Carolina, Georgia
Enacted Legislation | Mandates patient notification about breast density | California, Arizona, Oregon, Nevada, Massachusetts, Minnesota, Texas, Alabama, Missouri, Tennessee, North Carolina, Virginia, Maryland, New Jersey, Pennsylvania, New York, Connecticut, Rhode Island, Hawaii, Michigan, Ohio, Louisiana, Delaware, North Dakota
Enacted Legislation | Requires specific language for patient notification | California, Arizona, Texas, Alabama, Missouri, Tennessee, North Carolina, Virginia, Maryland, New Jersey, Pennsylvania, New York, Connecticut, Rhode Island, Hawaii, Ohio, Michigan, Louisiana, Massachusetts
Enacted Legislation | Requires that [underlined: all] mammography reports provide information about breast density and the patient's current breast density level | Nevada, North Carolina, Maryland, Pennsylvania, Connecticut, Louisiana
Enacted Legislation | Requires that insurers cover appropriate medical examinations and tests for women with dense breasts | Illinois, Connecticut, New Jersey, Indiana

Source: D.E.N.S.E® State Efforts.

* As of September 2015.

† During the 2015 legislative season.

## Previous USPSTF Recommendation

The 2009 USPSTF recommendation statement on screening for breast cancer focused on the general population, and not specifically on screening women with dense breasts and a negative mammogram.45 The recommendation acknowledged that digital mammography had increased sensitivity (compared with film mammography) for women with dense breasts. It called for future randomized trials comparing the effectiveness of digital versus film mammography for women with dense breasts. Such trials have not been conducted and digital mammography is presently used for over 95 percent of mammograms in the United States.46