# Excluded Studies

Exclusion Code
E1. Population; a. Other definition of dense breasts
E2. Setting
E3. Intervention or Exposure; a. Not an included modality; b. Diagnostic or surveillance use; c. Did not utilize BI-RADS assessment and compare to other approaches
E4. Study design; a. Inadequate number of readers
E5. No relevant outcomes
E6. Study quality
E7. No original data to include; publication or dataset with longer followup, more complete data, or same data already included in review
E8. No reference standard utilized
E9. Precedes search period

1 Abdolell M, Tsuruda K, Schaller G, Caines J. Statistical evaluation of a fully automated mammographic breast density algorithm. Comput Math Methods Med. 2013;2013:651091. KQ3E5. [pmid: 23737861].
2 Bakic PR, Carton AK, Kontos D, Zhang C, Troxel AB, Maidment AD. Breast percent density: estimation on digital mammograms and central tomosynthesis projections. Radiology. 2009;252(1):40-9. KQ1E3c. [pmid: 19420321].
3 Benndorf M, Baltzer PA, Vag T, Gajda M, Runnebaum IB, Kaiser WA. Breast MRI as an adjunct to mammography: Does it really suffer from low specificity? A retrospective analysis stratified by mammographic BI-RADS classes. Acta Radiol. 2010;51(7):715-21. KQ2E3b. [pmid: 20707656].
4 Benson SR, Blue J, Judd K, Harman JE. Ultrasound is now better than mammography for the detection of invasive breast cancer. Am J Surg. 2004;188(4):381-5. KQ3E1. [pmid: 15474430].
5 Berg WA. Supplemental screening sonography in dense breasts. Radiol Clin North Am. 2004;42(5):845-51. vi. KQ3E4. [pmid: 15337420].
6 Berg WA, Blume JD, Cormack JB, Mendelson EB, Lehrer D, Bohm-Velez M, et al. Combined screening with ultrasound and mammography vs mammography alone in women at elevated risk of breast cancer. JAMA - Journal of the American Medical Association. 2008;299(18):2151-63. KQ2E7,KQ3E7. [pmid: 18477782].
7 Berg WA, Campassi C, Langenberg P, Sexton MJ. Breast Imaging Reporting and Data System: inter- and intraobserver variability in feature analysis and final assessment. AJR American Journal of Roentgenology. 2000;174(6):1769-77. KQ1E5. [pmid: 10845521].
8 Blane CE, Fitzgerald JT, Gruppen LD, Oh MS, Helvie MA, Andersson I. Decreasing rate of fatty involution at screening mammography. Acad Radiol. 2002;9(8):895-8. KQ3E5. [pmid: 12186437].
9 Boudreau DM, Rutter CM, Buist DS. The influence of statin use on breast density. Cancer Epidemiol Biomarkers Prev. 2006;15(5):1026-9. KQ3E5. [pmid: 16702387].
10 Brem RF, Hoffmeister JW, Rapelyea JA, Zisman G, Mohtashemi K, Jindal G, et al. Impact of breast density on computer-aided detection for breast cancer. American Journal of Roentgenology. 2005;184(2):439-44. KQ2E3a, KQ3E3a. [pmid: 15671360].
11 Buchberger W, Niehoff A, Obrist P, DeKoekkoek-Doll P, Dunser M. Clinically and mammographically occult breast lesions: detection and classification with high-resolution sonography. Semin Ultrasound CT MR. 2000;21(4):325-36. KQ2E1, KQ3E1. [pmid: 11014255].
12 Chae EY, Kim HH, Cha JH, Shin HJ, Kim H. Evaluation of screening whole-breast sonography as a supplemental tool in conjunction with mammography in women with dense breasts. J Ultrasound Med. 2013;32(9):1573-8. KQ2E3, KQ3E3. [pmid: 23980217].
13 Chang RF, Chang-Chien KC, Takada E, Suri JS, Moon WK, Wu JH, et al. Three comparative approaches for breast density estimation in digital and screen film mammograms. Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2006;1:4853-6. KQ1E3c. [pmid: 17945860].
14 Ciatto S, Bernardi D, Calabrese M, Durando M, Gentilini MA, Mariscotti G, et al. A first evaluation of breast radiological density assessment by QUANTRA software as compared to visual classification. Breast. 2012;21(4):503-6. KQ1E5. [pmid: 22285387].
15 Ciatto S, Houssami N, Apruzzese A, Bassetti E, Brancato B, Carozzi F, et al. Categorizing breast mammographic density: intra- and interobserver reproducibility of BI-RADS density categories. Breast. 2005;14(4):269-75. KQ1E1. [pmid: 16085233].
16 Cohen SL, Margolies LR, Schwager SJ, Zuckerman S, Patel N, Szabo J, et al. Early discussion of breast density and supplemental breast cancer screening: is it possible?. Breast Journal. 2014;20(3):229-34. KQ4E5. [pmid: 24689788].
17 Corsetti V, Ferrari A, Ghirardi M, Bergonzini R, Bellarosa S, Angelini O, et al. Role of ultrasonography in detecting mammographically occult breast carcinoma in women with dense breasts. Radiologia Medica. 2006;111(3):440-8. KQ3E7. [pmid: 16683089].
18 Corsetti V, Houssami N, Ferrari A, Ghirardi M, Bellarosa S, Angelini O, et al. Breast screening with ultrasound in women with mammography-negative dense breasts: evidence on incremental cancer detection and false positives, and associated cost. (Structured abstract). Eur J Cancer. 2008;44(4):539-44. KQ3E7. [pmid: 18267357].
19 Crystal P, Strano SD, Shcharynski S, Koretz MJ. Using sonography to screen women with mammographically dense breasts. AJR Am J Roentgenol. 2003;181(1):177-82. KQ2E1a. [pmid: 12818853].
20 De Felice C, Savelli S, Angeletti M, Ballesio L, Manganaro L, Meggiorini ML, et al. Diagnostic utility of combined ultrasonography and mammography in the evaluation of women with mammographically dense breasts. J Ultrasound. 2007;10(3):143-51. KQ2E4a. [pmid: 23396266].
21 de Gelder R, van As E, Tilanus-Linthorst MM, Bartels CC, Boer R, Draisma G, et al. Breast cancer screening: evidence for false reassurance?. Int J Cancer. 2008;123(3):680-6. KQ3E3b. [pmid: 18484587].
22 Del Carmen MG, Hughes KS, Halpern E, Rafferty E, Kopans D, Parisky YR, et al. Racial differences in mammographic breast density. Cancer. 2003;98(3):590-6. KQ3E5. [pmid: 12879477].
23 DeMartini WB, Liu F, Peacock S, Eby PR, Gutierrez RL, Lehman CD. Background parenchymal enhancement on breast MRI: impact on diagnostic performance. AJR American Journal of Roentgenology. 2012;198(4):W373-80. KQ2E1, KQ3E1. [pmid: 22451576].
24 Ding J, Warren R, Warsi I, Day N, Thompson D, Brady M, et al. Evaluating the effectiveness of using standard mammogram form to predict breast cancer risk: case-control study. Cancer Epidemiol Biomarkers Prev. 2008;17(5):1074-81. KQ3E5. [pmid: 18483328].
25 Drukker K, Horsch KJ, Pesce LL, Giger ML. Interreader scoring variability in an observer study using dual-modality imaging for breast cancer detection in women with dense breasts. Acad Radiol. 2013;20(7):847-53. KQ3E3. [pmid: 23601952].
26 Elmore JG, Miglioretti DL, Reisch LM, Barton MB, Kreuter W, Christiansen CL, et al. Screening mammograms by community radiologists: variability in false-positive rates. J Natl Cancer Inst. 2002;94(18):1373-80. KQ3E5. [pmid: 12237283].
27 Fowler EE, Sellers TA, Lu B, Heine JJ. Breast Imaging Reporting and Data System (BI-RADS) breast composition descriptors: Automated measurement development for full field digital mammography. Med Phys. 2013;40(11). KQ1E3c. [pmid: 24320473].
28 Gao J, Warren R, Warren-Forward H, Forbes JF. Reproducibility of visual assessment on mammographic density. Breast Cancer Res Treat. 2008;108(1):121-7. KQ1E3c. [pmid: 17616811].
29 Garrido-Estepa M, Ruiz-Perales F, Miranda J, Ascunce N, Gonzalez-Roman I, Sanchez-Contador C, et al. Evaluation of mammographic density patterns: reproducibility and concordance among scales. BMC Cancer. 2010;10:485. KQE4a. [pmid: 20836850].
30 Gartlehner G, Thaler K, Chapman A, Kaminski-Hartenthaler A, Berzaczy D, Van Noord Megan G, et al. Mammography in combination with breast ultrasonography versus mammography for breast cancer screening in women at average risk. Cochrane Database of Syst Rev. 2013;4. [doi: 10.1002/14651858.CD009632.pub2]. KQ2E1, KQ3E1.
31 Gartlehner G, Thaler KJ, Chapman A, Kaminski A, Berzaczy D, Van Noord MG, et al. Adjunct ultrasonography for breast cancer screening in women at average risk: a systematic review. International Journal of Evidence-Based Healthcare. 2013;11(2):87-93. KQ2E7, KQ3E7. [pmid: 23750571].
32 Granader EJ, Dwamena B, Carlos RC. MRI and mammography surveillance of women at increased risk for breast cancer: recommendations using an evidence-based approach. Acad Radiol. 2008;15(12):1590-5. KQ3E1. [pmid: 19000876].
33 Haas BM, Kalra V, Geisel J, Raghu M, Durand M, Philpotts LE. Comparison of tomosynthesis plus digital mammography and digital mammography alone for breast cancer screening. Radiology. 2013;269(3):694-700. KQ2E8. [pmid: 23901124].
34 Health Quality O. Cancer screening with digital mammography for women at average risk for breast cancer, magnetic resonance imaging (MRI) for women at high risk: an evidence-based analysis. Ontario Health Technology Assessment Series. 2010;10(3):1-55. KQ2E1, KQ3E1. [pmid: 23074406].
35 Heine JJ, F EEE, Flowers CI. Full Field Digital Mammography and Breast Density. Comparison of Calibrated and Noncalibrated Measurements. Acad Radiol. 2011;18(11):1430-6. KQ1E3c. [pmid: 21971260].
36 Hollingsworth AB, Stough RG. An alternative approach to selecting patients for high-risk screening with breast MRI. Breast Journal. 2014;20(2):192-7. KQ3E4. [pmid: 24387050].
37 Honjo S, Ando J, Tsukioka T, Morikubo H, Ichimura M, Sunagawa M, et al. Relative and combined performance of mammography and ultrasonography for breast cancer screening in the general population: a pilot study in Tochigi Prefecture, Japan. Jpn J Clin Oncol. 2007;37(9):715-20. KQ3E1. [pmid: 17766996].
38 Irwig L, Houssami N, van Vliet C. New technologies in screening for breast cancer: a systematic review of their accuracy. Br J Cancer. 2004;90(11):2118-22. KQ3E1. [pmid: 15150556].
39 Kaplan SS. Clinical utility of bilateral whole-breast US in the evaluation of women with dense breast tissue. Radiology. 2001;221(3):641-9. KQ2E4a, KQ3E4a. [pmid: 11719658].
40 Keller BM, Nathan DL, Gavenonis SC, Chen J, Conant EF, Kontos D. Reader variability in breast density estimation from full-field digital mammograms: the effect of image postprocessing on relative and absolute measures. Acad Radiol. 2013;20(5):560-8. KQ1E3c. [pmid: 23465381].
41 Kerlikowske K, Grady D, Barclay J, Frankel SD, Ominsky SH, Sickles EA, et al. Variability and accuracy in mammographic interpretation using the American College of Radiology Breast Imaging Reporting and Data System. J Natl Cancer Inst. 1998;90(23):1801-9. KQ1E4. [pmid: 9839520].
42 Kerlikowske K, Hubbard RA, Miglioretti DL, Geller BM, Yankaskas BC, Lehman CD, et al. Comparative effectiveness of digital versus film-screen mammography in community practice in the United States: a cohort study. Ann Intern Med. 2011;155(8):493-502. KQ3E4a. [pmid: 22007043].
43 Kim do Y, Moon WK, Cho N, Ko ES, Yang SK, Park JS, et al. MRI of the breast for the detection and assessment of the size of ductal carcinoma in situ. Korean Journal of Radiology. 2007;8(1):32-9. KQ3E3b. [pmid: 17277561].
44 Kim SJ, Chang JM, Cho N, Chung SY, Han W, Moon WK. Outcome of breast lesions detected at screening ultrasonography. Eur J Radiol. 2012;81(11):3229-33. KQ3E5. [pmid: 22591758].
45 Kim WH, Moon WK, Kim SJ, Yi A, Yun BL, Cho N, et al. Ultrasonographic assessment of breast density. Breast Cancer Res Treat. 2013;138(3):851-9. KQ1E1. [pmid: 23568482].
46 Kim WH, Moon WK, Kim SM, Yi A, Chang JM, Koo HR, et al. Variability of breast density assessment in short-term reimaging with digital mammography. Eur J Radiol. 2013;82(10):1724-30. KQ1E1. [pmid: 23727379].
47 Ko SY, Kim EK, Kim MJ, Moon HJ. Mammographic density estimation with automated volumetric breast density measurement. Korean Journal of Radiology. 2014;15(3):313-21. KQ1E3c. [pmid: 24843235].
48 Kolb TM, Lichy J, Newhouse JH. Occult cancer in women with dense breasts: detection with screening US--diagnostic yield and tumor characteristics. Radiology. 1998;207(1):191-9. KQ3E9. [pmid: 9530316].
49 Kolb TM, Lichy J, Newhouse JH. Comparison of the performance of screening mammography, physical examination, and breast US and evaluation of factors that influence them: an analysis of 27,825 patient evaluations. Radiology. 2002;225(1):165-75. KQ2E6. [pmid: 12355001].
50 Kriege M, Brekelmans CT, Boetes C, Besnard PE, Zonderland HM, Obdeijn IM, et al. Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. 2004;351(5):427-37. KQ3E1. [pmid: 15282350].
51 Kriege M, Brekelmans CT, Peterse H, Obdeijn IM, Boetes C, Zonderland HM, et al. Tumor characteristics and detection method in the MRISC screening program for the early detection of hereditary breast cancer. Breast Cancer Res Treat. 2007;102(3):357-63. KQ3E1. [pmid: 17051427].
52 Kuhl CK, Schrading S, Bieling HB, Wardelmann E, Leutner CC, Koenig R, et al. MRI for diagnosis of pure ductal carcinoma in situ: a prospective observational study. Lancet. 2007;370(9586):485-92. KQ2E1. [pmid: 17693177].
53 Leconte I, Feger C, Galant C, Berliere M, Berg BV, D'Hoore W, et al. Mammography and subsequent whole-breast sonography of nonpalpable breast cancers: the importance of radiologic breast density. AJR American Journal of Roentgenology. 2003;180(6):1675-9. KQ2E8. [pmid: 12760942].
54 Lee CI, Ichikawa L, Rochelle MC, Kerlikowske K, Miglioretti DL, Sprague BL, et al. Breast MRI BI-RADS Assessments and Abnormal Interpretation Rates by Clinical Indication in US Community Practices. Acad Radiol. 2014. KQ1E3c. [pmid: 25126973].
55 Lehman CD, Blume JD, Weatherall P, Thickman D, Hylton N, Warner E, et al. Screening women at high risk for breast cancer with mammography and magnetic resonance imaging. Cancer. 2005;103(9):1898-905. KQ2E1. [pmid: 15800894].
56 Leung TK, Huang PJ, Chen CS, Lin YH, Wu CH, Lee CM. Is breast MRI screening more effective than digital mammography in Asian women?. Journal of Experimental and Clinical Medicine. 2010;2(5):245-50. KQ3E5.
57 Li J, Szekely L, Eriksson L, Heddson B, Sundbom A, Czene K, et al. High-throughput mammographic-density measurement: a tool for risk prediction of breast cancer. Breast Cancer Res. 2012;14(4). KQ3E5. [pmid: 22846386].
58 Lord SJ, Lei W, Craft P, Cawson JN, Morris I, Walleser S, et al. A systematic review of the effectiveness of magnetic resonance imaging (MRI) as an addition to mammography and ultrasound in screening young women at high risk of breast cancer. Eur J Cancer. 2007;43(13):1905-17. KQ2E1, KQ3E1. [pmid: 17681781].
59 Lowry SJ, Aiello Bowles EJ, Anderson ML, Buist DSM. Predictors of breast density change after hormone therapy cessation: Results from a randomized trial. Cancer Epidemiology Biomarkers and Prevention. 2011;20(10):2309-12. KQ3E5. [pmid: 21813728].
60 Manning MA, Duric N, Littrup P, Bey-Knight L, Penner L, Albrecht TL. Knowledge of breast density and awareness of related breast cancer risk. J Cancer Educ. 2013;28(2):270-4. KQ4E5. [pmid: 23467999].
61 Mercer CE, Hogg P, Kelly J, Borgen R, Millington SR, Hilton B, et al. A mammography image set for research purposes using BI-RADS density classification. Radiol Technol. 2014;85(6):609-13. KQ1E1. [pmid: 25002640].
62 Myles JP, Salmininen T, Duffy SW, Prevost TC, Day NE, Hakama M. Prospective estimation of rates of change in mammographic parenchymal patterns: Influence of age and of hormone replacement therapy. Breast. 2004;13(1):56-60. KQ3E5. [pmid: 14759717].
63 Nicholson BT, LoRusso AP, Smolkin M, Bovbjerg VE, Petroni GR, Harvey JA. Accuracy of assigned BI-RADS breast density category definitions. Acad Radiol. 2006;13(9):1143-9. KQ1E5. [pmid: 16935726].
64 Nickson C, Arzhaeva Y, Aitken Z, Elgindy T, Buckley M, Li M, et al. AutoDensity: An automated method to measure mammographic breast density that predicts breast cancer risk and screening outcomes. Breast Cancer Res. 2013;15(5). KQ1E3c. [pmid: 24020331].
65 Nothacker M, Duda V, Hahn M, Warm M, Degenhardt F, Madjar H, et al. Early detection of breast cancer: benefits and risks of supplemental breast ultrasound in asymptomatic women with mammographically dense breast tissue. A systematic review. BMC Cancer. 2009;9:335. KQ2E7, KQE7. [pmid: 19765317].
66 Obdeijn IM, Loo CE, Rijnsburger AJ, Wasser MN, Bergers E, Kok T, et al. Assessment of false-negative cases of breast MR imaging in women with a familial or genetic predisposition. Breast Cancer Res Treat. 2010;119(2):399-407. KQ3E4. [pmid: 19876732].
67 O'Driscoll D, Warren R, MacKay J, Britton P, Day NE. Screening with breast ultrasound in a population at moderate risk due to family history. J Med Screen. 2001;8(2):106-9. KQ3E1. [pmid: 11480440].
68 Ohuchi N, Suzuki A, Sakurai Y, Kawai M, Narikawa Y, Narimatsu H, et al. Current status and problems of breast cancer screening. Japan Medical Association Journal. 2009;52(1):45-9. KQ3E4.
69 Oliver A, Llado X, Freixenet J, Marti R, Perez E, Pont J, et al. Influence of Using Manual or Automatic Breast Density Information in a Mass Detection CAD System. Acad Radiol. 2010;17(7):877-83. KQ1E3c. [pmid: 20540910].
70 Ooms EA, Zonderland HM, Eijkemans MJ, Kriege M, Mahdavian Delavary B, Burger CW, et al. Mammography: interobserver variability in breast density assessment. Breast. 2007;16(6):568-76. KQ1E1. [pmid: 18035541].
71 Pediconi F, Catalano C, Roselli A, Dominelli V, Cagioli S, Karatasiou A, et al. The challenge of imaging dense breast parenchyma: is magnetic resonance mammography the technique of choice? A comparative study with x-ray mammography and whole-breast ultrasound. Invest Radiol. 2009;44(7):412-21. KQ2E1, KQ3E1. [pmid: 19448554].
72 Perez-Gomez B, Ruiz F, Martinez I, Casals M, Miranda J, Sanchez-Contador C, et al. Women's features and inter-/intra-rater agreement on mammographic density assessment in full-field digital mammograms (DDM-SPAIN). Breast Cancer Res Treat. 2012;132(1):287-95. KQ1E3c. [pmid: 22042363].
73 Peters G, Anderson J, Longman G, Thomson J, Taylor D, Bennett M, et al. Magnetic resonance findings in women at high risk for developing breast cancer: an Australian feasibility study. J Med Imaging Radiat Oncol. 2008;52(1):29-35. KQ3E1. [pmid: 18373823].
74 Podo F, Sardanelli F, Canese R, D'Agnolo G, Natali PG, Crecco M, et al. The Italian multi-centre project on evaluation of MRI and other imaging modalities in early detection of breast cancer in subjects at high genetic risk. J Exp Clin Cancer Res. 2002;21(3 Suppl):115-24. KQ3E1. [pmid: 12585665].
75 Riedl CC, Ponhold L, Flory D, Weber M, Kroiss R, Wagner T, et al. Magnetic resonance imaging of the breast improves detection of invasive cancer, preinvasive cancer, and premalignant lesions during surveillance of women at high risk for breast cancer. Clin Cancer Res. 2007;13(20):6144-52. KQ3E1. [pmid: 17947480].
76 Rubinstein WS, Latimer JJ, Sumkin JH, Huerbin M, Grant SG, Vogel VG. Prospective screening study of 0.5 Tesla dedicated magnetic resonance imaging for the detection of breast cancer in young, high-risk women. BMC Womens Health. 2006;6:10. KQ3E1. [pmid: 16800895].
77 Sadowski EA, Kelcz F. Frequency of malignancy in lesions classified as probably benign after dynamic contrast-enhanced breast MRI examination. J Magn Reson Imaging. 2005;21(5):556-64. KQ3E1. [pmid: 15834907].
78 Sardanelli F, Giuseppetti GM, Panizza P, Bazzocchi M, Fausto A, Simonetti G, et al. Sensitivity of MRI versus mammography for detecting foci of multifocal, multicentric breast cancer in fatty and dense breasts using the whole-breast pathologic examination as a gold standard. American Journal of Roentgenology. 2004;183(4):1149-57. KQ2E1. [pmid: 15385322].
79 Sardanelli F, Podo F. Breast MR imaging in women at high-risk of breast cancer. Is something changing in early breast cancer detection?. Eur Radiol. 2007;17(4):873-87. KQ2E4. [pmid: 17008989].
80 Scheel JR, Lee JM, Sprague BL, Lee CI, Lehman CD. Screening ultrasound as an adjunct to mammography in women with mammographically dense breasts. Am J Obstet Gynecol. 2014. KQ3E7. [pmid: 24959654].
81 Seo JM, Ko ES, Han BK, Ko EY, Shin JH, Hahn SY. Automated volumetric breast density estimation: a comparison with visual assessment. Clin Radiol. 2013;68(7):690-5. KQ1E5. [pmid: 23434202].
82 Sergeant JC, Walshaw L, Wilson M, Seed S, Barr N, Beetles U, et al. Same task, same observers, different values: the problem with visual assessment of breast density. Medical Imaging Conference: Image Perception, Observer Performance, and Technology Assessment. 2013. Feb. 09. Lake Buena Vista, Florida. International Society for Optics and Photonics. 2013. KQ1E3c.
83 Singh JM, Fallenberg EM, Diekmann F, Renz DM, Witlandt R, Bick U, et al. Volumetric breast density assessment: reproducibility in serial examinations and comparison with visual assessment. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2013;185(9):844-8. KQ1E1. [pmid: 23888472].
84 Sprague BL, Stout NK, Schechter C, van Ravesteyn NT, Cevik M, Oguzhan A, et al. Potential impact of legislation mandating breast density notification: benefits, harms, and cost effectiveness of supplemental ultrasound screening. Ann Intern Med. in press. KQ1E5.
85 Sprague BL, Gangnon RE, Burt V, Trentham-Dietz A, Hampton JM, Wellman RD, et al. Prevalence of mammographically dense breasts in the United States. J Natl Cancer Inst. 2014;106(10). KQ1E5. [pmid: 25217577].
86 Stone J, Ding J, Warren RML, Duffy SW, Hopper JL. Using mammographic density to predict breast cancer risk: Dense area or percentage dense area. Breast Cancer Res. 2010;12(6). KQ3E5. [pmid: 21087468].
87 Stone J, Warren RM, Pinney E, Warwick J, Cuzick J. Determinants of percentage and area measures of mammographic density. Am J Epidemiol. 2009;170(12):1571-8. KQ1E3c. [pmid: 19910376].
88 Stone JGA, Martin LJ, Yaffe M, Minkin S, Boyd NF. The detection of change in mammographic density. Cancer Epidemiol Biomarkers Prev. 2003;12(7):625-30. KQ3E5. [pmid: 12869401].
89 Stoutjesdijk MJ, Boetes C, Jager GJ, Beex L, Bult P, Hendriks JH, et al. Magnetic resonance imaging and mammography in women with a hereditary risk of breast cancer. J Natl Cancer Inst. 2001;93(14):1095-102. KQ2E1, KQ3E1. [pmid: 11459871].
90 Svahn TM, Chakraborty DP, Ikeda D, Zackrisson S, Do Y, Mattsson S, et al. Breast tomosynthesis and digital mammography: a comparison of diagnostic accuracy. Br J Radiol. 2012;85(1019):e1074-82. KQ3E1. [pmid: 22674710].
91 Tagliafico A, Tagliafico G, Astengo D, Cavagnetto F, Rosasco R, Rescinito G, et al. Mammographic density estimation: one-to-one comparison of digital mammography and digital breast tomosynthesis using fully automated software. Eur Radiol. 2012;22(6):1265-70. KQ1E4. [pmid: 22358426].
92 Tagliafico A, Tagliafico G, Tosto S, Chiesa F, Martinoli C, Derchi LE, et al. Mammographic density estimation: comparison among BI-RADS categories, a semi-automated software and a fully automated one. Breast. 2009;18(1):35-40. KQ1E5. [pmid: 19010678].
93 Tagliafico AS, Tagliafico G, Cavagnetto F, Calabrese M, Houssami N. Estimation of percentage breast tissue density: Comparison between digital mammography (2D full field digital mammography) and digital breast tomosynthesis according to different BI-RADS categories. Br J Radiol. 2013;86(1031). KQ1E1. [pmid: 24029631].
94 Tilanus-Linthorst MMA, Obdeijn IMM, Bartels KCM, De Koning HJ, Oudkerk M. First experiences screening women at high risk for breast cancer with MR imaging. Breast Cancer Res Treat. 2000;63(1):53-60. KQ2E1. [pmid: 11079159].
95 Wallis MG, Moa E, Zanca F, Leifland K, Danielsson M. Two-view and single-view tomosynthesis versus full-field digital mammography: High-resolution x-ray imaging observer study. Radiology. 2012;262(3):788-96. KQ2E1a. [pmid: 22274840].
96 Wang FL, Chen F, Yin H, Xu N, Wu XX, Ma JJ, et al. Effects of age, breast density and volume on breast cancer diagnosis: a retrospective comparison of sensitivity of mammography and ultrasonography in China's rural areas. Asian Pacific Journal of Cancer Prevention: Apjcp. 2013;14(4):2277-82. KQ2E1. [pmid: 23725127].
97 Warner E, Messersmith H, Causer P, Eisen A, Shumak R, Plewes D. Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. Ann Intern Med. 2008;148(9):671-9. KQ2E1, KQ3E1. [pmid: 18458280].
98 Warren RM, Pointon L, Caines R, Hayes C, Thompson D, Leach MO, et al. What is the recall rate of breast MRI when used for screening asymptomatic women at high risk?. Magn Reson Imaging. 2002;20(7):557-65. KQ3E1. [pmid: 12413602].
99 Warren RM, Young JR, McLean L, Lyons K, Wilson AR, Evans A, et al. Radiology review of the UKCCCR Breast Screening Frequency Trial: potential improvements in sensitivity and lead time of radiological signs. Clin Radiol. 2003;58(2):128-32. KQ2E3. [pmid: 12623041].
100 Weinstein SP, Localio AR, Conant EF, Rosen M, Thomas KM, Schnall MD. Multimodality screening of high-risk women: a prospective cohort study. J Clin Oncol. 2009;27(36):6124-8. KQ3E1. [pmid: 19884532].
101 Wojcinski S, Gyapong S, Farrokh A, Soergel P, Hillemanns P, Degenhardt F. Diagnostic performance and inter-observer concordance in lesion detection with the automated breast volume scanner (ABVS). BMC Med Imaging. 2013;13:36. KQ1E3c. [pmid: 24219312].
102 Yaghjyan L, Colditz GA, Drake B. Vitamin D and mammographic breast density: A systematic review. Cancer Causes Control. 2012;23(1):1-13. KQ3E5. [pmid: 21984232].
103 Zuley ML, Guo B, Catullo VJ, Chough DM, Kelly AE, Lu AH, et al. Comparison of Two-dimensional synthesized Mammograms versus Original Digital Mammograms alone and in combination with Tomosynthesis images. Radiology. 2014;271(3):664-71. KQ1E3c. [pmid: 24475859].