# Ongoing Studies and Trials Pending Assessment

Investigator (Location) Study Title/Name | Number of Participants/Estimated Enrollment | Intervention | Outcomes | 2015 Status
Carla van Gils (Netherlands) Breast Cancer Screening with MRI in Women Aged 50-75 Years with Extremely Dense Breast Tissue: the DENSE Trial | 36,185 | Biennial screening with mammography and MRI compared to mammography alone among women with >75% mammographic density | Interval cancers; screen-detected tumors, tumor size, stage, grade distribution; referral rate; positive predictive value and false positives; biopsies per positive test; mortality rate; cost effectiveness; quality of life | Study Period: November 2011 – December 2019 Recruiting
Alberto Tagliafico (Italy) Tomosynthesis (TS) Versus Ultrasonogrphy (US) in Women with Dense Breasts (ASTOUND) | 4,000 | Screening with DBT compared to ultrasound in women with dense breasts | Sensitivity; specificity | Study Period: December 2012 – July 2016 Recruiting
Denise Chough (Pittsburg) Assessment of Automated Breast Ultrasound | 1,000 | Screening with ABUS, DBT, or a combination of both | False positive rates; biopsy rates; NPV | Study Period: April 2015 – November 2017 Not yet recruiting
Constance Lehman (Seattle) Automated Breast Ultrasound and Digital Breast Tomosynthesis Screening Compared to Full Field Digital Mammography in Women With Dense Breasts | 650 | Screening with digital mammography and DBT with and without automated whole breast ultrasound in women with dense breasts | Abnormal interpretation rate; sensitivity; specificity; cancer rate; positive predictive value; negative predictive value | Study Period: April 2014 – June 2017 Recruiting
Jung Min Chang (South Korea) Comparison of Diagnostic Performance of Digital Breast Tomosynthesis and Ultrasound in Women With Dense Breasts | 825 | Screening with DBT compared to ultrasonography in women with dense breasts | Sensitivity; specificity; negative predictive value; positive predictive value | Study Period: June 2013 – April 2014 Recruiting
Tilanus-Linthorst (Netherlands) Breast density in women with familial risk as indicator for the use of mammography or MRI to screen for breast cancer: An RCT (FaMRIsc) | 2,000 | Annual screening with MRI and mammography versus mammography alone in women at high risk of breast cancer | Cancer detection; interval cancer rates; stage at diagnosis; sensitivity; specificity; mortality; cost-effectiveness | Study Period: January 2011 – January 2015 Recruiting