# Detailed Methods

## Key Question Literature Search Strategies

### KQ 1 BI-RADS Accuracy and Reliability

Database: Ovid MEDLINE(R)

Search Strategy:

---------------------------------------------------------------------------

1. “breast densit*”.ti,ab.
2. parenchym*.ti,ab.
3. mammo* pattern.ti,ab.
4. mammo* patterns.ti,ab.
5. radiological pattern*.ti,ab.
6. wolfe*.ti,ab.
7. tabar*.ti,ab.
8. mammo* feature*.ti,ab.
9. breast pattern*.ti,ab.
10. mammo* densit*.ti,ab.
11. tissue densit*.ti,ab.
12. exp “Predictive Value of Tests”/ or diagnostic accuracy.mp. or exp “Sensitivity and Specificity”/
13. diagnostic errors/ or observer variation/
14. “Reproducibility of Results”/ or inter-rater.mp.
15. or/12-14
16. or/1-11
17. (BI-RADS or birad or bi-rad or bi-rads or “Breast Imaging Reporting and Data System”).ti,ab.
18. 15 and 16 and 17
19. limit 18 to ((abstracts or english language) and yr=”2000 - 2014”)

### KQ 2, 3 Supplemental Screening Performance and Outcomes

Database: Cochrane

Search Strategy:

---------------------------------------------------------------------------

‘mammogra* AND screen* AND (breast density OR dense breast OR parenchym*) in Title, Abstract, Keywords

Database: Ovid MEDLINE(R)

Search Strategy:

---------------------------------------------------------------------------

1. “breast densit*”.ti,ab.
2. parenchym*.ti,ab.
3. mammo* pattern.ti,ab.
4. mammo* patterns.ti,ab.
5. radiological pattern*.ti,ab.
6. wolfe*.ti,ab.
7. tabar*.ti,ab.
8. mammo* feature*.ti,ab.
9. breast pattern*.ti,ab.
10. mammo* densit*.ti,ab.
11. tissue densit*.ti,ab.
12. or/1-11
13. (negative test result* or false negative).mp. or exp False Negative Reactions/
14. “sensitivity and specificity”/ or “limit of detection”/ or roc curve/ or signal-to-noise ratio/
15. “sensitivity and specificity”/ or “limit of detection”/ or roc curve/ or signal-to-noise ratio/
16. or/13-15
17. ((negative adj4 mammogra*) or negative screen).mp.
18. 16 or 17
19. (supplementa* adj3 screen*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
20. (breast or mammogra*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
21. 12 and 16 and 18
22. 20 and 21
23. 12 and 19
24. (((supplementa* adj5 ultraso*) or supplementa*) adj5 imag*).mp.
25. 12 and 24
26. 20 and 25
27. 22 or 26
28. 23 or 27
29. limit 28 to ((abstracts or english language) and yr=”2000 -Current”)

Database: Ovid MEDLINE(R)

Search Strategy:

---------------------------------------------------------------------------

1 exp Sensitivity and Specificity/
2 sensitivity.tw.
3 specificity.tw.
4 ((pre-test or pretest) adj probability).tw.
5 post-test probability.tw.
6 post-test probability.tw.
7 likelihood ratio.tw.
8 or/1-7
9 Breast Neoplasms/
10 (breast adj (neoplasm or neoplasms or tumour or tumor or tumors or tumours or cancer or carcinoma or carcinomas or oncologic or oncology)).mp.
11 9 or 10
12 exp Mammography/
13 Mammograph.ti,ab.
14 12 or 13
15 8 and 14
16 breast densit.ti,ab.
17 parenchym.ti,ab.
18 mammo pattern.ti,ab.
19 mammo patterns.ti,ab.
20 radiological pattern.ti,ab.
21 wolfe.ti,ab.
22 tabar.ti,ab.
23 (birad or bi-rad).ti,ab.
24 mammo feature.ti,ab.
25 breast pattern.ti,ab.
26 mammo densit.ti,ab.
27 tissue densit.ti,ab.
28 breast imaging reporting and data system.ti,ab.
29 or/16-28
30 8 and 11 and 14 and 29
31 limit 30 to english language
1 65. Image Processing, Computer-Assisted/ or Radiographic Image Interpretation, Computer-Assisted/ or Tomography, X-Ray Computed/ or Radiographic Image Enhancement/ or Tomography, X-Ray/ or tomosynthesis.mp. or Imaging, Three-Dimensional/
2 66. 64 and 65
3 67. Ultrasonography, Mammary/ or automated ultrasound.mp.
4 68. whole breast ultrasound.mp.
5 69. hand help ultrasound.mp.
6 70. magnetic resonance imaging.mp. or Magnetic Resonance Imaging/
7 71. mri.mp.
8 72. Technetium Tc 99m Sestamibi/ or scintimammography.mp.
9 73. or/67-72
10 74. 31 and 73
11 75. limit 74 to (english language and yr=”2000 -Current”)
12 79. or/76-78
13 80. 62 and 79
14 81. limit 80 to (english language and yr=”2000 -Current”)
15 82. 81 not 75
16 83. 65 or 73
17 84. 82 and 83

Database: Embase

Search Strategy:

---------------------------------------------------------------------------

1 ‘mammography’/exp OR ‘mammography’ OR ‘mammography system’/exp OR ‘mammography system’ OR mammograph*:ab,ti AND [2000-2014]/py
2 ‘dosimetry’/exp OR ‘dosimetry’ OR ‘radiation protection’/exp OR ‘radiation protection’ OR ‘radiation measurement’/exp OR ‘radiation measurement’ AND [2000-2014]/py
4 ‘radiation exposure’/exp OR ‘radiation exposure’ OR ‘radiation induced neoplasm’/exp OR ‘radiation induced neoplasm’ OR ‘radiation injury’/exp OR ‘radiation injury’ AND [2000-2014]/py
5 ‘morbidity’/exp OR ‘morbidity’ OR ‘mortality’/exp OR ‘mortality’ OR ‘adverse effect’:ab,ti OR ‘adverse effects’:ab,ti OR harm:ab,ti OR harms:ab,ti OR contraindic*:ab,ti AND [2000-2014]/py
6 #2 OR #4
7 #1 AND #5 AND #6
8.1 ‘breast tumor’/exp/dm_pc,dm_di
8.2 (breast NEXT/5 (neoplasm* OR tumour* OR tumor* OR cancer* OR carcinom* OR oncolog*)):ab,ti
8.3 #8.1 OR #8.2
8.4 ‘mass screening’/exp OR ‘mass radiography’/exp
8.5 ‘neoplasm’/exp/dm_pc,dm_di
8.6 ‘mammography’/exp OR ‘mammography system’/exp OR mammograph*:ab,ti
8.7 screen*:ab,ti
8.8 #8.4 OR #8.5 OR #8.6 OR #8.7
8.9 #8.3 AND #8.8
8.10 ‘sensitivity and specificity’/exp OR sensitivity:ab,ti OR specificity:ab,ti
8.11 ((‘pre test’ OR pretest) NEAR/5 probability):ab,ti
8.12 ((‘pre test’ OR pretest) NEAR/5 probability):ab,ti
8.13 ‘likelihood ratio’:ab,ti OR ‘likelihood ratios’:ab,ti
8.14 #8.10 OR #8.11 OR #8.12 OR #8.13
8.15 #8.9 AND #8.14
8.16 ‘breast density’:ab,ti OR ‘dense breasts’:ab,ti OR ‘dense breast’:ab,ti OR parenchym*:ab,ti OR ‘mammographic feature’:ab,ti OR ‘mammographic features’:ab,ti OR (mammography NEAR/2 feature*):ab,ti OR ‘breast pattern’:ab,ti OR ‘breast patterns’:ab,ti OR (breast NEAR/3 pattern):ab,ti OR ‘mammographic density’:ab,ti OR (mammography NEAR/3 density):ab,ti OR ‘mammographic pattern’:ab,ti OR ‘mammographic patterns’:ab,ti OR (mammography NEAR/2 patterns):ab,ti OR ‘radiological pattern’:ab,ti OR ‘radiological patterns’:ab,ti OR wolfe*:ab,ti OR tabar*:ab,ti OR birad*:ab,ti OR ‘bi rad’:ab,ti OR ‘breast imaging reporting and data system’:ab,ti OR ‘tissue density’:ab,ti OR (tissue NEAR/3 density):ab,ti
8.17 #8.15 AND #8.16
8.18 #8.17 AND [english]/lim AND [2000-2014]/py

### KQ 4 Breast Density Notification-Related Harms

Database: Ovid MEDLINE(R)

Search Strategy:

---------------------------------------------------------------------------

1. “breast densit*”.ti,ab.
2. parenchym*.ti,ab.
3. mammo* pattern.ti,ab.
4. mammo* patterns.ti,ab.
5. radiological pattern*.ti,ab.
6. wolfe*.ti,ab.
7. tabar*.ti,ab.
8. mammo* feature*.ti,ab.
9. breast pattern*.ti,ab.
10. mammo* densit*.ti,ab.
11. tissue densit*.ti,ab.
12. or/1-11
13. px.fs.
14. “Risk Factors”/
15. “Health Knowledge, Attitudes, Practice”/
16. “Awareness”/
17. or/13-16
18. 12 and 17
19. (breast or mammogr*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
20. 18 and 19
21. “False Positive Reactions”/ or “False Negative Reactions”/ or “Anxiety”/ or “Depression”/ or “Stress, Psychological”/ or “Patient Acceptance of Health Care”/ or px.fs. or “Motivation”/ or barrier$.mp. or “attitude to health”/ or “womens health”/ or exp “Quality of Life”/ or exp Health Status Indicators/
22. 20 and 21
23. limit 22 to ((abstracts or english language) and yr=”2000 - current”)

Database: Embase

Search Strategy:

---------------------------------------------------------------------------

1 ‘breast density’:ab,ti OR (breast NEAR/3 density):ab,ti OR ‘dense breast’:ab,ti OR ‘dense breasts’:ab,ti
2 parenchym*:ab,ti
3 (mammo* NEAR/1 pattern):ab,ti
4 (radiologic* NEAR/1 pattern):ab,ti
5 #breastcascreening-59 OR #breastcascreening-58 OR #breastcascreening-57 OR #breastcascreening-56 OR #breastcascreening-55 OR #breastcascreening-54 OR #breastcascreening-53
6 #1 OR #2 OR #3 OR #4 OR #5
7 ‘false positive reactions’/exp OR ‘false positive reactions’ OR ‘false negative reactions’/exp OR ‘false negative reactions’ OR ‘anxiety’/exp OR ‘anxiety’ OR ‘depression’/exp OR ‘depression’ OR ‘stress, psychological’/exp OR ‘stress, psychological’ OR ‘patient acceptance of health care’/exp OR ‘patient acceptance of health care’ OR psychological OR ‘motivation’/exp OR ‘motivation’ OR barrier$:ab,ti OR ‘attitude to health’/exp OR ‘attitude to health’ OR ‘womens health’/exp OR ‘womens health’ OR ‘quality of life’/exp OR ‘quality of life’ OR ‘health’/exp OR health AND status AND indicators OR harms OR harm AND (‘reduction’/exp OR reduction) OR ‘risk’/exp OR risk AND assessment
8 #6 AND #7
9 mammogram OR ‘mammography’/exp OR mammography OR magnetic AND resonance AND (‘imaging’/exp OR imaging) OR ‘mri’/exp OR mri OR ultrasonog*
10 #8 AND #9
11 ‘breast’/exp OR breast
12 #10 AND #11
13 #12 AND [english]/lim AND [2000-2014]/py
14 harms AND [2000-2014]/py
15 #13 AND #14
17 supplementary AND (‘screening’/exp OR screening) AND [2000-2014]/py
18 #13 AND #17
19 #15 OR #18
20 ‘risk assessment’/exp
22 #6 AND #20 AND [2000-2014]/py
23 #11 AND #22
24 #1 AND #23
25 #24 AND [english]/lim AND [2000-2014]/py

Appendix A Figure 1 Literature Flow Diagram

Appendix A Figure 1 is a flow chart that summarizes the search and selection of articles. There were 1,947 citations identified through literature databases and an additional 56 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 1,891 unique citations were screened at the title/abstract stage. The full-text of 126 citations were examined for inclusion for one or more of the four Key Questions. The following number of articles were included for Key Question 1 (n=5), Key Question 2 (n=8), Key Question 3 (n=18), and Key Question 4 (n=1). Reasons for excluding the other articles are available in Appendix C.

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | KQs | Inclusion | Exclusion
Populations | 1 | Women primarily aged 40 years and older receiving screening mammography (digital or film) | Women with:; - Pre-existing breast cancer; - Clinically significant BRCA 1/2 mutations; - Li-Fraumeni syndrome; - Cowden syndrome; - Hereditary diffuse gastric syndrome; - Other familial breast cancer syndromes; - High-risk breast lesions (DCIS, LCIS, ADH, ALH); - Previous doses of chest radiation (>20Gy) before age 30; - Undergoing diagnostic or surveillance mammography
Populations | 2-4 | Women primarily aged 40 years and older undergoing screening mammography or who had a negative mammogram and found to have dense breasts. Dense breasts defined as BI-RADS 3 or 4, c or d, or “heterogeneous” or “extremely” dense
Setting | 1-4 | Conducted in primary care or other setting with primary care-comparable population | Settings not generalizable to primary care
Intervention or Exposure | 1 | Breast Imaging Reporting and Data System (BI-RADS) for mammographic breast density | Digital or full-film mammography alone (okay for KQ1); use of new technologies for diagnostic or surveillance purposes; use in a diagnostic or surveillance setting only
Intervention or Exposure | 2-3 | Breast MRI, hand-held ultrasound, whole breast ultrasound, and/or breast DBT used in a screening setting | Digital or full-film mammography alone (okay for KQ1); use of new technologies for diagnostic or surveillance purposes; use in a diagnostic or surveillance setting only
Intervention or Exposure | 4 | Received breast density notification | Digital or full-film mammography alone (okay for KQ1); use of new technologies for diagnostic or surveillance purposes; use in a diagnostic or surveillance setting only
Comparisons or Nonexposue | 1 | Other approaches for breast density determination (BIRAD ultrasound, percent density, other systems (e.g., Boyd, Wolfe):
Comparisons or Nonexposue | 2-3 | Digital mammography; women ages 40-49 vs. 50-59 vs. 60-69 vs. 70-79 (or other age comparisons); non-dense breasts
Comparisons or Nonexposue | 4 | Did not receive breast density notification
Outcomes | 1 | BI-RADS density determination concordance (inter- and intra- rater reliability, consistency)
Outcomes | 2 | Test performance characteristics (sensitivity, specificity, positive predictive value, negative predictive value, likelihood ratios for invasive breast cancers, breast lesions [DCIS], total breast cancers, breast cancers by stage)
Outcomes | 3 | Health Outcomes (interval cancer incidence, DCIS diagnosis rate, stage at breast cancer diagnosis, invasive breast cancer recurrence rate, breast cancer mortality)
Outcomes | 4 | Harms of breast density notification (quality of life, anxiety)
Study Designs | 1 | RCT's, prospective and retrospective cohort studies, cross-sectional studies, test sets involving multiple blinded readings of digital or film mammograms by at least three readers looking at reproducibility cross-sectional or longitudinally | Test sets involving fewer than 3 independent readers
Study Designs | 2 | Diagnostic accuracy studies with reference standard and more than one radiologist/reader, cohort studies with more than one radiologist/reader, and meta-analyses | Narrative reviews, editorials, commentary
Study Designs | 3 | Randomized controlled trials (RCTs), cohort studies ; meta-analyses | Narrative reviews, editorials, commentary
Study Designs | 4 | RCTs, prospective and retrospective cohort studies, case-control studies, cross-sectional studies, systematic reviews, meta-analyses, and modeling studies | Narrative reviews, editorials, commentary
Language | 1-4 | English only | Non-English languages
Publication Date | 1-4 | Trials published from January 2000 to present | Trials published before January 2000
Study Quality | 1-4 | Fair- and good-quality studies | Poor-quality studies