# References

1 U. S. Preventive Services Task Force. Screening for breast cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(10):716-26. [pmid: 19920272].
2 Simpson JF, Wilkinson EJ. Malignant Neoplasia of the Breast: Infiltrating Carcinomas. Bland KI, Copeland EM 3rd, editors. The breast : comprehensive management of benign and malignant disorders. 3rd Ed. St Louis. Saunders. 2004.
3 Houghton J, George WD, Cuzick J, et al. Radiotherapy and tamoxifen in women with completely excised ductal carcinoma in situ of the breast in the UK, Australia, and New Zealand: randomised controlled trial. Lancet. 2003;362(9378):95-102. [pmid: 12867108].
4 Schwartz GF. Biology and Management of Lobular Carcinoma In Situ of the Breast. Bland KI, Copeland EM 3rd, editors. The breast : comprehensive management of benign and malignant disorders. St Louis. Saunders. 2004.
5 Page DL, Lagios MD. In Situ Carcinomas of the Breast: Ductal Carcinoma In Situ, Paget's Disease, Lobular Carcinoma In Situ. Bland KI, Copeland EM 3rd, editors. The breast : comprehensive management of benign and malignant disorders. St Louis. Saunders. 2004.
6 Centers for Disease Control and Prevention. Breast Cancer Statistics. Available at: http://www.cdc.gov/cancer/breast/statistics/. October 10, 2012.
7 Centers for Disease Control and Prevention. Screening for Breast Cancer. Available at: http://www.cdc.gov/cancer/breast/basic_info/screening.htm. June 4, 2013.
8 SEER Statistics Fact Sheets: Breast Cancer. National Cancer Institute. Bethesda, MD. Available at: http://seer.cancer.gov/statfacts/html/breast.html. March 15, 2015.
9 Howlader N, Noone A, Krapcho M, et al. Cancer Statistics Review. 1975-2008. Available at: http://seer.cancer.gov/csr/1975_2008/. October 16, 2014.
10 Lawson JS, Gunzburg WH, Whitaker NJ. Viruses and human breast cancer. Future Microbiol. 2006;1:33-51. [pmid: 17661684].
11 American Cancer Society. Breast Cancer Facts & Figures 2013-2014. Atlanta. American Cancer Society, Inc. 2013. Available at:.
12 Burstein HJ, Polyak K, Wong JS, et al. Ductal carcinoma in situ of the breast. N Engl J Med. 2004;350(14):1430-41. [pmid: 15070793].
13 Erbas B, Provenzano E, Armes J, et al. The natural history of ductal carcinoma in situ of the breast: a review. Breast Cancer Res Treat. 2006;97(2):135-44. [pmid: 16319971].
14 Armstrong K, Moye E, Williams S, et al. Screening mammography in women 40 to 49 years of age: a systematic review for the American College of Physicians. Ann Intern Med. 2007;146(7):516-26. [pmid: 17404354].
15 Allegra CJ, Aberle DR, Ganschow P, et al. NIH state-of-the-science conference statement: diagnosis and management of ductal carcinoma in situ (DCIS). NIH Consens State Sci Statements. 2009;26(2):1-27. [pmid: 19784089].
16 Hwang ES, Miglioretti DL, Ballard-Barbash R, et al. Association between breast density and subsequent breast cancer following treatment for ductal carcinoma in situ. Cancer Epidemiol Biomarkers Prev. 2007;16(12):2587-93. [pmid: 18086762].
17 Nelson HD, Zakher B, Cantor A, et al. Risk factors for breast cancer for women aged 40 to 49 years: a systematic review and meta-analysis. Ann Intern Med. 2012;156(9):635-48. [pmid: 22547473].
18 Nelson HD, Pappas M, Zakher B, et al. Risk assessment, genetic counseling, and genetic testing for BRCA-related cancer in women: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2014;160(4):255-66. [pmid: 24366442].
19 National Cancer Institute. Screening mammograms: questions and answers. National Cancer Institute. Available at: http://www.cancer.gov/cancertopics/factsheet/detection/mammograms. 30 July, 2012.
20 Coopey S, Mazzola E, Buckley J, et al. The role of chemoprevention in modifying the risk of breast cancer in women with atypical breast lesions. Breast Cancer Res Treat. 2012;136(3):627-33. [pmid: 23117858].
21 Colditz GA, Willett WC, Hunter DJ. Family history, age, and risk of breast cancer. Prospective data from the Nurses' Health Study. JAMA. 1993;270(3):338-43. [pmid: 8123079].
22 Johnson N, Lancaster T, Fuller A. The prevalence of a family history of cancer in general practice. Fam Pract. 1995;12(3):287-9. [pmid: 8536831].
23 Pharoah PD, Day NE, Duffy S, et al. Family history and the risk of breast cancer: a systematic review and meta-analysis. Int J Cancer. 1997;71(5):800-9. [pmid: 9180149].
24 Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993;270(13):1563-8. [pmid: 8371466].
25 Yang Q, Khoury MJ, Rodriguez C, et al. Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982-1991. Am J Epidemiol. 1998;147(7):652-9. [pmid: 9554604].
26 Nelson HD, Walker M, Zakher B, et al. Menopausal Hormone Therapy for the Primary Prevention of Chronic Conditions: A Systematic Review to Update the U.S. Preventive Services Task Force Recommendations. Ann Intern Med. 2012;157(2):104-W-23. [pmid: 22786830].
27 Huang Z, Hankinson SE, Colditz GA, et al. Dual effects of weight and weight gain on breast cancer risk. JAMA. 1997;278(17):1407-11. [pmid: 9355998].
28 Kerlikowske K, Cook AJ, Buist DSM, et al. Breast cancer risk by breast density, menopause, and postmenopausal hormone therapy use. J Clin Oncol. 2010;28(24):3830-7. [pmid: 20644098].
29 D'Orsi C, Sickles E, Mendelson E, et al. ACR BI-RADS® Atlas, Breast Imaging Reporting and Data System. Reston, VA. American College of Radiology. 2013.
30 Sprague BL, Gangnon RE, Burt V, et al. Prevalence of mammographically dense breasts in the United States. J Natl Cancer Inst. 2014;106(10). [pmid: 25217577].
31 Nelson HD, Smith ME, Griffin JC, et al. Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;158(8):604-14. [pmid: 23588749].
32 Esserman LJ, Thompson IM, Reid B, et al. Addressing overdiagnosis and overtreatment in cancer: a prescription for change. Lancet Oncol. 2014;15(6):e234-e42. [pmid: 24807866].
33 Berry DA, Cronin KA, Plevritis SK, et al. Effect of screening and adjuvant therapy on mortality from breast cancer. N Engl J Med. 2005;353(17):1784-92. [pmid: 16251534].
34 Kalager M, Zelen M, Langmark F, et al. Effect of screening mammography on breast-cancer mortality in Norway. N Engl J Med. 2010;363(13):1203-10. [pmid: 20860502].
35 NCCN. NCCN Clinical Practice Guidelines in Oncology: Breast Cancer. Fort Washington, PA. 2014. Available at: http://www.nccn.org/professionals/physician_gls/f_guidelines.asp. September 18, 2014.
36 Edge S, Byrd DR, Compton C, et al. AJCC Cancer Staging Manual. 7th ed. New York. Springer. 2010.
37 Goss PE, Ingle JN, Martino S, et al. A randomized trial of letrozole in postmenopausal women after five years of tamoxifen therapy for early-stage breast cancer. N Engl J Med. 2003;349(19):1793-802. [pmid: 14551341].
38 Paik S, Shak S, Tang G, et al. A Multigene Assay to Predict Recurrence of Tamoxifen-Treated, Node-Negative Breast Cancer. N Engl J Med. 2004;351(27):2817-26. [pmid: 15591335].
39 Buyse M, Loi S, van't Veer L, et al. Validation and clinical utility of a 70-gene prognostic signature for women with node-negative breast cancer. J Natl Cancer Inst. 2006;98(17):1183-92. [pmid: 16954471].
40 Paik S, Tang G, Shak S, et al. Gene expression and benefit of chemotherapy in women with node-negative, estrogen receptor-positive breast cancer. J Clin Oncol. 2006;24(23):3726-34. [pmid: 16720680].
41 National Center for Health Statistics. Utilization of Health Resources, Table 82(page 1 of 3). Use of mammography among women aged 40 and over, by selected characteristics: United States, selected years 1987–2010. Hyattsville, Maryland. Available at: http://www.cdc.gov/nchs/data/hus/2012/083.pdf. 9 July.
42 Block L, Jarlenski M, Wu A, et al. Mammography Use Among Women Ages 40–49 After the 2009 U.S. Preventive Services Task Force Recommendation. J Gen Intern Med. 2013:1-7. [pmid: 23242866].
43 NCQA. Proposed Changes to Existing Measure for HEDIS^®1^ 2014: Breast Cancer Screening (BCS). Available at: http://www.ncqa.org/Portals/0/PublicComment/HEDIS2014/2.%20BCS%20Materials.pdf. October 27, 2014.
44 Nelson HD, Tyne K, Naik A, et al. Screening for breast cancer: an update for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(10):727-37. [pmid: 19920273].
45 Diagnostic Imaging. Breast Density Notification Laws by State-Interactive Map. Available at: http://www.diagnosticimaging.com/login?referrer=http%3A//www.diagnosticimaging.com%2Fbreast-density-notification-laws-state-interactive-map. March 20, 2015.
46 Berg WA, Zhang Z, Lehrer D, et al. Detection of breast cancer with addition of annual screening ultrasound or a single screening MRI to mammography in women with elevated breast cancer risk. JAMA. 2012;307(13):1394-404. [pmid: 22474203].
47 Berg WA, Blume JD, Cormack JB, et al. Combined screening with ultrasound and mammography vs mammography alone in women at elevated risk of breast cancer. [Erratum appears in JAMA. 2010 Apr 21;303(15):1482]. JAMA. 2008;299(18):2151-63. [pmid: 18477782].
48 Weigert J, Steenbergen S. The connecticut experiment: the role of ultrasound in the screening of women with dense breasts. Breast J. 2012;18(6):517-22. [pmid: 23009208].
49 Parris T, Wakefield D, Frimmer H. Real world performance of screening breast ultrasound following enactment of Connecticut Bill 458. Breast J. 2013;19(1):64-70. [pmid: 23240937].
50 Hooley RJ, Greenberg KL, Stackhouse RM, et al. Screening US in patients with mammographically dense breasts: initial experience with Connecticut Public Act 09-41. Radiology. 2012;265(1):59-69. [pmid: 22723501].
51 Nothacker M, Duda V, Hahn M, et al. Early detection of breast cancer: benefits and risks of supplemental breast ultrasound in asymptomatic women with mammographically dense breast tissue. A systematic review. BMC Cancer. 2009;9:335. [pmid: 19765317].
52 Saslow D, Boetes C, Burke W, et al. American Cancer Society guidelines for breast screening with MRI as an adjunct to mammography. [Erratum appears in CA Cancer J Clin. 2007 May-Jun;57(3):185]. CA Cancer J Clin. 2007;57(2):75-89. [pmid: 17392385].
53 Fajardo LL, Pisano ED, Caudry DJ, et al. Stereotactic and sonographic large-core biopsy of nonpalpable breast lesions: results of the Radiologic Diagnostic Oncology Group V study. Acad Radiol. 2004;11(3):293-308. [pmid: 15035520].
54 Pisano ED, Fajardo LL, Caudry DJ, et al. Fine-needle aspiration biopsy of nonpalpable breast lesions in a multicenter clinical trial: results from the radiologic diagnostic oncology group V. Radiology. 2001;219(3):785-92. [pmid: 11376270].
55 Silverstein MJ, Lagios MD, Recht A, et al. Image-detected breast cancer: state of the art diagnosis and treatment. J Am Coll Surg. 2005;201(4):586-97. [pmid: 16183499].
56 American Cancer Society. Breast Cancer: Early Detection. Available at: http://www.cancer.org/cancer/breastcancer/moreinformation/breastcancerearlydetection/breast-cancer-early-detection-toc. June 3, 2014.
57 American Academy of Family Physicians. Updated AAFP Breast Cancer Screening Recommendations Stress Communication. Available at: http://www.aafp.org/online/en/home/publications/news/news-now/clinical-care-research/20100115aafp-brca-recs.html. June 4, 2013.
58 American Congress of Obstetricians and Gynecologists. Breast Cancer Screening. Obstet Gynecol. 2011;118(2 Pt 1):372-82. [pmid: 21775869].
59 American College of Radiology. ACR Practice Guideline for the Performance of Screening and Diagnostic Mammography. 2008. Available at: http://www.acr.org/˜/media/ACR/Documents/PGTS/guidelines/Screening_Mammography.pdf. September 19, 2014.
60 NCCN. NCCN Clinical Practice Guidelines in Oncology: Breast Cancer Screening and Diagnosis. Fort Washington, PA. 2014. Available at: http://www.nccn.org/professionals/physician_gls/f_guidelines.asp. September 18, 2014.
61 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
62 U.S. Preventive Services Task Force. Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. 2011. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. September 18, 2014.
63 National Cancer Institute. Breast Cancer Surveillance Consortium: Evaluating Screening Performance in Practice. NIH Publication No. 04-5490. Bethesda, MD. National Cancer Institute, National Institutes of Health, U.S. Department of Health and Human Services. April. 2004. Available at: http://breastscreening.cancer.gov/espp.pdf. September 19, 2014.
64 Ballard-Barbash R, Taplin SH, Yankaskas BC, et al. Breast Cancer Surveillance Consortium: a national mammography screening and outcomes database. AJR Am J Roentgenol. 1997;169(4):1001-8. [pmid: 9308451].
65 Autier P, Hery C, Haukka J, et al. Advanced breast cancer and breast cancer mortality in randomized controlled trials on mammography screening. J Clin Oncol. 2009;27(35):5919-23. [pmid: 19884547].
66 van Ravesteyn NT, Miglioretti DL, Stout NK, et al. Tipping the balance of benefits and harms to favor screening mammography starting at age 40 years: a comparative modeling study of risk. Ann Intern Med. 2012;156(9):609-17. [pmid: 22547470].
67 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996;15(6):619-29. [pmid: 8731004].
68 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
69 Miller AB, Wall C, Baines CJ, et al. Twenty five year follow-up for breast cancer incidence and mortality of the Canadian National Breast Screening Study: randomised screening trial. BMJ. 2014;348:g366. [pmid: 24519768].
70 Tabár L, Vitak B, Chen TH-H, et al. Swedish two-county trial: impact of mammographic screening on breast cancer mortality during 3 decades. Radiology. 2011;260(3):658-63. [pmid: 21712474].
71 D'Orsi CJ, Bassett LW, Berg WA. Follow-up and outcome monitoring. In: Breast imaging reporting and data system: ACR BIRADS. 4th ed. Reston, VA. American College of Radiology. 2003:229-51.
72 BCSC Glossary of Terms. Available at: http://breastscreening.cancer.gov/data/bcsc_data_definitions.pdf. October 27, 2014.
73 Rosenberg RD, Yankaskas BC, Abraham LA, et al. Performance benchmarks for screening mammography. Radiology. 2006;241(1):55-66. [pmid: 16990671].
74 Shapiro S, Venet W, Strax P, et al. Ten- to fourteen-year effect of screening on breast cancer mortality. J Natl Cancer Inst. 1982;69(2):349-55. [pmid: 6955542].
75 Miller AB, Baines CJ, To T, et al. Canadian National Breast Screening Study: 1. Breast cancer detection and death rates among women aged 40 to 49 years. CMAJ. 1992;147(10):1459-76. [pmid: 1423087].
76 Miller AB, To T, Baines CJ, et al. The Canadian National Breast Screening Study-1: breast cancer mortality after 11 to 16 years of follow-up. A randomized screening trial of mammography in women age 40 to 49 years. Ann Intern Med. 2002;137(5 Part 1):305-12. [pmid: 12204013].
77 Miller AB, Baines CJ, To T, et al. Canadian National Breast Screening Study: 2. Breast cancer detection and death rates among women aged 50 to 59 years. CMAJ. 1992;147(10):1477-88. [pmid: 1423088].
78 Miller AB, To T, Baines CJ, et al. Canadian National Breast Screening Study-2: 13-year results of a randomized trial in women aged 50-59 years. J Natl Cancer Inst. 2000;92(18):1490-9. [pmid: 10995804].
79 Moss SM, Cuckle H, Evans A, et al. Effect of mammographic screening from age 40 years on breast cancer mortality at 10 years' follow-up: a randomised controlled trial. Lancet. 2006;368(9552):2053-60. [pmid: 17161727].
80 Frisell J, Lidbrink E, Hellstrom L, et al. Followup after 11 years--update of mortality results in the Stockholm mammographic screening trial. Breast Cancer Res Treat. 1997;45(3):263-70. [pmid: 9386870].
81 Andersson I, Aspegren K, Janzon L, et al. Mammographic screening and mortality from breast cancer: the Malmö mammographic screening trial. BMJ. 1988;297(6654):943-8. [pmid: 3142562].
82 Bjurstam N, Bjorneld L, Warwick J, et al. The Gothenburg Breast Screening Trial. Cancer. 2003;97(10):2387-96. [pmid: 12733136].
83 Tabár L, Fagerberg G, Chen HH, et al. Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer. 1995;75(10):2507-17. [pmid: 7736395].
84 Alexander FE, Anderson TJ, Brown HK, et al. 14 years of follow-up from the Edinburgh randomised trial of breast-cancer screening. Lancet. 1999;353(9168):1903-8. [pmid: 10371567].
85 Roberts MM, Alexander FE, Anderson TJ, et al. Edinburgh trial of screening for breast cancer: mortality at seven years. Lancet. 1990;335(8684):241-6. [pmid: 1967717].
86 Moss S, Johns L, Cuckle H, et al. Randomised controlled trial of mammographic screening in young women: updated results on incidence and mortality. NCRI Cancer Conference Abstracts. Available at: http://conference.ncri.org.uk/abstracts/2009/abstracts/B35.htm. September 18, 2014.
87 Nyström L, Andersson I, Bjurstam N, et al. Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet. 2002;359(9310):909-19. [pmid: 11918907].
88 Nyström L, Rutqvist LE, Wall S, et al. Breast cancer screening with mammography: overview of Swedish randomised trials. Lancet. 1993;341(8851):973-8. [pmid: 8096941].
89 Lidbrink E, Frisell J, Brandberg Y, et al. Nonattendance in the Stockholm mammography screening trial: Relative Mortality and reasons for nonattendance. Breast Cancer Res Treat. 1995;35(3):267-75. [pmid: 7579497].
90 Shapiro S, Venet W, Strax P, et al. Current results of the breast cancer screening randomized trial: the health insurance plan (HIP) of greater New York study. Screening for Breast Cancer Toronto: Hans Huber. 1988:3-15.
91 Schonberg MA, Silliman RA, Marcantonio ER. Weighing the benefits and burdens of mammography screening among women age 80 years or older. J Clin Oncol. 2009;27(11):1774-80. [pmid: 19255318].
92 Humphrey L, Chan BKS, Detlefsen S, et al. Screening for Breast Cancer. Systematic Evidence Reviews No. 15. Rockville (MD). Agency for Healthcare Research and Quality (US). 2002. Available at: http://www.ncbi.nlm.nih.gov/books/NBK42742/. September 19, 2014. [pmid: 20722110].
93 Humphrey LL, Helfand M, Chan BKS, et al. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. [Summary for patients in Ann Intern Med. 2002 Sep 3;137(5 Part 1):I47; PMID: 12204048]. Ann Intern Med. 2002;137(5 Part 1):347-60. [pmid: 12204020].
94 Nelson HD, Tyne K, Naik A, et al. Screening for Breast Cancer: Systematic Evidence Review Update for the US Preventive Services Task Force. AHRQ Report No.:10-05142-EF-1. Rockville (MD). 2009. Available at: http://www.ncbi.nlm.nih.gov/pubmed/20722173. September 19, 2014. [pmid: 20722173].
95 Habbema JD, van Oortmarssen GJ, van Putten DJ, et al. Age-specific reduction in breast cancer mortality by screening: an analysis of the results of the Health Insurance Plan of Greater New York study. J Natl Cancer Inst. 1986;77(2):317-20. [pmid: 3461193].
96 Njor S, Nyström L, Moss S, et al. Breast cancer mortality in mammographic screening in Europe: a review of incidence-based mortality studies. J Med Screen. Suppl 1. 2012;19:33-41. [pmid: 22972809].
97 Moss SM, Nyström L, Jonsson H, et al. The impact of mammographic screening on breast cancer mortality in Europe: a review of trend studies. J Med Screen. Suppl 1. 2012;19:26-32. [pmid: 22972808].
98 Broeders M, Moss S, Nyström L, et al. The impact of mammographic screening on breast cancer mortality in Europe: a review of observational studies. J Med Screen. Suppl 1. 2012;19:14-25. [pmid: 22972807].
99 Harris R, Yeatts J, Kinsinger L. Breast cancer screening for women ages 50 to 69 years a systematic review of observational evidence. Prev Med. 2011;53(3):108-14. [pmid: 21820465].
100 Jørgensen KJ, Zahl PH, Gøtzsche PC. Breast cancer mortality in organised mammography screening in Denmark: comparative study. BMJ. 2010;340:c1241. [pmid: 20332505].
101 Otto SJ, Fracheboud J, Looman CWN, et al. Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: a systematic review. Lancet. 2003;361(9367):1411-7. [pmid: 12727393].
102 Otten JDM, Broeders MJM, Fracheboud J, et al. Impressive time-related influence of the Dutch screening programme on breast cancer incidence and mortality, 1975-2006. Int J Cancer. 2008;123(8):1929-34. [pmid: 18688863].
103 Pons-Vigués M, Puigpinós R, Cano-Serral G, et al. Breast cancer mortality in Barcelona following implementation of a city breast cancer-screening program. Cancer Detect Prev. 2008;32(2):162-7. [pmid: 18639990].
104 Cabanes A, Vidal E, Pérez-Gómez B, et al. Age-specific breast, uterine and ovarian cancer mortality trends in Spain: changes from 1980 to 2006. Cancer epidemiol. 2009;33(3-4):169-75. [pmid: 19766076].
105 Barchielli A, Paci E. Trends in breast cancer mortality, incidence, and survival, and mammographic screening in Tuscany, Italy. Cancer Causes Control. 2001;12(3):249-55. [pmid: 11405330].
106 Gorini G, Zappa M, Miccinesi G, et al. Breast cancer mortality trends in two areas of the province of Florence, Italy, where screening programmes started in the 1970s and 1990s. Br J Cancer. 2004;90(9):1780-3. [pmid: 15150601].
107 Ascunce EN, Moreno-Iribas C, Barcos Urtiaga A, et al. Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 2007;14(1):14-20. [pmid: 17362566].
108 Haukka J, Byrnes G, Boniol M, et al. Trends in breast cancer mortality in Sweden before and after implementation of mammography screening. PLoS ONE. 2011;6(9):e22422. [pmid: 21966354].
109 Blanks RG, Moss SM, McGahan CE, et al. Effect of NHS breast screening programme on mortality from breast cancer in England and Wales, 1990-8: comparison of observed with predicted mortality. BMJ. 2000;321(7262):665-9. [pmid: 10987769].
110 Duffy SW, Tabár L, Olsen AH, et al. Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J Med Screen. 2010;17(1):25-30. [pmid: 20356942].
111 Autier P, Boniol M, Gavin A, et al. Breast cancer mortality in neighbouring European countries with different levels of screening but similar access to treatment: trend analysis of WHO mortality database. BMJ. 2011;343:d4411. [pmid: 21798968].
112 Hakama M, Pukkala E, Heikkila M, et al. Effectiveness of the public health policy for breast cancer screening in Finland: population based cohort study. BMJ. 1997;314(7084):864-7. [pmid: 9093096].
113 Olsen AH, Njor SH, Vejborg I, et al. Breast cancer mortality in Copenhagen after introduction of mammography screening: cohort study. BMJ. 2005;330(7485):220. [pmid: 15649904].
114 Sarkeala T, Heinavaara S, Anttila A. Breast cancer mortality with varying invitational policies in organised mammography. Br J Cancer. 2008;98(3):641-5. [pmid: 18231108].
115 Paci E, Giorgi D, Bianchi S, et al. Assessment of the early impact of the population-based breast cancer screening programme in Florence (Italy) using mortality and surrogate measures. Eur J Cancer. 2002;38(4):568-73. [pmid: 11872351].
116 Swedish Organised Service Screening Evaluation Group. Reduction in breast cancer mortality from organized service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiol Biomarkers Prev. 2006;15(1):45-51. [pmid: 16434585].
117 Gabe R, Tryggvadottir L, Sigfusson BF, et al. A case-control study to estimate the impact of the Icelandic population-based mammography screening program on breast cancer death. Acta Radiol. 2007;48(9):948-55. [pmid: 18080359].
118 Puliti D, Miccinesi G, Collina N, et al. Effectiveness of service screening: a case-control study to assess breast cancer mortality reduction. [Erratum appears in Br J Cancer. 2008 Nov 18;99(10):1756]. Br J Cancer. 2008;99(3):423-7. [pmid: 18665188].
119 Otto SJ, Fracheboud J, Verbeek ALM, et al. Mammography screening and risk of breast cancer death: a population-based case-control study. Cancer Epidemiol Biomarkers Prev. 2012;21(1):66-73. [pmid: 22147362].
120 van Schoor G, Moss SM, Otten JDM, et al. Increasingly strong reduction in breast cancer mortality due to screening. Br J Cancer. 2011;104(6):910-4. [pmid: 21343930].
121 Allgood PC, Warwick J, Warren RML, et al. A case-control study of the impact of the East Anglian breast screening programme on breast cancer mortality. Br J Cancer. 2008;98(1):206-9. [pmid: 18059396].
122 Fielder HM, Warwick J, Brook D, et al. A case-control study to estimate the impact on breast cancer death of the breast screening programme in Wales. J Med Screen. 2004;11(4):194-8. [pmid: 15563774].
123 Hellquist BN, Duffy SW, Abdsaleh S, et al. Effectiveness of population-based service screening with mammography for women ages 40 to 49 years: evaluation of the Swedish Mammography Screening in Young Women (SCRY) cohort. Cancer. 2011;117(4):714-22. [pmid: 20882563].
124 Coldman A, Phillips N, Wilson C, et al. Pan-Canadian study of mammography screening and mortality from breast cancer. J Natl Cancer Inst. 2014;106(11). [pmid: 25274578].
125 Hofvind S, Skaane P. Stage distribution of breast cancer diagnosed before and after implementation of population-based mammographic screening. Fortschr Geb Rontgenstr Nuklearmed. 2012;184(5):437-42. [pmid: 22426937].
126 Hofvind S, Ursin G, Tretli S, et al. Breast cancer mortality in participants of the Norwegian Breast Cancer Screening Program. Cancer. 2013;119(17):3106-12. [pmid: 23720226].
127 Mook S, Van 't Veer LJ, Rutgers EJ, et al. Independent prognostic value of screen detection in invasive breast cancer. J Natl Cancer Inst. 2011;103(7):585-97. [pmid: 21350218].
128 Aron JL, Prorok PC. An analysis of the mortality effect in a breast cancer screening study. Int J Epidemiol. 1986;15(1):36-43. [pmid: 3957541].
129 Coldman AJ, Phillips N, Olivotto IA, et al. Impact of changing from annual to biennial mammographic screening on breast cancer outcomes in women aged 50-79 in British Columbia. J Med Screen. 2008;15(4):182-7. [pmid: 19106258].
130 Parvinen I, Chiu S, Pylkkanen L, et al. Effects of annual vs triennial mammography interval on breast cancer incidence and mortality in ages 40-49 in Finland. Br J Cancer. 2011;105(9):1388-91. [pmid: 21934688].
131 Chu KC, Smart CR, Tarone RE. Analysis of breast cancer mortality and stage distribution by age for the Health Insurance Plan clinical trial. J Natl Cancer Inst. 1988;80(14):1125-32. [pmid: 3411625].
132 Duffy SW, Tabár L, Vitak B, et al. The Swedish Two-County Trial of mammographic screening: cluster randomisation and end point evaluation. Ann Oncol. 2003;14(8):1196-8. [pmid: 12881376].
133 Moss S, Thomas I, Evans A, et al. Randomised controlled trial of mammographic screening in women from age 40: results of screening in the first 10 years. Br J Cancer. 2005;92(5):949-54. [pmid: 15726102].
134 Breaset Screening Frequency Trial Group, Blamey RW, Day NE, et al. The frequency of breast cancer screening: Results from the UKCCCR Randomised Trial. Eur J Cancer. 2002;38(11):1458-64. [pmid: 12110490].
135 Buseman S, Mouchawar J, Calonge N, et al. Mammography screening matters for young women with breast carcinoma: evidence of downstaging among 42-49-year-old women with a history of previous mammography screening. Cancer. 2003;97(2):352-8. [pmid: 12518359].
136 Garcia Fernández A, Chabrera C, Garcia Font M, et al. Mortality and recurrence patterns of breast cancer patients diagnosed under a screening programme versus comparable non-screened breast cancer patients from the same population: analytical survey from 2002 to 2012. Tumour Biol. 2014;35(3):1945-53. [pmid: 24114015].
137 Jensen AR, Garne JP, Storm HH, et al. Stage and survival in breast cancer patients in screened and non-screened Danish and Swedish populations. Acta Oncol. 2003;42(7):701-9. [pmid: 14690155].
138 Olivotto IA, Mates D, Kan L, et al. Prognosis, treatment, and recurrence of breast cancer for women attending or not attending the Screening Mammography Program of British Columbia. Breast Cancer Res Treat. 1999;54(1):73-81. [pmid: 10369083].
139 Olsson A, Garne JP, Tengrup I, et al. Overweight in relation to tumour size and axillary lymph node involvement in postmenopausal breast cancer patients-differences between women invited to vs. not invited to mammography in a randomized screening trial. Cancer epidemiol. 2009;33(1):9-15. [pmid: 19679041].
140 Gotzsche PC, Jorgensen KJ. Screening for breast cancer with mammography. Cochrane Database Syst Rev. 2013;6. [pmid: 23737396].
141 Dittus K, Geller B, Weaver DL, et al. Impact of mammography screening interval on breast cancer diagnosis by menopausal status and BMI. J Gen Intern Med. 2013;28(11):1454-62. [pmid: 23760741].
142 Goel A, Littenberg B, Burack RC. The association between the pre-diagnosis mammography screening interval and advanced breast cancer. Breast Cancer Res Treat. 2007;102(3):339-45. [pmid: 16927175].
143 Hubbard RA, Kerlikowske K, Flowers CI, et al. Cumulative probability of false-positive recall or biopsy recommendation after 10 years of screening mammography: a cohort study. [Summary for patients in Ann Intern Med. 2011 Oct 18;155(8):I14; PMID: 22007059]. Ann Intern Med. 2011;155(8):481-92. [pmid: 22007042].
144 Kerlikowske K, Zhu W, Hubbard RA, et al. Outcomes of screening mammography by frequency, breast density, and postmenopausal hormone therapy. JAMA Intern Med. 2013;173(9):807-16. [pmid: 23552817].
145 White E, Miglioretti DL, Yankaskas BC, et al. Biennial versus annual mammography and the risk of late-stage breast cancer. J Natl Cancer Inst. 2004;96(24):1832-9. [pmid: 15601639].
146 Rose SL, Tidwell AL, Bujnoch LJ, et al. Implementation of breast tomosynthesis in a routine screening practice: an observational study. AJR Am J Roentgenol. 2013;200(6):1401-8. [pmid: 23701081].
147 Skaane P, Bandos AI, Gullien R, et al. Comparison of digital mammography alone and digital mammography plus tomosynthesis in a population-based screening program. Radiology. 2013;267(1):47-56. [pmid: 23297332].
148 Hofvind S, Wang H, Thoresen S. Do the results of the process indicators in the Norwegian Breast Cancer Screening Program predict future mortality reduction from breast cancer?. Acta Oncol. 2004;43(5):467-73. [pmid: 15360051].
149 Elmore JG, Barton MB, Moceri VM, et al. Ten-year risk of false positive screening mammograms and clinical breast examinations. N Engl J Med. 1998;338(16):1089-96. [pmid: 9545356].
150 Olivotto IA, Kan L, Coldman AJ. False positive rate of screening mammography. N Engl J Med. 1998;339:560. [pmid: 9714619].
151 Yankaskas BC, Taplin SH, Ichikawa L, et al. Association between mammography timing and measures of screening performance in the United States. Radiology. 2005;234(2):363-73. [pmid: 15670994].
152 Moss S. Overdiagnosis and overtreatment of breast cancer: overdiagnosis in randomised controlled trials of breast cancer screening. Breast Cancer Res. 2005;7(5):230-4. [pmid: 16168145].
153 Paci E, Miccinesi G, Puliti D, et al. Estimate of overdiagnosis of breast cancer due to mammography after adjustment for lead time. A service screening study in Italy. Breast Cancer Res. 2006;8(6):R68. [pmid: 17147789].
154 Paci E, Warwick J, Falini P, et al. Overdiagnosis in screening: is the increase in breast cancer incidence rates a cause for concern?. J Med Screen. 2004;11(1):23-7. [pmid: 15006110].
155 de Koning HJ, Draisma G, Fracheboud J, et al. Overdiagnosis and overtreatment of breast cancer: microsimulation modelling estimates based on observed screen and clinical data. Breast Cancer Res. 2006;8(1):202. [pmid: 16524452].
156 Olsen AH, Agbaje OF, Myles JP, et al. Overdiagnosis, sojourn time, and sensitivity in the Copenhagen mammography screening program. Breast J. 2006;12(4):338-42. [pmid: 16848843].
157 Duffy SW, Agbaje O, Tabár L, et al. Overdiagnosis and overtreatment of breast cancer: estimates of overdiagnosis from two trials of mammographic screening for breast cancer. Breast Cancer Res. 2005;7(6):258-65. [pmid: 16457701].
158 Yen MF, Tabár L, Vitak B, et al. Quantifying the potential problem of overdiagnosis of ductal carcinoma in situ in breast cancer screening. Eur J Cancer. 1990). 2003;39(12):1746-54. [pmid: 12888370].
159 Zackrisson S, Andersson I, Janzon L, et al. Rate of over-diagnosis of breast cancer 15 years after end of Malmö mammographic screening trial: follow-up study. BMJ. 2006;332(7543):689-92. [pmid: 16517548].
160 Zahl PH. Overdiagnosis of breast cancer in Denmark. Br J Cancer. 2004;90(8):1686. author reply 7. [pmid: 15083204].
161 Puliti D, Duffy SW, Miccinesi G, et al. Overdiagnosis in mammographic screening for breast cancer in Europe: a literature review. J Med Screen. Suppl 1. 2012;19:42-56. [pmid: 22972810].
162 Etzioni R, Gulati R, Mallinger L, et al. Influence of study features and methods on overdiagnosis estimates in breast and prostate cancer screening. Ann Intern Med. 2013;158(11):831-8. [pmid: 23732716].
163 Marmot M, Altman D, Cameron D, et al. The benefits and harms of breast cancer screening: an independent review. Br J Cancer. 2013;108(11):2205-40. [pmid: 23744281].
164 Independent UKPoBCS. The benefits and harms of breast cancer screening: an independent review. Lancet. 2012;380(9855):1778-86. [pmid: 23117178].
165 Bleyer A, Welch HG. Effect of three decades of screening mammography on breast-cancer incidence. N Engl J Med. 2012;367(21):1998-2005. [pmid: 23171096].
166 Coldman A, Phillips N. Incidence of breast cancer and estimates of overdiagnosis after the initiation of a population-based mammography screening program. CMAJ. 2013;185(10):E492-8. [pmid: 23754101].
167 de Gelder R, Fracheboud J, Heijnsdijk EAM, et al. Digital mammography screening: weighing reduced mortality against increased overdiagnosis. Prev Med. 2011;53(3):134-40. [pmid: 21718717].
168 de Gelder R, Heijnsdijk EAM, van Ravesteyn NT, et al. Interpreting overdiagnosis estimates in population-based mammography screening. Epidemiol Rev. 2011;33(1):111-21. [pmid: 21709144].
169 Falk RS, Hofvind S, Skaane P, et al. Overdiagnosis among women attending a population-based mammography screening program. Int J Cancer. 2013;133(3):705-12. [pmid: 23355313].
170 Hellquist BN, Duffy SW, Nyström L, et al. Overdiagnosis in the population-based service screening programme with mammography for women aged 40 to 49 years in Sweden. J Med Screen. 2012;19(1):14-9. [pmid: 22355181].
171 Jorgensen KJ, Zahl P-H, Gotzsche PC. Overdiagnosis in organised mammography screening in Denmark. A comparative study. BMC Womens Health. 2009;9:36. [pmid: 20028513].
172 Kalager M, Adami H-O, Bretthauer M, et al. Overdiagnosis of invasive breast cancer due to mammography screening: results from the Norwegian screening program. [Summary for patients in Ann Intern Med. 2012 Apr 3;156(7):I58; PMID: 22473444]. Ann Intern Med. 2012;156(7):491-9. [pmid: 22473436].
173 Martinez-Alonso M, Vilaprinyo E, Marcos-Gragera R, et al. Breast cancer incidence and overdiagnosis in Catalonia (Spain). Breast Cancer Res. 2010;12(4):R58. [pmid: 20682042].
174 Morrell S, Barratt A, Irwig L, et al. Estimates of overdiagnosis of invasive breast cancer associated with screening mammography. Cancer Causes Control. 2010;21(2):275-82. [pmid: 19894130].
175 Njor SH, Olsen AH, Blichert-Toft M, et al. Overdiagnosis in screening mammography in Denmark: population based cohort study. BMJ. 2013;346:f1064. [pmid: 23444414].
176 Puliti D, Zappa M, Miccinesi G, et al. An estimate of overdiagnosis 15 years after the start of mammographic screening in Florence. Eur J Cancer. 2009;45(18):3166-71. [pmid: 19879130].
177 Seigneurin A, Francois O, Labarere J, et al. Overdiagnosis from non-progressive cancer detected by screening mammography: stochastic simulation study with calibration to population based registry data. BMJ. 2011;343:d7017. [pmid: 22113564].
178 Yen AM-F, Duffy SW, Chen TH-H, et al. Long-term incidence of breast cancer by trial arm in one county of the Swedish Two-County Trial of mammographic screening. Cancer. 2012;118(23):5728-32. [pmid: 22605639].
179 Zahl P-H, Maehlen J. Overdiagnosis of breast cancer after 14 years of mammography screening. Tidsskr Nor Laegeforen. 2012;132(4):414-7. [pmid: 22353833].
180 Gunsoy NB, Garcia-Closas M, Moss SM. Estimating breast cancer mortality reduction and overdiagnosis due to screening for different strategies in the United Kingdom. Br J Cancer. 2014;110(10):2412-9. [pmid: 24762956].
181 Duffy SW, Lynge E, Jonsson H, et al. Complexities in the estimation of overdiagnosis in breast cancer screening. Br J Cancer. 2008;99(7):1176-8. [pmid: 18766185].
182 Biesheuvel C, Barratt A, Howard K, et al. Effects of study methods and biases on estimates of invasive breast cancer overdetection with mammography screening: a systematic review. Lancet Oncol. 2007;8(12):1129-38. [pmid: 18054882].
183 Brett J, Bankhead C, Henderson B, et al. The psychological impact of mammographic screening. A systematic review. Psychooncology. 2005;14(11):917-38. [pmid: 15786514].
184 Brewer NT, Salz T, Lillie SE. Systematic review: the long-term effects of false-positive mammograms. Ann Intern Med. 2007;146(7):502-10. [pmid: 17404352].
185 Bond M, Pavey T, Welch K, et al. Psychological consequences of false-positive screening mammograms in the UK. Evid Based Med. 2013;18(2):54-61. [pmid: 22859786].
186 Brett J, Austoker J. Women who are recalled for further investigation for breast screening: Psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 2001;23(4):292-300. [pmid: 11873891].
187 Ong G, Austoker J, Brett J. Breast screening: adverse psychological consequences one month after placing women on early recall because of a diagnostic uncertainty. A multicentre study. J Med Screen. 1997;4(3):158-68. [pmid: 9368874].
188 Bull AR, Campbell MJ. Assessment of the psychological impact of a breast screening programme. Br J Radiol. 1991;64(762):510-5. [pmid: 2070180].
189 Ellman R, Angeli N, Christians A, et al. Psychiatric morbidity associated with screening for breast cancer. Br J Cancer. 1989;60(5):781-4. [pmid: 2803955].
190 McCann J, Stockton D, Godward S. Impact of false-positive mammography on subsequent screening attendance and risk of cancer. Breast Cancer Res. 2002;4(5):R11. [pmid: 12223128].
191 O'Sullivan I, Sutton S, Dixon S, et al. False positive results do not have a negative effect on reattendance for subsequent breast screening. J Med Screen. 2001;8(3):145-8. [pmid: 11678554].
192 Orton M, Fitzpatrick R, Fuller A, et al. Factors affecting women's response to an invitation to attend for a second breast cancer screening examination. Br J Gen Pract. 1991;41(349):320-2. [pmid: 1777275].
193 Meldrum P, Turnbull D, Dobson HM, et al. Tailored written invitations for second round breast cancer screening: a randomised controlled trial. J Med Screen. 1994;1(4):245-8. [pmid: 8790529].
194 Hafslund B, Nortvedt MW. Mammography screening from the perspective of quality of life: a review of the literature. Scand J Caring Sci. 2009;23(3):539-48. [pmid: 19170959].
195 Lowe JB, Balanda KP, Del Mar C, et al. Psychologic distress in women with abnormal findings in mass mammography screening. Cancer. 1999;85(5):1114-8. [pmid: 10091796].
196 Hislop TG, Harris SR, Jackson J, et al. Satisfaction and anxiety for women during investigation of an abnormal screening mammogram. Breast Cancer Res Treat. 2002;76(3):245-54. [pmid: 12462385].
197 Lampic C, Thurfjell E, Sjödén PO. The influence of a false-positive mammogram on a woman's subsequent behaviour for detecting breast cancer. Eur J Cancer. 2003;39(12):1730-7. [pmid: 12888368].
198 Gibson CJ, Weiss J, Goodrich M, et al. False-positive mammography and depressed mood in a screening population: findings from the New Hampshire Mammography Network. J Public Health (Oxf). 2009;31(4):554-60. [pmid: 19574274].
199 Keyzer-Dekker CMG, De Vries J, van Esch L, et al. Anxiety after an abnormal screening mammogram is a serious problem. Breast. 2012;21(1):83-8. [pmid: 21924905].
200 Fitzpatrick P, Fleming P, O'Neill S, et al. False-positive mammographic screening: factors influencing re-attendance over a decade of screening. J Med Screen. 2011;18(1):30-3. [pmid: 21536814].
201 Maxwell AJ, Beattie C, Lavelle J, et al. The effect of false positive breast screening examinations on subsequent attendance: retrospective cohort study. J Med Screen. 2013;20(2):91-8. [pmid: 24009091].
202 Klompenhouwer E, Duijm LM, Voogd A, et al. Re-attendance at biennial screening mammography following a repeated false positive recall. Breast Cancer Res Treat. 2014;145(2):429-37. [pmid: 24748569].
203 Brodersen J, Siersma VD. Long-term psychosocial consequences of false-positive screening mammography. Ann Fam Med. 2013;11(2):106-15. [pmid: 23508596].
204 Tosteson AN, Fryback DG, Hammond CS, et al. Consequences of False-Positive Screening Mammograms. JAMA Intern Med. 2014. [pmid: 24756610].
205 Hafslund B, Espehaug B, Nortvedt MW. Effects of false-positive results in a breast screening program on anxiety, depression and health-related quality of life. Cancer Nurs. 2012;35(5):E26-34. [pmid: 22067696].
206 Espasa R, Murta-Nascimento C, Bayes R, et al. The psychological impact of a false-positive screening mammogram in Barcelona. J Cancer Educ. 2012;27(4):780-5. [pmid: 22477233].
207 Schou Bredal I, Karesen R, Skaane P, et al. Recall mammography and psychological distress. Eur J Cancer. 2013;49(4):805-11. [pmid: 23021930].
208 Hendrick RE. Radiation doses and cancer risks from breast imaging studies. Radiology. 2010;257(1):246-53. [pmid: 20736332].
209 Yaffe MJ, Mainprize JG. Risk of radiation-induced breast cancer from mammographic screening. [Erratum appears in Radiology. 2012 Jul;264(1):306]. Radiology. 2011;258(1):98-105. [pmid: 21081671].
210 Miller D, Livingstone V, Herbison P. Interventions for relieving the pain and discomfort of screening mammography. Cochrane Database Syst Rev. 2008;(1). CD002942. [pmid: 18254010].
211 Whelehan P, Evans A, Wells M, et al. The effect of mammography pain on repeat participation in breast cancer screening: a systematic review. Breast. 2013;22(4):389-94. [pmid: 23541681].
212 Friedewald SM, Rafferty EA, Rose SL, et al. Breast cancer screening using tomosynthesis in combination with digital mammography. JAMA. 2014;311(24):2499-507. [pmid: 25058084].
213 Ciatto S, Houssami N, Bernardi D, et al. Integration of 3D digital mammography with tomosynthesis for population breast-cancer screening (STORM): a prospective comparison study. Lancet Oncol. 2013;14(7):583-9. [pmid: 23623721].
214 Haas BM, Kalra V, Geisel J, et al. Comparison of tomosynthesis plus digital mammography and digital mammography alone for breast cancer screening. Radiology. 2013;269(3):694-700. [pmid: 23901124].
215 Chiarelli AM, Majpruz V, Brown P, et al. The contribution of clinical breast examination to the accuracy of breast screening. J Natl Cancer Inst. 2009;101(18):1236-43. [pmid: 19720967].
216 Ava Kwong, Michael Sable. Mastectomy: Indications, types, and concurrent axillary lymph node management. Available at: http://www.uptodate.com/contents/mastectomy-indications-types-and-concurrent-axillary-lymph-node-management?source=see_link&anchor=H374254849#H37425484. September 18, 2014.
217 Haviland JS, Owen JR, Dewar JA, et al. The UK Standardisation of Breast Radiotherapy (START) trials of radiotherapy hypofractionation for treatment of early breast cancer: 10-year follow-up results of two randomised controlled trials. Lancet Oncol. 2013;14(11):1086-94. [pmid: 24055415].
218 Fisher B, Dignam J, Bryant J, et al. Five versus more than five years of tamoxifen therapy for breast cancer patients with negative lymph nodes and estrogen receptor-positive tumors. J Natl Cancer Inst. 1996;88(21):1529-42. [pmid: 8901851].
219 Arimidex TAoiCTG, Forbes JF, Cuzick J, et al. Effect of anastrozole and tamoxifen as adjuvant treatment for early-stage breast cancer: 100-month analysis of the ATAC trial. Lancet Oncol. 2008;9(1):45-53. [pmid: 18083636].
220 Howlader N, Noone A, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2011. National Cancer Institute. Bethesda, MD. Based on November 2013 SEER data submission, posted to the SEER website. April. 2014. Available at: http://seer.cancer.gov/csr/1975_2011/. September 19, 2014.
221 Edwards AG, Naik G, Ahmed H, et al. Personalised risk communication for informed decision making about taking screening tests. Cochrane Database Syst Rev. 2013;2. CD001865. [pmid: 23450534].
222 Edgar L, Glackin M, Hughes C, et al. Factors influencing participation in breast cancer screening. Br J Nurs. 2013;22(17):1021-6. [pmid: 24067312].
223 Antill YC, Reynolds J, Young MA, et al. Screening behavior in women at increased familial risk for breast cancer. Fam Cancer. 2006;5(4):359-68. [pmid: 16817030].
224 Pfeffer N. Screening for breast cancer: candidacy and compliance. Soc Sci Med. 2004;58(1):151-60. [pmid: 14572928].
225 Azaiza F, Cohen M. Health beliefs and rates of breast cancer screening among Arab women. J Womens Health (Larchmt). 2006;15(5):520-30. [pmid: 16796479].
226 Sin C, Janjua A, Hedges A, et al. Breast cancer screening and treatment in England: the impact of ethnicity and age on access, experiences and outcomes. Ethn Inequal Health Soc Care. 2009;2(3):10-9.
227 Gregory-Mercado KY, Will J, True S, et al. A combined approach to women's health is associated with a greater likelihood of repeat mammography in a population of financially disadvantaged women. Prev Chronic Dis. 2007;4(4):A89. [pmid: 17875264].
228 Isaacs C, Peshkin BN, Schwartz M, et al. Breast and ovarian cancer screening practices in healthy women with a strong family history of breast or ovarian cancer. Breast Cancer Res Treat. 2002;71(2):103-12. [pmid: 11881908].
229 Litaker D, Tomolo A. Association of contextual factors and breast cancer screening: finding new targets to promote early detection. J Womens Health (Larchmt). 2007;16(1):36-45. [pmid: 17324095].
230 Swan J, Breen N, Coates RJ, et al. Progress in cancer screening practices in the United States: results from the 2000 National Health Interview Survey. Cancer. 2003;97(6):1528-40. [pmid: 12627518].
231 Ackerson K, Preston SD. A decision theory perspective on why women do or do not decide to have cancer screening: systematic review. J Adv Nurs. 2009;65(6):1130-40. [pmid: 19374678].
232 Chamot E, Charvet AI, Perneger TV. Predicting stages of adoption of mammography screening in a general population. Eur J Cancer. 2001;37(15):1869-77. [pmid: 11576843].
233 Gigerenzer G, Mata J, Frank R. Public knowledge of benefits of breast and prostate cancer screening in Europe. J Natl Cancer Inst. 2009;101(17):1216-20. [pmid: 19671770].
234 Tripathy D. Targeted therapies in breast cancer. Breast. 2005;11(Suppl 1):S30-S5.
235 Badgwell BD, Giordano SH, Duan ZZ, et al. Mammography before diagnosis among women age 80 years and older with breast cancer. J Clin Oncol. 2008;26(15):2482-8. [pmid: 18427152].
236 Galit W, Green MS, Lital K-B. Routine screening mammography in women older than 74 years: a review of the available data. Maturitas. 2007;57(2):109-19. [pmid: 17336004].
237 FDA. Mammography Quality Standards Act Regulations Sec. 900.12 Quality Standards. Available at: http://www.fda.gov/radiation-emittingproducts/mammographyqualitystandardsactandprogram/Regulations/ucm110906.htm#s90012. September 18, 2014.
238 FDA. MQSA National Statistics. Available at: http://www.fda.gov/Radiation-EmittingProducts/MammographyQualityStandardsActandProgram/facilityScorecard/ucm113858.htm. September 18, 2014.
239 Pisano ED, Gatsonis C, Hendrick E, et al. Diagnostic performance of digital versus film mammography for breast-cancer screening. [Erratum appears in N Engl J Med. 2006 Oct 26;355(17):1840]. N Engl J Med. 2005;353(17):1773-83. [pmid: 16169887].
240 ACR. American College of Radiology ACR Appropriateness Criteria: Breast Cancer Screening. Available at: http://www.acr.org/˜/media/ACR/Documents/AppCriteria/Diagnostic/BreastCancerScreening.pdf. September 18, 2014.
241 Bjurstam N, Bjorneld L, Duffy SW, et al. The Gothenburg Breast Cancer Screening Trial: preliminary results on breast cancer mortality for women aged 39-49. J Natl Cancer Inst. Monographs. 1997;(22):53-5. [pmid: 9709276].
242 Bjurstam N, Bjorneld L, Duffy SW, et al. The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39-49 years at randomization. Cancer. 1997;80(11):2091-9. [pmid: 9392331].
243 Frisell J, Eklund G, Hellström L, et al. Randomized study of mammography screening—preliminary report on mortality in the Stockholm trial. Breast Cancer Res Treat. 1991;18(1):49-56. [pmid: 1854979].
244 Andersson I, Janzon L. Reduced breast cancer mortality in women under age 50: updated results from the Malmö Mammographic Screening Program. J Natl Cancer Inst. Monographs. 1997;(22):63-7. [pmid: 9709278].
245 Andersson I, Janzon L, Sigfusson BF. Mammographic breast cancer screening - a randomized trial in Malmö, Sweden. Maturitas. 1985;7(1):21-9. [pmid: 2991708].
246 Tabár L, Chen HH, Fagerberg G, et al. Recent results from the Swedish Two-County Trial: the effects of age, histologic type, and mode of detection on the efficacy of breast cancer screening. J Natl Cancer Inst. Monographs. 1997;(22):43-7. [pmid: 9709274].
247 Tabár L, Vitak B, Chen HH, et al. The Swedish Two-County Trial twenty years later. Updated mortality results and new insights from long-term follow-up. Radiol Clin North Am. 2000;38(4):625-51. [pmid: 10943268].
248 Moss S, Waller M, Anderson TJ, et al. Randomised controlled trial of mammographic screening in women from age 40: predicted mortality based on surrogate outcome measures. Br J Cancer. 2005;92(5):955-60. [pmid: 15726103].
249 Lyman GH, Giuliano AE, Somerfield MR, et al. American Society of Clinical Oncology guideline recommendations for sentinel lymph node biopsy in early-stage breast cancer. J Clin Oncol. 2005;23(30):7703-20. [pmid: 16157938].
250 Krag DN, Anderson SJ, Julian TB, et al. Technical outcomes of sentinel-lymph-node resection and conventional axillary-lymph-node dissection in patients with clinically node-negative breast cancer: results from the NSABP B-32 randomised phase III trial. Lancet Oncol. 2007;8(10):881-8. [pmid: 17851130].
251 Wernicke AG, Shamis M, Sidhu KK, et al. Complication rates in patients with negative axillary nodes 10 years after local breast radiotherapy after either sentinel lymph node dissection or axillary clearance. Am J Clin Oncol. 2013;36(1):12-9. [pmid: 22134519].
252 McLaughlin SA, Wright MJ, Morris KT, et al. Prevalence of lymphedema in women with breast cancer 5 years after sentinel lymph node biopsy or axillary dissection: patient perceptions and precautionary behaviors. J Clin Oncol. 2008;26(32):5220-6. [pmid: 18838708].
253 Kaufman B, Mackey JR, Clemens MR, et al. Trastuzumab plus anastrozole versus anastrozole alone for the treatment of postmenopausal women with human epidermal growth factor receptor 2-positive, hormone receptor-positive metastatic breast cancer: results from the randomized phase III TAnDEM study. J Clin Oncol. 2009;27(33):5529-37. [pmid: 19786670].
254 Gnant M, Mlineritsch B, Schippinger W, et al. Endocrine therapy plus zoledronic acid in premenopausal breast cancer. N Engl J Med. 2009;360(7):679-91. [pmid: 19213681].
255 Breast International Group 1-98 Collaborative G, Thurlimann B, Keshaviah A, et al. A comparison of letrozole and tamoxifen in postmenopausal women with early breast cancer. N Engl J Med. 2005;353(26):2747-57. [pmid: 16382061].
256 Buzdar AU, Hortobagyi GN, Frye D, et al. Bioequivalence of 20-mg once-daily tamoxifen relative to 10-mg twice-daily tamoxifen regimens for breast cancer. J Clin Oncol. 1994;12(1):50-4. [pmid: 8270984].
257 van de Velde CJ, Rea D, Seynaeve C, et al. Adjuvant tamoxifen and exemestane in early breast cancer (TEAM): a randomised phase 3 trial. Lancet. 2011;377(9762):321-31. [pmid: 21247627].
258 Sparano JA, Wang M, Martino S, et al. Weekly paclitaxel in the adjuvant treatment of breast cancer. N Engl J Med. 2008;358(16):1663-71. [pmid: 18420499].
259 Jones SE, Savin MA, Holmes FA, et al. Phase III trial comparing doxorubicin plus cyclophosphamide with docetaxel plus cyclophosphamide as adjuvant therapy for operable breast cancer. J Clin Oncol. 2006;24(34):5381-7. [pmid: 17135639].
260 Slamon D, Eiermann W, Robert N, et al. Adjuvant Trastuzumab in HER2-Positive Breast Cancer. N Engl J Med. 2011;365(14):1273-83. [pmid: 21991949].
261 Schneeweiss A, Chia S, Hickish T, et al. Pertuzumab plus trastuzumab in combination with standard neoadjuvant anthracycline-containing and anthracycline-free chemotherapy regimens in patients with HER2-positive early breast cancer: a randomized phase II cardiac safety study (TRYPHAENA). Ann Oncol. 2013;24(9):2278-84. [pmid: 23704196].
262 Seidman AD, Berry D, Cirrincione C, et al. Randomized phase III trial of weekly compared with every-3-weeks paclitaxel for metastatic breast cancer, with trastuzumab for all HER-2 overexpressors and random assignment to trastuzumab or not in HER-2 nonoverexpressors: final results of Cancer and Leukemia Group B protocol 9840. J Clin Oncol. 2008;26(10):1642-9. [pmid: 18375893].
263 Piccart MJ, Klijn J, Paridaens R, et al. Corticosteroids significantly delay the onset of docetaxel-induced fluid retention: final results of a randomized study of the European Organization for Research and Treatment of Cancer Investigational Drug Branch for Breast Cancer. J Clin Oncol. 1997;15(9):3149-55. [pmid: 9294478].
264 Fumoleau P, Largillier R, Clippe C, et al. Multicentre, phase II study evaluating capecitabine monotherapy in patients with anthracycline- and taxane-pretreated metastatic breast cancer. Eur J Cancer. 2004;40(4):536-42. [pmid: 14962720].
265 Tabár L, Fagerberg G, Duffy SW, et al. The Swedish two county trial of mammographic screening for breast cancer: recent results and calculation of benefit. J Epidemiol Community Health. 1989;43(2):107-14. [pmid: 2512366].