# Discussion

## Summary of Review Findings

Table 28 summarizes the evidence reviewed for this update and Table 29 provides a concise summary of benefits and harms. Trials of mammography screening indicated reduced breast cancer mortality with screening for women age 39 to 69 years, although results for ages 39 to 49 and 50 to 59 years were of borderline statistical significance and varied depending on how cases were accrued in trials. The absolute breast cancer mortality reduction per 10,000 women screened for 10 years varied from 4 for age 39 to 49 years; 5 to 8 for age 50 to 59 years; and 12 to 21 for age 60 to 69 years. Estimates for age 70 to 74 years were limited by low numbers of events in trials that had smaller numbers of women in this age group. The meta-analysis results reflect updated data from the Canadian (CNBSS-1 and CNBSS-2), Swedish Two-County Study, and Age trials that were not available for the previous review, as well as previously published results from the Stockholm, Gothenburg, Malmö (MMST I and MMST II), and HIP trials. The meta-analyses used long and short case accrual methods in order to explore the methodological differences of the trials and interpret findings using both approaches.

Table 28 Summary of Evidence: Screening for Breast Cancer

Main findings from previous USPSTF reviews | Number/type of studies in update | | Overall quality* | Limitations | Consistency | Applicability | Summary of findings
Key Question 1 . What is the effectiveness of routine mammography screening in reducing breast cancer–specific and all–cause mortality, and how does it differ by age, risk factor, and screening interval?
Screening reduced breast cancer mortality in RCTs for women age 39-49 (RR 0.85; 95% CrI, 0.75 to 0.96; 8 trials); 50-59 (RR 0.86; 95% CrI, 0.75 to 0.99; 6 trials); and 60-69 (0.68; 95% CrI, 0.54 to 0.87; 2 trials); data were limited for 70-74. | 3 RCTs provided updated data in addition to 5 RCTs with older data; 65 observational studies (57 included in 4 systematic reviews + 8 additional studies) | | Fair | Trials have methodological limitations; observational studies use various methods that introduce potential bias. | Results are consistent across types of studies | Most studies were conducted in Europe. RCTs used outdated technologies and treatments have changed over time. | - Screening reduced breast cancer mortality in RCTs for women age 40-49 (RR 0.88; 95% CI, 0.73 to 1.003; 9 trials); 50-59 (RR 0.86; 95% CI, 0.68 to 0.97; 7 trials); 60-69 (RR 0.67; 95% CI, 0.54 to 0.83; 5 trials); data were limited for 70-74.; - Meta-analysis of observational studies indicated 25% to 38% reduction in breast cancer mortality with screening for age 50-59.; - Two observational studies of women in their 40s indicated 25% to 44% reduction in breast cancer mortality for screening participants versus nonparticipants.; - All-cause mortality was not reduced with screening.; - Results for risk factors and screening intervals were not available.
Key Question 2 . What is the effectiveness of routine mammography screening in reducing the incidence of advanced breast cancer and treatment-related morbidity, and how does it differ by age, risk factors, and screening interval?
Not included. | 3 RCTs of screening and cancer stage; 1 Cochrane review of 5 RCTs of screening and uptake of cancer treatment; 4 analyses of BCSC data; 8 observational studies | | Fair | Trials have methodological limitations; observational studies use various methods that introduce potential bias. | Results are consistent across types of studies. | Most studies were conducted in Europe. RCTs used outdated technologies and treatments have changed over time. | - Screening reduced cancer stage for age ≥50 (RR, 0.62; 95% CI, 0.46 to 0.83; 3 trials), but not for age 40-49.; - Women randomized to screening had more mastectomies, lumpectomies, and radiation therapy, and less hormone therapy than controls.; - Women age 40-49 with extremely dense breasts had increased risks for advanced stage cancer and large-size tumors with biennial compared with annual screening.
Key Question 3 . How does the effectiveness of routine breast cancer screening in reducing breast cancer–specific and all-cause mortality vary by different screening modality?
Not included. | No studies evaluated this question. | | NA | NA | NA | NA | RCTs of mammography with or without CBE do not compare relative mortality reduction across the different modalities.
Key Question 4 . How does the effectiveness of routine breast cancer screening in reducing the incidence of advanced breast cancer and treatment-related morbidity vary by different screening modality?
Not included. | 2 case-series studies | | Poor | No RCTs; comparability of groups not known. | Results are consistent. | High clinical relevance. | Tumor size, stage, and node status did not differ between women screened with tomosynthesis + digital mammography compared with those receiving mammography alone in 2 case-series studies.
Key Question 5 . What are the harms of routine mammography screening, and how do they differ by age, risk factor, and screening interval?
Analysis of BCSC data showed that younger women had more false-positives results; the cumulative risk for false-positive mammograms was 21% to 49% after 10 screens, and 56% for age 40-49; cumulative false-positive biopsy rate after 10 screens was 19%. Many women have anxiety and pain with mammography, but it is generally transient and not a deterrent. Estimates of overdiagnosis ranged from 0% to 50% in a review and 8 studies. | Analysis of BCSC data; 3 observational studies of cumulative false positive results; 4 systematic reviews and 10 studies of anxiety; 3 reviews of pain; 1 meta-analysis, 2 reviews, and 27 studies of overdiagnosis; 2 modeling studies of radiation exposure | | Poor (radiation) to good (false-positive results) | Limitations vary by outcome; lack of studies for some outcomes (radiation); methodological diversity of studies (overdiagnosis); lack of RCTs; comparability of groups vary in observational studies. | Consistent in general | High clinical relevance. | - Younger women and those with risk factors had more false-positives results, and recommendations for additional imaging and biopsies.; - 10-year cumulative rates of false-positive mammography and biopsy results were higher for annual than biennial screening (mammography 61% vs. 41% biopsy 7% vs. 5%); for women with heterogeneously dense or extremely dense breasts, women in their 40s, and those who used combination hormone therapy.; - Women with false-positive results were more distressed than women with negative results, and some women did not return for screening.; - Estimates of overdiagnosis based on trials ranged from 11% to 22% estimates from other studies ranged from 0% to 54%.; - Deaths due to radiation induced cancer from screening with digital mammography was estimated through modeling as between 2 to 11 per 100,000 depending on age at onset and screening intervals.
Key Question 6 . How do the harms of routine breast cancer screening vary by different screening modality?
Not included. | 6 observational studies | Poor | | No RCTs; single studies; comparability of groups not known. | Lack of studies to access consistency | High clinical relevance | Tomosynthesis with mammography reduced recalls, but increased biopsies.

Abbreviations: BCSC= Breast Cancer Surveillance Consortium; CBE=clinical breast exam; CI=confidence interval; CrI=credible interval; NA=not applicable; RCT=randomized controlled trial; RR=relative risk; U.S.=United States; USPSTF=United States Preventive Services Task Force

Table 29 Summary of Results: Benefits and Harms of Mammography Screening

Benefits of Mammography Screening

Age, years | Reduction in breast cancer deaths from RCTs; RR (95% CI)^*^ | Breast cancer deaths prevented per 10,000 over 10 years (95% CI)^*^ | Reduction in breast cancer deaths from observational studies; RR (95% CI) | Reduction in all-cause deaths from RCTs; RR (95% CI)^*^ | Reduction in advanced breast cancer from RCTs; RR (95% CI) | Reduction in treatment morbidity from RCTs; RR (95% CI)^†^
40-49 | 0.88 (0.73 to 1.003) 0.84 (0.70 to 1.002) | 4 (0 to 9) | 0.74 (0.66 to 0.83); 0.56 (0.45 to 0.67)^‡^ | 0.99 (0.94 to 1.06) | 0.98 (0.74 to 1.37) | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
50-59 | 0.86 (0.68 to 0.97) 0.86 (0.69 to 1.007) | 5 to 8 (0 to 17) | | 1.02 (0.94 to 1.10) | | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
60-69 | 0.67 (0.54 to 0.83) 0.67 (0.55 to 0.91) | 12 to 21 (3 to 32) | | 0.97 (0.90 to 1.04) | | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
70-74 | 0.80 (0.51 to 1.28) 0.90 (0.46 to 1.78) | 12 to 13 (0 to 32) | | 0.98 (0.86 to 1.14) | | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
50-69 | 0.78 (0.68 to 0.90) 0.81 (0.69 to 0.95) | 6 to 13 (1 to 20) | 0.75 (0.69 to 0.81)^§^ 0.69 (0.57 to 0.83)║ | | 0.62 (0.46 to 0.83)

*From meta-analyses of screening trials using two different methods of case accrual; long case accrual results are provided first, then short case accrual results.

† Based on trials of screening included in the meta-analysis.

‡ Based on a study in Sweden, and a study in Canada (standardized mortality ratio), respectively.

§ Based on seven incidence-based mortality studies.

║ Based on eight case-control studies.

Abbreviations: CI=confidence interval; RR=relative risk.

Harms of Mammography Screening

Age, years | False-positive mammography^*^ | Additional imaging recommended^*^ | Biopsy recommended^*^ | 10-yr FP mammography rates (annual; biennial) | 10-yr FP biopsy rates (annual; biennial) | Overdiagnosis estimates from RCTs % (95% CI)^†^ | Overdiagnosis estimates from screening programs^‡^ | Radiation exposure
40-49 | 121.2 | 124.9 | 16.4 | 61% 42% | 7% 5% | 10.7 (9.3 to 12.2) 19.0 (15.2 to 22.7) | 0 to 54% unadjusted 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^
50-59 | 93.2 | 98.5 | 15.9 | 61% 42% | 9% 6% | 10.7 (9.3 to 12.2) 19.0 (15.2 to 22.7) | 0 to 54% unadjusted 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^
60-69 | 80.8 | 88.7 | 16.5 | | | 10.7 (9.3 to 12.2) 19.0 (15.2 to 22.7) | 0 to 54% unadjusted 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^
70-74 | 69.6 | 79.0 | 17.5 | | | 10.7 (9.3 to 12.2) 19.0 (15.2 to 22.7) | 0 to 54% unadjusted 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^

*Number per 1,000 screened per screening round.

† From meta-analysis of screening trials using two different methods of case accrual; long case accrual results are provided first, then short case accrual results.

‡ From EUROSCREEN review based on 13 studies overall and 6 studies adjusted for breast cancer risk and lead time.

§ From a model of digital mammography.

Abbreviations: CI=confidence interval; FP=false positive.

Observational studies of population-based mammography screening reported a wide range of reductions in breast cancer mortality. Most studies were conducted in Europe or the United Kingdom and included women age 50 to 69 years. Meta-analyses of studies indicated a breast cancer mortality RR of 0.75 (95% CI, 0.69 to 0.81) based on seven incidence-based mortality studies; and an OR of 0.69 (95% CI, 0.57 to 0.83) based on seven case-control studies. The 25 to 31 percent mortality reduction from observational studies compares with a 19 to 22 percent reduction estimated from the meta-analysis of screening trials for women age 50 to 69 years. A large observational study of Swedish women in their 40s indicated 26 percent reduction in breast cancer mortality for women invited to screening, while a Canadian study indicated 44 percent reduction for screening participants. These mortality reductions compare with 12 to 16 percent mortality reductions in the trials, although the trial estimates were only of borderline statistical significance.

All-cause mortality did not differ between randomized groups in meta-analyses of trials, regardless of whether trials were analyzed in combined or separate age groups. Also, no trials evaluated mortality outcomes on the basis of risk factors besides age, and there are no head-to-head trials of the effectiveness of different screening intervals or modalities.

The screening trials also provided several measures of intermediate breast cancer outcomes. When thresholds for advanced disease were defined by the most severe categories available from the trials (Stage III + IV disease, size ≥50 mm), a meta-analysis indicated a significant reduction in advanced disease for women age 50 years and older randomized to screening versus nonscreening groups (RR 0.62; 95% CI, 0.46 to 0.83; 3 trials), but not for women age 39 to 49 years. This reduction in intermediate outcomes aligns with the reduction in mortality outcomes that were also statistically significant in the trials for the older age groups.

Although no trials evaluated the incidence of advanced breast cancer outcomes and treatment on the basis of risk factors or screening intervals, an analysis of BCSC data indicated a lower proportion of Stage III + IV disease among women age 40 to 49 years screened annually versus biennially. Also, BCSC data indicated that women age 40 to 49 years with extremely dense breasts had increased risks for advanced stage cancer (IIB+) and large-size tumors (>20 mm) with biennial compared with annual screening. These results suggest that women in their 40s with increased risk may reduce their risk for higher stage tumors with screening, even though mortality outcomes were not significantly reduced in the trials. These findings are consistent with a modeling study based on BCSC data that indicated that women in their 40s with 2-fold increases in risk (such as with extremely dense breasts) would experience benefits and harms comparable with average-risk women in their 50s when using life-years as the benefit metric.66

A Cochrane review that included five screening trials indicated that women randomized to screening were significantly more likely to have surgical and radiation therapy, and less likely to have hormone therapy than controls, while use of chemotherapy was similar between groups. This finding would be expected because screening increases detection of DCIS and early stage disease that are currently aggressively treated. However, treatment outcomes in the RCTs represent outdated therapies that limit their applicability. Observational studies of the impact of screening on advanced cancer diagnosis and treatment generally provided comparisons between screen-detected and nonscreened-detected cases rather than rates between screening populations that more directly address this Key Question.

There were few studies meeting inclusion criteria that compared the effectiveness of screening across various modalities, despite the increasing use of them in clinical practice. Tumor size, stage, and node status did not differ between women screened with tomosynthesis and digital mammography compared with those receiving mammography alone in two case series studies.

Several potential harms were also addressed in this systematic review. Updated BCSC data on digital mammography indicated that false-positive rates and recommendations for additional imaging were highest among women aged 40 to 49 years and declined with age, while false-negative rates were low across all age groups. Rates of recommendations for biopsy did not differ between ages. Results did not differ by time since last mammography screening regardless of whether broad or narrow estimates of one versus two years were used.

Several risk factors were statistically significantly associated with higher rates of false-positive and false-negative results and recommendations for additional imaging and biopsy across most age groups. These included family history of breast cancer, high breast density, and previous benign breast biopsy. Premenopausal status, use of menopausal hormone therapy, and lower BMI were associated with some of the outcomes for specific age groups only. Comparisons based on race and ethnicity indicated the lowest rates of false-positive results and additional imaging among Asians. Comparisons based on different combinations of breast density categories indicated that rates for all outcomes were lowest for women with almost entirely fat breasts, and highest for women with heterogeneously dense breasts or for those in the combined category of heterogeneous and extreme density. Women with extremely dense breasts had the highest rates of false-negative results.

While some risk factors reflect high exposure to estrogen and related changes in breast tissue (premenopause, menopausal hormone therapy), others may serve primarily as markers of increased breast cancer risk (family history, previous benign biopsy). The mechanisms of these risk factors and whether screening outcomes are influenced by how they affect the mammographic image, increase clinical suspicion, or other ways, are beyond the scope of this analysis.

Additional publications of BCSC data indicated that 10-year cumulative rates of false-positive mammography and biopsy results were higher for annual than biennial screening (mammography 61% vs. 41% biopsy 7% vs. 5%); for women with heterogeneously dense or extremely dense breasts; women in their 40s; and those who used combination hormone therapy.

Studies of overdiagnosis were primarily based on screening trials, screening programs and registries, or modeled data. Studies differed by their characteristics, methods, and measures, and estimates of the magnitude of overdiagnosis varied depending on the analytic approach, particularly regarding the different denominators used in the estimates. These estimates are difficult to apply to individual women because it is not known which types of cancer will progress, how quickly cancer will advance, and expected lifetimes.

Estimates of overdiagnosis from three RCTs that did not provide screening of controls at the end of the trial (Malmö I, CNBSS-1, CNBSS-2) indicated overdiagnosis rates of 11 to 22 percent. Unadjusted estimates from 13 observational studies indicated rates ranging from 0 to 54 percent; while six studies that adjusted for breast cancer risk and lead time indicated rates ranging from 1 to 10 percent.

Women with false-positive results were more distressed than women with negative results. Anxiety improved over time for most women, but persisted for over 2 years for some. Some women with false-positive results were less likely to return for their next mammogram, although studies were inconsistent. Although many women experienced pain during mammography (1% to 77%), the proportion of those experiencing pain who did not attend future screening varied (11% to 46%). Trials of interventions indicated that discomfort was reduced by providing written or verbal information or using breast cushions.

A U.S. study comparing tomosynthesis and mammography with mammography alone reported a significant reduction of 16 recalls per 1,000 women, but also an increase of 1.3 biopsies per 1,000 women. Mammography and CBE resulted in 55 per 10,000 additional recalls. Studies of screening with MRI or ultrasound focus on high-risk women. The number of deaths due to radiation induced cancer from screening with digital mammography was estimated through modeling as between 2 to 11 per 100,000 depending on age at onset and screening intervals. However, these models are based on assumptions that may not be accurate.

## Limitations

Limitations of this review include using only English-language articles, which could result in language bias, although we did not identify non–English-language studies that otherwise met inclusion criteria in our searches. We only included studies that are applicable to current practice in the United States in order to improve clinical relevance for the USPSTF, excluding much research in the field. This perspective may not be as relevant to other populations and settings. Despite using updated data, the RCTs of screening represent older technologies and cancer treatments that are not relevant today. Also, this update prioritized studies that addressed the Key Questions guiding the review. As with most areas of medicine, breast cancer screening does not exist in isolation, and applying inclusion criteria for studies places artificial boundaries around this complex topic. Many important issues could not be addressed because they were outside the scope of this review, including additional benefits (e.g., increasing breast awareness) and harms (e.g., economic hardship). Studies were lacking for some Key Questions, and the number, quality, and applicability of studies varied widely.

## Emerging Issues and Next Steps

Breast cancer is a continuum of entities, not just one disease, that must be considered when choosing screening and treatment options and when balancing benefits and harms. None of the screening trials consider breast cancer in this manner. As diagnostic and treatment experiences become more individualized234 and include patient preferences and decision making, it becomes even more difficult to characterize benefits and harms in a general way. Many patients would consider quality-of-life issues important outcomes, although these issues are more difficult to measure and report in research studies.

New technologies, such as tomosynthesis and MRI, are becoming more widely used in the United States without definitive studies of their effects on screening outcomes. Consumer expectations that new technology is better than old may obscure potential adverse effects, such as higher false-positive results, biopsies, and expense. No screening trials incorporating newer technologies have been published, and estimates of benefits and harms in this report are based predominantly on studies of film and digital mammography. No trials have evaluated the appropriate interval for mammography screening or the role of risk factors.

## Relevance for Priority Populations

Women age 70 years and older are a rapidly growing population in the United States, yet research on breast cancer screening and prevention in this age group is limited. Observational studies suggest that older women may benefit from regular mammography screening.235,236

Most of the screening trials and studies of screening programs were based in Europe and the United Kingdom, and enrolled predominantly white women. Data on race and ethnicity from the BCSC suggest possible differences between groups, but inferences from these subgroups are generally inconclusive because of lower numbers of participants and missing data.

Very little research has been conducted on women who are not screened in the United States, whether by choice, access, or other issues. Individuals who do not participate in screening and prevention services differ from those who do, and particularly differ from women who enroll in research studies. More information about this population could lead to improvements that could serve them better than currently available services.

## Future Research

Additional research on benefits and harms of mammography screening with quality-of-life outcomes, as well as morbidity and mortality outcomes, would provide further understanding of the implications of routine screening. Data for specific groups of women, based on risk, racial and ethnic background, access to screening, or existence of co-morbidities, for example, could inform screening practice. Studies of older women are essential in order to improve the evidence on screening for them including when to discontinue screening. Studies on the role of additional imaging modalities in screening are required in order to appropriately incorporate this technology in the screening process. More information on DCIS is needed, including its implications and outcomes. Distinguishing aggressive from non-aggressive forms of DCIS could lead to more selective treatment and reduce the consequences of overdiagnosis, particularly uncertainties regarding the transition from DCIS to invasive cancer, and lead time issues. Improving the methodology and assumptions involved in estimates of overdiagnosis would provide more meaningful understanding of this potential harm.

## Conclusions

Trials indicate that mammography screening prevents 4 deaths per 10,000 women age 40 to 49 years after 10 years; 5 to 8 for age 50 to 59 years; and 12 to 21 for age 60 to 69 years; while estimates for age 70 to 74 years are limited by low numbers. These results are generally supported by observational studies of screening programs of women age 50 to 69 years. Higher stage tumors are also reduced with screening for women over age 50 years and for younger women with dense breasts who have annual compared with biennial screening. False-positive results and additional imaging are common, particularly for younger women and those with risk factors, while biopsies occur less often. Rates of false-negative results are low. Estimates of overdiagnosis based on trials ranged from 11 to 22 percent, while estimates based on observational studies ranged from 1 to 10 percent. Although RCTs are lacking, observational studies of tomosynthesis and digital mammography indicate reduced recalls, but increased cancer detection and biopsy rates. Mammography screening at any age is a tradeoff of a continuum of benefits and harms that varies on population and individual levels.